# Creating Registries

1 Patient Registries

2 Planning a Registry

3 Registry Design

4 Use of Registries in Product Safety Assessment

5 Data Elements for Registries

6 Data Sources for Registries

7 Linking Registry Data: Technical and Legal Considerations

8 Principles of Registry Ethics, Data Ownership, and Privacy