# Registry Design

## Introduction

This chapter is intended as a high-level practical guide to the application of epidemiologic methods that are particularly useful in the design of registries that evaluate patient outcomes. Since it is not intended to replace a basic textbook on epidemiologic design, readers are encouraged to seek more information from textbooks and scientific articles. Table 1, on this page, summarizes the key considerations for study design that are discussed in this chapter. Throughout the design process, registry planners may want to discuss options and decisions with the registry stakeholders and relevant experts to ensure that sound decisions are made. The choice of groups to be consulted during the design phase generally depends on the nature of the registry, the registry funding source and funding mechanism, and the intended audience for registry reporting. A more detailed discussion of registry design, specific to product safety, is provided in Chapter 4.

Table 1 Considerations for Study Design

Construct | Relevant questions
Research question | What are the clinical and/or public health questions of interest?
Resources | What resources, in terms of funding, sites, clinicians, and patients, are available for the study?
Exposures and outcomes | How do the clinical questions of interest translate into measurable exposures and outcomes?
Data sources | Where can the necessary data be found?
Study design | What types of design can be used to answer the questions or fulfill the purpose?
Study population | What types of patients are needed for study? Is a comparison group needed? How should patients be selected for study?
Sampling | How should the study population be sampled, taking into account the target populations and study design?
Study size and duration | For how long should data be collected, and for how many patients?
Internal and external validity | What are the potential biases? What are the concerns about generalizability of the results (external validity)?

## Research Questions Appropriate for Registries

The questions typically addressed in registries range from purely descriptive questions aimed at understanding the characteristics of people who develop the disease and how the disease generally progresses, to highly focused questions intended to support decisionmaking. Registries focused on determining clinical effectiveness or cost-effectiveness or assessing safety or harm are generally hypothesis driven and concentrate on evaluating the effects of specific treatments on patient outcomes. Research questions should address the registry’s purposes, as broadly described in Table 2.

Table 2 Overview of Registry Purposes

• Assessing natural history, including estimating the magnitude of a problem; determining the underlying incidence or prevalence rate; examining trends of disease over time; conducting surveillance; assessing service delivery and identifying groups at high risk; documenting the types of patients served by a health provider; and describing and estimating survival.
• Determining clinical effectiveness, cost-effectiveness, or comparative effectiveness of a test or treatment, including evaluating the acceptability of drugs, devices, or procedures for reimbursement.
• Measuring or monitoring safety and harm of specific products and treatments, including conducting comparative evaluation of safety and effectiveness.
• Measuring or improving quality of care, including conducting programs to measure and/or improve the practice of medicine and/or public health.

Observational studies derived from registries are often considered alternatives to randomized controlled trials (RCTs). While observational studies and RCTs can be complementary research methodologies, some research questions are better answered by one method than the other. RCTs are considered by many to provide the highest grade evidence for evaluating whether a drug has the ability to bring about an intended effect in optimal or “ideal world” situations, a concept also known as “efficacy.”1 In some situations, registries may be preferable designs for studies of effectiveness—that is, whether a drug, device, procedure, or program in fact achieves its desired effect in the real world. (See Case Example 7.) This is particularly true when the factors surrounding the decision to treat are an important aspect of understanding treatment effectiveness.

Case Example 7 Designing a Registry for a Health Technology Assessment

Description | The Nuss procedure registry was a short-term registry designed specifically for the health technology assessment of the Nuss procedure, a novel, minimally invasive procedure for the repair of pectus excavatum, a congenital malformation of the chest. The registry collected procedure outcomes, patient-reported outcomes, and safety outcomes.
Sponsors | National Institute for Health and Clinical Excellence (NICE), United Kingdom
Year Started | 2004
Year Ended | 2007
No. of Sites | 13 hospitals
No. of Patients | 260 patients

#### Challenge

The Nuss procedure is a minimally invasive intervention for the repair of pectus excavatum. During a review of the evidence supporting this procedure conducted in 2003, the National Institute for Health and Clinical Excellence (NICE) determined that the existing data included relatively few patients, few quality of life outcomes, and did not sufficiently address safety concerns. NICE concluded in the 2003 review that the evidence was not adequate for routine use and that more evidence was needed to make a complete assessment of the procedure.

#### Proposed Solution

Gathering additional evidence through a randomized controlled trial was not feasible for several reasons. First, a blinded trial would be difficult because the other procedures for the repair of pectus excavatum produce much larger scars than the Nuss procedure. Surgeons also tend to either perform only the Nuss procedure or only another procedure, a factor which would complicate randomization efforts. In addition, only a small number of procedures are done in the United Kingdom. The sample for a randomized trial would likely be very small, making it difficult to detect rare adverse events.

Due to these limitations, NICE decided to develop a short-term registry to gather evidence on the Nuss procedure. The advantages of a registry were its ability to gather data on all patients undergoing the procedure in the UK to provide a more complete safety assessment, and its ability to collect patient-reported outcomes.

The registry was developed by an academic partner, with input from clinicians. Hospitals performing the procedure were identified and asked to enter data into the registry on all patients undergoing the intervention. Once the registry was underway, the cases in the registry were compared against cases included in the Hospital Episodes Statistics (HES) database, a nationwide source of routine data on hospital activity, and nonparticipating hospitals were identified and prompted to enter their data.

#### Results

NICE conducted a reassessment of the Nuss procedure in 2009, comparing data from the registry to other published evidence on safety and efficacy. The quantity of published literature had increased substantially between 2003 and 2009. The new publications primarily focused on technical and safety outcomes, while the registry included patient-reported outcomes. The literature and the registry reported similar rates of major adverse events such as bar displacement (from 2 to 10 percent). Based on the registry data and the new literature, the review committee found that the evidence was now sufficient to support routine use of the Nuss procedure, and no further review of the guidance is planned. Committee members considered that the registry made a useful contribution to guidance development.

#### Key Point

The Nuss registry demonstrated that a small, short-term, focused registry with recommended (but not automatic or mandatory) submission can produce useful data, both about safety and about patient-reported outcomes.

In many situations, nonrandomized comparisons either are sufficient to address the research question or, in some cases, may be necessary because of the following issues with randomized treatment:

- Equipoise: Can providers ethically introduce randomization between treatments when the treatments are not clinically equivalent?
- Ethics: If reasonable suspicion about the safety of a product has become known, would it be ethical to conduct a trial that deliberately exposes patients to potential harm? For example, can pregnant women be ethically exposed to drugs that may be teratogenic? (See Case Example 8.)
- Practicality: Will patients enroll in a study where they might not receive the treatment, or might not receive what is likely to be the best treatment? How can compliance and adherence to a treatment be studied, if not by observing what people do in real-world situations?

Case Example 8 Assessing the Safety of Products Used During Pregnancy

Description | The Antiretroviral Pregnancy Registry is the oldest ongoing pregnancy exposure registry. This multisponsor, international collaborative registry monitors prenatal exposures to all marketed antiretroviral drugs, which include several drug classes and multiple drugs in each class.
Sponsors | Abbott Laboratories, Aurobindo Pharma, Barr Laboratories, Boehringer Ingelheim Pharmaceuticals, Bristol-Myers Squibb Company, Cipla, Gilead Sciences Inc, GlaxoSmithKline, Hetero USA, Merck & Co. Inc, Mylan Laboratories, Novartis Pharmaceuticals, Pfizer, Ranbaxy, Roche, and Tibotec BVBA.
Year Started | 1989
Year Ended | Ongoing
No. of Sites | Not site based; open to all health care providers. More than 1,200 health care providers have enrolled patients.
No. of Patients: | 12,500

#### Challenge

Data on the teratogenic effects of pharmaceutical products is often difficult to obtain. Most clinical trials exclude pregnant women because of ethical concerns about potentially exposing the fetus to harm. While data on teratogenic risk is available from preclinical animal testing, this information is not always predictive of the effects of a drug taken during human pregnancy. As a result, data are often lacking to help patients and physicians understand the potential risks and benefits of continuing a treatment during pregnancy.

There is a great need for this information, because pregnant women may receive drugs for many reasons; for example, to treat an illness that arises during pregnancy, or to treat a chronic mental or physical illness. Women may also become pregnant while taking a drug, with the result that the fetus receives an unintended exposure. This last scenario is particularly likely, given that 50 to 60 percent of all pregnancies in the United States are unintended, and most are not recognized until late in the first trimester.

Antiretroviral treatments represent an area of particular concern, as women may need to take the drugs during pregnancy to manage their HIV infection. In addition, these drugs can reduce the risk of transmitting HIV to the infant, but this benefit must be weighed against the risk of teratogenic effects. Because of these factors, it is extremely important for clinicians and patients to understand the risks of using antiretroviral drugs during pregnancy in order to make an informed decision. However, ethical and practical concerns make a randomized trial to gather these data difficult, if not impossible.

#### Proposed Solution

In 1989, the first manufacturer of an antiretroviral drug voluntarily initiated a pregnancy exposure registry to track the outcomes of women who had used its product during pregnancy. The purpose of the registry is to collect information on any teratogenic effects of the product by prospectively enrolling women during the course of their pregnancy and following up with them to determine the outcome of the pregnancy. Physicians enroll a patient by providing information on the pregnancy dates, characteristics of the HIV infection, drug dosage, length of therapy, and trimester of exposure to the antiretroviral drug. Information on the pregnancy outcome is gathered through a followup form sent to the physician after the expected delivery date.

In 1993, the registry was expanded to include all antiretroviral drugs, as other manufacturers voluntarily joined the registry once their drugs were on the market. The registry is international in scope and allows any health care provider to enroll a patient who has intentional or unintentional use of an antiretroviral drug during pregnancy. The U.S. Food and Drug Administration (FDA), which has used this registry as a model for new pregnancy registries, now requires participation in the registry for all new and generic antiretroviral drugs.

#### Results

Since its inception 20 years ago, the registry has provided many lessons, and developed processes, on how to monitor and assess the safety of these drugs during pregnancy. To ensure both rigor and consistency, it has put in place predefined analytic methods and criteria for recognizing a potential teratogenic signal.

The monitoring system developed by the registry includes several groups, which provide different levels of monitoring. The groups include:

- Steering Committee (comprised of representatives of all groups below).
- Scientific Advisory Committee (comprised of experts from FDA, Centers for Disease Control and Prevention [CDC], National Institutes of Health [NIH], and academia).
- Birth Defect Review Committee (comprised of representatives from the other groups).
- Sponsor Committee (comprised of epidemiologists and safety experts).
- Consultants (geneticist and pharmacoepidemiologist).
- Coordinating Center staff (epidemiologist, project manager, and clinical research associates).

Tools for coding and classifying birth defects have been developed specifically for the registry to maximize the likelihood of identifying a teratogenic signal. This unique system groups birth defects by etiology or embryology rather than by general location or category, as does the Medical Dictionary for Regulatory Activities (MedDRA). Grouping like defects together increases the likelihood of detecting a potential signal. Another unique aspect of this registry that aids in signal detection is coding the temporal association between timing of exposure and formation of the birth defect.

Specific monitoring criteria have been developed for evaluating signals at various levels, including:

- Individual and composite data.
- Use of the Rule of Three—that three exposure-specific cases with the same birth defect requires immediate evaluation. This rule is based on the statistical principle that the likelihood of finding at least three of any specific defect in a cohort of 600 or fewer by chance alone is less than 5 percent.
- Primary analysis (statistical considerations, including power/relative risk calculation and statistical probabilities associated with detecting various birth defects using internal and external comparators).
- Complementary data, including clinical studies in pregnancy, retrospectively reported data, other registries or epidemiological studies, published studies, and case studies.

These efforts to monitor and study the teratogenic effects of antiretroviral use during pregnancy have produced many publications. Registry data have been used in 9 publications, 7 abstracts, and 22 presentations, and the registry design and operation have been the subject of many publications and presentations. The registry data and publications can help to provide clinicians and patients with information to make informed decisions regarding use of antiretroviral drugs during pregnancy.

#### Key Point

An observational registry can collect data to answer research questions in cases where a randomized trial is not feasible for ethical or practical reasons. For pregnancy exposure registries, the observational model allows the researchers to gather data on women and infants exposed to products during pregnancy without deliberately introducing the exposure.

#### For More Information

Tilson H, Doi PA, Covington DL, et al. The antiretrovirals in pregnancy registry: A fifteenth anniversary celebration. Obstet Gynecol Surv. 2007;62:137-48. [pmid: 17229330].
Watts D, Covington D, Beckerman K, et al. Assessing the risk of birth defects associated with antiretroviral exposure during pregnancy. Am J Obstet Gynecol. 2004;191:985-92. [pmid: 15467577].
Covington D, Tilson H, Elder J, et al. Assessing teratogenicity of antiretroviral drugs: monitoring and analysis plan of the Antiretroviral Pregnancy Registry. Pharmacoepidemiol Drug Saf. 2004;13:537-45. [pmid: 15317035].
Scheuerle A, Covington D. Clinical review procedures for the Antiretroviral Pregnancy Registry. Pharmacoepidemiol Drug Saf. 2004;13:529-36. [pmid: 15317034].

Registries are particularly suitable for situations where experimental research is not feasible or practical, such as:

- Natural history studies where the goal is to observe clinical practice and patient experience but not to introduce any intervention.
- Measures of clinical effectiveness, especially as related to compliance, where the purpose is to learn about what patients and practitioners actually do and how their actions affect outcomes, if at all, rather than to observe the effects of products used according to a study protocol. This is especially important for treatments that have poor compliance.
- Studies of effectiveness and safety for which clinician training and technique are part of the study of the treatment (e.g., a procedure such as placement of carotid stent).
- Studies of heterogeneous patient populations, since unlike randomized trials, registries generally have much broader inclusion criteria and fewer exclusion criteria. These characteristics lead to studies with greater generalizability (external validity).
- Followup for delayed or long-term benefits or harm, since registries can extend over much longer periods than most clinical trials (because of their generally lower costs to run and lesser burden on participants).
- Surveillance for rare events or of rare diseases.
- Studies for treatments in which randomization is unethical, such as intentional exposure to potential harm (as in safety studies of marketed products that are suspected of being harmful).
- Studies for treatments in which randomization is not necessary, such as when certain therapies are only available in certain places owing to high cost or other restrictions (e.g., proton beam therapy).
- Studies for which blinding is challenging or unethical (e.g., studies of surgical interventions, acupuncture).
- Studies of rapidly changing technology.
- Studies of conditions with complex treatment patterns and treatment combinations.
- Studies of health care access and barriers to care.
- Evaluations of actual standard medical practice. (See Case Example 9.)

Registry studies may also include embedded substudies as part of their overall design. These substudies can themselves have various designs (e.g., highly detailed prospective data collection on a subset of registry participants, or a case-control study focused on either incident or prevalent cases identified within the registry). (See Case Example 10.) Registries can also be used as sampling frames for RCTs.

Case Example 9 Designing a Registry To Study Outcomes

Description | The Carotid Artery Stenting with Emboli Protection Surveillance Post-Marketing Study (CASES-PMS) was designed to assess the outcomes of carotid artery stent procedures for the treatment of obstructive artery disease during real-world use. The primary purpose of the registry was to evaluate outcomes in the periapproval setting, including the use of a detailed training program for physicians not experienced in carotid artery stenting.
Sponsor | Cordis Corporation
Year Started | 2004
Year Ended | 2006
No. of Sites | 74
No. of Patients | 1,493

#### Challenge

In 2004, the sponsor received approval for a carotid stent procedure from the U.S. Food and Drug Administration (FDA), largely because of the results of the Stenting and Angioplasty With Protection in Patients at HIgh Risk for Endarterectomy (SAPPHIRE) clinical trial. The SAPPHIRE trial studied the results of stent procedures performed by experts in the field. While the trial provided strong data to support the approval of the carotid stent, FDA and the Centers for Medicare & Medicaid Services (CMS) both questioned whether the outcomes of the trial were generalizable to procedures performed by physicians without prior experience in carotid artery stenting.

To respond to the FDA and CMS requests, the sponsor needed to design a study to confirm the safety and effectiveness of carotid artery stenting in a variety of settings. The study needed to gather data from academic and nonacademic settings, from physicians with various levels of carotid stenting experience, from settings with varying levels of carotid stenting volume, and from a geographically diverse mix of sites. The study would also need to examine the effectiveness of a training program that the sponsor had designed to teach physicians about the stenting procedure.

#### Proposed Solution

The sponsor designed a comprehensive training program for physicians and other health care professionals. The training program, which began in 2004, included didactic review, case observations and simulation training, and hands-on experience. To study the effectiveness of the training program and to provide data on the clinical safety and effectiveness of carotid stenting in a variety of settings, the sponsor designed and launched the registry in 2004.

The registry was a multicenter, prospective, observational study designed to assess stenting outcomes in relation to the outcomes of the SAPPHIRE trial (historic comparison group). The study enrolled 1,493 patients from 74 sites, using inclusion and exclusion criteria that matched those of the SAPPHIRE trial. The patients in the study were high-surgical-risk patients with de novo atherosclerotic or postendarterectomy restenotic obstructive lesions in native carotid arteries. Study participants completed clinical followups at 30 days and again at 1 year after the procedure. The 30-day assessments included a neurological examination by an independent neurologist and an evaluation of adverse events. The study defined the 30-day major adverse event rate as the 30-day composite of all deaths, myocardial infarctions, and strokes.

#### Results

The 30-day major adverse event rate of 5.0 percent met the criteria for noninferiority to the outcomes of stented patients from the pivotal SAPPHIRE trial. Outcomes were similar across levels of physician experience, carotid stent volume, geographic location, and presence/absence of the training program. The initial findings show that a comprehensive, formal training program in carotid stenting enables physicians from multiple specialties with varying levels of experience in carotid stenting to achieve outcomes similar to those achieved by the experts in the clinical trial

#### Key Point

An observational registry can provide the necessary data for a postmarket evaluation of devices that are dependent on newly acquired skills. The registry can provide data to assess both the clinical safety of the device and the effectiveness and success of a training program.

#### For More Information

Katzen B, Criado F, Ramee S, et al. on behalf of the CASES-PMS Investigators: Carotid artery stenting with emboli protection surveillance study: 30-day results of the CASES-PMS study. Catheter Cardiovasc Interv. 2007;70:316-23. [pmid: 17630678].
Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. N Engl J Med. 2004;351:1493-501. [pmid: 15470212].

Case Example 10 Analyzing Clinical Effectiveness and Comparative Effectiveness in an Observational Study

Description | The National Cooperative Growth Study (NCGS) collects data on children with growth disorders who are treated with a specific growth hormone (GH). The purpose of the multicenter, observational, postmarketing surveillance registry is to collect long-term safety and efficacy information on the GH preparations, with the goal of better understanding the growth response to GH therapy.
Sponsor | Genentech, Inc.
Year Started | 1985
Year Ended | Ongoing
No. of Sites | More than 500 centers have participated over the life of the registry.
No. of Patients | 47,226 at time of analysis

#### Challenge

Clinical trials of GH therapy for short children without GH deficiency and without known etiology for their growth failure (idiopathic short stature, or ISS) have generally only included a small number of patients. The registration trial for the sponsor’s GH therapy for the ISS condition was comprised of 118 children at baseline. While the trial demonstrated the efficacy of the treatment and an indication was obtained, physicians and families had lingering concerns about the applicability (safety and effectiveness) of the results to clinical practice.

#### Proposed Solution

To provide further safety and effectiveness data, the sponsor compared the data in the registration trial with data in the existing NCGS registry. In the 18-year period used in the analysis, the registry contained 8,018 children without GH deficiency and with no identified etiology for their growth failure. The analysis team extracted the data from these 8,018 children as a comparator to the 118 children in the sponsor’s clinical registration trial. For the purposes of the safety analysis, the analysis team summarized all reportable adverse events, serious adverse events, and certain targeted adverse events specified by the protocol for the registry cohort and compared these data with data from the clinical trial cohort. For the purposes of the effectiveness analysis, the analysis team selected children from the registry who matched the clinical characteristics of the trial cohort (age 5 years or older, prepubertal, maximum stimulated GH 10 ng/ml or more, no text report of contraindicating diagnosis, naive to previous therapy, and receiving a dose of GH similar to that in the clinical trial). The team found 1,721 patients who had at least 1 year of treatment data reported. The team compared these data with the growth rates of the children in the registration trial by year of treatment.

In addition, the team performed an analysis to look at children in the registry younger than those in the registration trial to provide clinical data that would be useful to clinicians but could not be obtained easily in a clinical trial. Lastly, the team completed an analysis on children in puberty, another group that could not be studied in the registration trial because of the confounding variable of puberty and the insufficient numbers in the trial to account for this variable versus the effect of GH alone.

#### Results

The results of these analyses using the registry data and the sponsor’s registration trial data demonstrated that ISS patients in a clinical setting had a significant increase in height similar to that of patients in the registration trial, with no new safety signals. Children in groups not studied in the registration trial had characteristic growth patterns that could be used by clinicians as comparators not available from the registration trial. Finally, the lack of new safety signals from any of the groups in the registry provided data in numbers and in years of exposure to GH that could never be obtained from a small registration trial.

#### Key Point

A large registry can provide a resource of study subjects for focused investigations. Inclusion and exclusion criteria can be designed to match those of a registration trial to provide more robust data on outcomes and safety.

#### For More Information

Kemp SF, Kuntze J, Attie KM, et al. Efficacy and safety results of long-term growth hormone treatment of idiopathic short stature. J Clin Endocrinol Metab. 2005;90:5247-53. [pmid: 15998780].

## Translating Clinical Questions Into Measurable Exposures and Outcomes

The specific clinical questions of interest in a registry will guide the definitions of study subjects, exposure, and outcome measures, as well as the study design, data collection, and analysis. In the context of registries, the term “exposure” is used broadly to include treatments and procedures, health care services, diseases, and conditions.

The clinical questions of interest can be defined by reviewing published clinical information, soliciting experts’ opinions, and evaluating the expressed needs of the patients, health care providers, and payers. Examples of research questions, key outcome and exposure variables, and sources of data are shown in Table 3. As these examples show, the outcomes (generally beneficial or deleterious outcomes) are the main endpoints of interest posed in the research question. These typically represent measures of health or onset of illness or adverse events, but also commonly include quality of life measures, and measures of health care utilization and costs.

Table 3 Examples of Research Questions and Key Exposures and Outcomes

Research question | Key exposure (source of data) | Key outcome (source of data)
What is the expected time to rejection for first kidney transplants among adults, and how does that differ according to immunosuppressive regimen? | All immunosuppressants, including dosage and duration (clinician) | Organ rejection (clinician)
Are patients using a particular treatment better able to perform activities of daily living than others? | Treatments for the disease of interest (clinician) | Ability to independently perform key activities related to daily living (patient)
Do patients undergoing gastric bypass surgery for weight loss utilize fewer health care resources in the year following surgery? | Surgery (clinician) | Number of inpatient and outpatient visits, medications dispensed, associated costs (administrative databases, clinician)
Are patients using a particular drug more likely to have serious adverse pregnancy outcomes? | Drug use by mother during pregnancy (clinician or patient) | Pregnancy outcome (clinician or patient)

Relevant exposures also derive from the main research question and relate to why a patient might experience benefit or harm. Evaluation of an exposure often takes into account not only the exposure of interest but also information that affects or augments the main exposure, such as dose, duration of exposure, route of exposure, or adherence. Other exposures of interest include independent risk factors for the outcomes of interest (e.g., comorbidities, age), as well as variables known as potential confounding variables, that are related to both the exposure and the outcome and are necessary for clarifying analyses. Confounding can result in the statistical detection of a significant association between the study variables where no real association between them exists. For example, in a study of asthma medications, prior history of treatment resistance should be collected or else results may be biased. The bias could occur because treatment resistance may relate both to the likelihood of receiving the new drug (meaning that doctors will be more likely to try a new drug in patients who have failed other therapies) and the likelihood of having a poorer outcome (e.g., hospitalization). Refer to Chapter 5 for a discussion of selecting data elements.

## Finding the Necessary Data

The identification of key outcome and exposure variables and patients will drive the strategy for data collection, including the choice of data sources. A key challenge to registries is that it is generally not possible to collect all desired data. As discussed in Chapter 5, data collection should be both parsimonious and broadly applicable. For example, while experimental imaging studies may provide interesting data, if the imaging technology is not widely available, the data will not be available for enough patients to be useful for analysis. Moreover, the registry findings will not be generalizable if only sophisticated centers that have such technology participate. Instead, registries should focus on collecting relevant data with relatively modest burden on patients and clinicians. Registry data can be obtained from patients, clinicians, medical records, and linkage with other sources (in particular, extant databases), depending on the available budget. (See Chapter 10.)

Examples of patient-reported data include health-related quality of life; utilities (i.e., patient preferences); symptoms; use of over-the-counter (OTC), complementary, and alternative medication; behavioral data (e.g., smoking and alcohol use); family history; and biological specimens. These data may rely on the subjective interpretation and reporting of the patient (e.g., health-related quality of life, utilities, symptoms such as pain or fatigue); may be difficult to otherwise track (e.g., use of complementary and alternative medication, smoking, and alcohol use); or may be unique to the patient (e.g., biological specimens). Health care resource utilization is another important construct that reflects both on cost of care (burden of illness) and on health-related quality of life. For example, more frequent office visits, procedures, or hospitalizations may result in reduced health-related quality of life for the patient. The primary advantage of this form of data collection is that it provides direct information from the entity that is ultimately of the most interest—the patient. The primary disadvantages are that the patient is not necessarily a trained observer and that various forms of bias, such as recall bias, may influence subjective information. For example, people may selectively recall certain exposures because they believe they have a disease that was caused by that exposure, or their recall may be influenced by recent news stories claiming cause-and-effect relationships.

Examples of clinician data include clinical impressions, clinical diagnoses, clinical signs, differential diagnoses, laboratory results, and staging. The primary advantage of clinician data is that clinicians are trained observers. Even so, the primary disadvantages are that clinicians are not necessarily accurate reporters of patient perceptions, and their responses may also be subject to recall bias. Moreover, the time that busy clinicians can devote to registry data collection is often limited.

Medical records also are a repository of clinician-derived data. Certain data about treatments, risk factors, and effect modifiers are often not consistently captured in medical records of any type, but where available, can be useful. Examples of such data that are difficult to find elsewhere include OTC medications, smoking and alcohol use, complementary and alternative medicines, and counseling activities by the clinician on lifestyle modifications. Medical records are often relied upon as a source of detailed clinical information for adjudication by external reviewers of medical diagnoses corresponding to study endpoints.

Electronic medical records, increasingly available, improve access to the data within medical records. The increasing use of electronic health records has facilitated the development of a number of registries within large health plans. Kaiser Permanente has created several registries of patients receiving total joint replacement, bariatric surgery, and nonsurgical conditions (e.g., diabetes), all of which rely heavily on existing electronic health record data. As discussed further in Chapter 10, the availability of medical records data in electronic format does not, by itself, guarantee consistency of terminology and coding.

Examples of other data sources include health insurance claims, pharmacy data, laboratory data, other registries, and national datasets, such as Medicare claims data and the National Death Index. These sources can be used to supplement registries with data that may otherwise be difficult to obtain, subject to recall bias, not collected because of loss to followup, or likely inaccurate by self-report (e.g., in those patients with diseases affecting recall, cognition, or mental status). See Table 8 in Chapter 6 for more information on data sources.

## Resources and Efficiency

Ideally, a study is designed to optimally answer a research question of interest and funded adequately based on the requirements of the design. Frequently, however, finite resources are available at the outset of a project that dictate the approaches that may be pursued. Often, through efficiencies in the selection of a study design and patient population (observational vs. RCT, case-control vs. prospective cohort), selection of data sources (e.g., medical-records-based studies vs. information collected directly from clinicians or patients), restriction of the number of study sites, or other approaches, studies may be planned that provide adequate evidence for addressing a research question, in spite of limited resources.

The section below, Study Designs for Registries, discusses how certain designs may be more efficient for addressing some research questions.

## Study Designs for Registries

Although studies derived from registries are, by definition, observational studies, the framework for how the data will be analyzed drives the data collection and choices of patients for inclusion in the study.

The conventional study models of cohort, case-control, and case-cohort are commonly applied to registry data and are described briefly here. When case-control or case-cohort designs are applied to registry data, additional data may be collected to facilitate examination of questions that arise. Before adding new data elements, whether in a nested substudy or for a new objective, the steps outlined in Chapter 2 (e.g., assess feasibility, determine scope, evaluate regulatory/ethical impact) should be undertaken. Other models that are also useful in some situations, but are not covered here, include: case-crossover studies, which are efficient designs for studying the effects of intermittent exposures (e.g., use of erectile dysfunction drugs) on conditions with sudden onset, and quasi-experimental studies, in which providers are randomized as to which intervention or quality improvement tools they use, but patients are observed without further intervention. Also, there has been recent interest in applying the concept of adaptive clinical trial design to registries. An adaptive design has been defined as a design that allows adaptations or modifications to some aspects of a clinical trial after its initiation without undermining the validity and integrity of the trial.2 While many long-term registries are modified after initiation, the more formal aspects of adaptive trial design have yet to be applied to registries and observational studies.

Determining what framework will be used to analyze the data is important in designing the registry and the registry data collection procedures. Readers are encouraged to consult textbooks of epidemiology and pharmacoepidemiology for more information. Many of the references in Chapter 13 relate to study design and analysis.

### Cohort

Cohort studies follow, over time, a group of people who possess a characteristic, to see if they develop a particular endpoint or outcome. Cohort studies are used for descriptive studies as well as for studies seeking to evaluate comparative effectiveness and/or safety or quality of care. Cohort studies may include only people with exposures (such as to a particular drug or class of drugs) or disease of interest. Cohort studies may also include one or more comparison groups for which data are collected using the same methods during the same period. A single cohort study may in fact include multiple cohorts, each defined by a common disease or exposure. Cohorts may be small, such as those focused on rare diseases, but often they target large groups of people (e.g., in safety studies), such as all users of a particular drug or device. Some limitations of registry-based cohort studies may include limited availability of treatment data and underreporting of outcomes if a patient leaves the registry or is not adequately followed up.3 These pitfalls should be considered and addressed when planning a study.

### Case-Control

A case-control study gathers patients who have a particular outcome or who have suffered an adverse event (“cases”) and “controls” who have not but are representative of the source population from which the cases arise.4 If properly designed and conducted, it should usually yield results similar to those expected from a cohort study of the population from which the cases were derived. The case-control design is often employed for understanding the etiology of rare diseases5 because of its efficiency. In studies where expensive data collection is required, such as some genetic analyses or other sophisticated testing, the case-control design is more efficient and cost-effective than a cohort study because a case-control design collects information only from cases and a sample of noncases. However, if the study design is being applied to existing registry data, the use of the cohort design may be preferable since it avoids the challenge of selecting controls, which may introduce bias.

Depending on the outcome or event of interest, cases and controls may be identifiable within a single registry. For example, in the evaluation of restenosis after coronary angioplasty in patients with end-stage renal disease, investigators identified both cases and controls from an institutional percutaneous transluminal coronary angioplasty registry; in this example, controls were randomly selected from the registry and matched by age and gender.6 Alternatively, cases can be identified in the registry and controls chosen from outside the registry. Care must be taken, however, that the controls from outside the registry meet the same requirement of arising from the same source population as the cases to which they will be compared. Matching in case-control designs—for example, ensuring that patient characteristics such as age and gender are similar in the cases and their controls—may yield additional efficiency, in that a smaller number of subjects may be required to answer the study question with a given power. Matching variables must then be accounted for in the analysis, because a form of selection bias similar to confounding will have been introduced.7

Properly executed, a case-control study can add efficiency to a registry if more extensive data are collected by the registry only for the smaller number of subjects selected for the case-control study. This design is sometimes referred to as a “nested” case-control study, since subjects are taken from a larger cohort. It is generally applied because of budgetary or logistical concerns relating to the additional data desired. Nested case-control studies have been conducted in a wide range of patient registries, from studying the association between oral contraceptives and various types of cancer using the Surveillance Epidemiology and End Results (SEER) program8,9,10 to evaluating the possible association of depression with Alzheimer’s disease. As an example, in the latter case-control study design, probable cases were enrolled from an Alzheimer’s disease registry and compared to randomly selected nondemented controls from the same base population.11

### Case-Cohort

Case-cohort design is a variant of a case-control study. As in a case-control study, a case-cohort study enrolls patients who have a particular outcome or who have suffered an adverse event (“cases”) and “controls” who have not, but are representative of the source population from which the cases arise. In traditional case-control studies, each person in the source population has a probability of being selected as a control that is, ideally, in proportion to his or her person-time contribution to the cohort. In a case-cohort study, however, each control has an equal probability of being sampled from the source population.12 This allows for collection of pertinent data for cases and for a sample of the full cohort, instead of the whole cohort. For example, in a case-cohort study of histopathologic and microbiological indicators of chorioamnionitis, which included identification of specific microorganisms in the placenta, cases consisted of extreme preterm infants with cerebral palsy. Controls, which can be thought of as a randomly selected subcohort of subjects at risk of the event of interest, were selected from all infants enrolled in a long-term study of preterm infants.13

## Choosing Patients for Study

The purpose of a registry is to provide information or describe events and patterns, and often to generate hypotheses about a specific patient population to whom study results are meant to apply. Studies can be conducted of people who share common characteristics, with or without including comparison groups. For example, studies can be conducted of:

- People with a particular disease/outcome or condition. (These are focused on characteristics of the person.)
  – Examples include studies of the occurrence of cancer or rare diseases, pregnancy outcomes, and recruitment pools for clinical trials.
- Those with a particular exposure. (These exposures may be to a product, procedure, or other health service.)
  – Examples include general surveillance registries, pregnancy registries for particular drug exposures, and studies of exposure to medications and to devices such as stents.14 They also include studies of people who were treated under a quality improvement program, as well as studies of a particular exposure that requires controlled distribution, such as drugs with serious safety concerns (e.g., isotretinoin, clozapine, natalizumab [Tysabri^®^]), where the participants in the registry are identified because of their participation in a controlled distribution/risk management program.
- Those who were part of a program evaluation, disease management effort, or quality improvement project.
  – An example is the evaluation of the effectiveness of evidence-based program guidelines on improving treatment.

### Target Population

Selecting patients for registries can be thought of as a multistage process that begins with understanding the target population (the population to which the findings are meant to apply, such as all patients with a disease or a common exposure) and then selecting a sample of this population for study. Some registries will enroll all, or nearly all, of the target population, but most registries will enroll only a sample of the target population. The accessible population is that portion of the target population to which the participating sites have access. The actual population is the subset of those who can actually be identified and invited and who agree to participate.15 While it is desirable for the patients who participate in a study to be representative of the target population, it is rarely possible to study groups that are fully representative from a statistical sampling perspective, either for budgetary reasons or for reasons of practicality. An exception is registries composed of all users of a product (as in post-marketing surveillance studies where registry participation is required as a condition of receiving an intervention), an approach which is becoming more common to manage expensive interventions and/or to track potential safety issues.

There are certain populations that pose greater difficulties in assembling an actual population that is truly representative of the target population. Children and other vulnerable populations present special challenges in recruitment, as they typically will have more restrictions imposed by institutional review boards (IRBs) and other oversight groups.

As with any research study, very clear definitions of the inclusion and exclusion criteria are necessary and should be clearly documented, including the rationale for these criteria. A common feature of registries is that they typically have few inclusion and exclusion criteria, which enhances their applicability to broader populations. Restriction, the strategy of limiting eligibility for entry to individuals within a certain range of values for a confounding factor, such as age, may be considered in order to reduce the effect of a confounding factor when it cannot otherwise be controlled, but this strategy may reduce the generalizability of results to other patients.

These criteria will largely be driven by the study objectives and any sampling strategy. For a more detailed description of target populations and their subpopulations, and how these choices affect generalizability and interpretation, see Chapter 13.

Once the patient population has been identified, attention shifts to selecting the groups from which patients will be selected (e.g., choosing the institutions and providers). For more information on recruiting patients and providers, see Chapter 9.

### Comparison Groups

Once the target population has been selected and the mechanism for their identification (e.g., by providers) is decided, the next decision involves determining whether to collect data on comparators (sometimes called parallel cohorts). Depending on the purpose of the registry, internal, external, or historical groups can be used to strengthen the understanding of whether the observed effects are real and in fact different from what would have occurred under other circumstances. Comparison groups are most useful in registries where it is important to distinguish between alternative decisions or to assess differences, the magnitude of differences, or the strength of associations between groups. Registries without comparison groups can be used for descriptive purposes, such as characterizing the natural history of a disease or condition, or for hypothesis generation. The addition of a control group may add significant complexity, time, and cost to a registry.

Although it may be appealing to use more than one comparison group in an effort to overcome the limitations that may result from using a single group, multiple comparison groups pose their own challenges to the interpretation of registry results. For example, the results of comparative safety and effectiveness evaluations may differ depending on the comparison group used. Generally, it is preferable to make judgments about the “best” comparison group for study during the design phase and then concentrate resources on these selected subjects. Alternatively, sensitivity analyses can be used to test inferences against alternative reference groups to determine the robustness of the findings. (See Chapter 13.)

The choice of comparison groups is more complex in registries than in clinical trials. Whereas clinical trials use randomization to try to achieve an equal (or nearly equal) distribution of known and unknown risk factors that can confound the drug-outcome association, registry studies need to use various design and analytic strategies to control for the confounders that they have measured. The concern for observational studies is that people who receive a new drug or device have different risk factors for adverse events than those who choose other treatments or receive no treatment at all. In other words, the treatment choices are often related to demographic and lifestyle characteristics and the presence of coexisting conditions that affect clinician decisionmaking about whom to treat.16

Design strategies that are used frequently to ensure comparability of groups relate to individual matching of exposed patients and comparators with regard to key demographic factors, such as age and gender. Matching is also achieved by inclusion criteria that could, for example, restrict the registry focus to patients who have had the disease for a similar duration or are receiving their first drug treatment for a new condition. These inclusion criteria make the patient groups more similar but add constraints to the external validity by defining the target population more narrowly. Other design techniques include matching study subjects on the basis of a large number of risk factors, by using statistical techniques (e.g., propensity scoring) to create strata of patients with similar risks. As an example, consider a recent study of a rare side effect in coronary artery surgery for patients with acute coronary syndrome. In this instance, the main exposure of interest was the use of antifibrinolytic agents during revascularization surgery, a practice that had become standard for such surgeries. The sickest patients, who were most likely to have adverse events, were much less likely to be treated with antifibrinolytic agents. To address this, the investigators measured more than 200 covariates (by drug and outcome) per patient and used this information in a propensity analysis. The results of this large-scale observational study revealed that the traditionally accepted practice (aprotinin) was associated with serious end-organ damage and that the less expensive generic medications were safe alternatives.17 Incorporation of propensity-scores in analysis is discussed further in Chapter 13.

Case-control studies present special challenges with regard to control selection. More information on considerations and strategies can be found in a set of papers by Wacholder.18,19,20

An internal comparison group refers to simultaneous data collection for patients who are similar to the focus of interest (i.e., those with a particular disease or exposure in common), but who do not have the condition or exposure of interest. For example, a registry might collect information on patients with arthritis who are using acetaminophen for pain control. An internal comparison group could be arthritis patients who are using other medications for pain control. Data regarding similar patients, collected during the same calendar period and using the same data collection methods, are useful for subgroup comparisons, such as for studying the effects in certain age categories or among people with similar comorbidities. However, the information value and utility of these comparisons depend largely on having adequate sample sizes within subgroups, and such analyses may need to be specified a priori to ensure that recruitment supports them. Internal comparisons are particularly useful because data are collected during the same observation period as for all study subjects, which will account for time-related influences that may be external to the study. For example, if an important scientific article is published that affects general clinical practice, and the publication occurs during the period in which the study is being conducted, clinical practice may change. The effects may be comparable for groups observed during the same period through the same system, whereas information from historical controls, for example, would be expected to reflect different practices.

An external comparison group is a group of patients similar to those who are the focus of interest, but who do not have the condition or exposure of interest, and for whom relevant data that have been collected outside of the registry are available. For example, the SEER program maintains national data about cancer and has provided useful comparison information for many registries where cancer is an outcome of interest.21 External comparison groups can provide informative benchmarks for understanding effects observed, as well as for assessing generalizability. Additionally, large clinical and administrative claims databases can contribute useful information on comparable subjects for a relatively low cost. A drawback of external comparison groups is that the data are generally not collected the same way and the same information may not be available. The underlying populations may be different. In addition, plans to merge data from other databases require the proper privacy safeguards to comply with legal requirements for patient data; Chapter 8 covers patient privacy rules in detail.

A historical comparison group refers to patients who are similar to the focus of interest, but who do not have the condition or exposure of interest, and for whom information was collected in the past (such as before the introduction of an exposure or treatment or development of a condition). Historical controls may actually be the same patients who later become exposed, or they may consist of a completely different group of patients. For example, historical comparators are often used for pregnancy studies since there is a large body of population-based surveillance data available, such as the Metropolitan Atlanta Congenital Defects Program (MACDP).22 This design provides weak evidence because symmetry is not assured (i.e., the patients in different time periods may not be as similar as desired). Historical controls are susceptible to bias by changes over time in uncontrollable, confounding risk factors, such as differences in climate, management practices, and nutrition. Bias stemming from differences in measuring procedures over time may also account for observed differences.

An approach related to the use of historical controls is the use of Objective Performance Criteria (OPC) as a comparator. This research method has been described as an alternative to randomized trials, particularly for the study of devices.23 OPC are “performance criteria based on broad sets of data from historical databases (e.g., literature or registries) that are generally recognized as acceptable values. These criteria may be used for surrogate or clinical endpoints in demonstrating the safety or effectiveness of a device.”24 A U.S. Food and Drug Administration guidance document on medical devices includes a description of study designs that should be considered as alternatives to randomized clinical trials, and that may meet the statutory criteria for preapproval as well as postapproval evidence.25 Registries serve as a source of reliable historical data in this context. New registries with safety or effectiveness endpoints may also be planned that will incorporate previously existing OPC as comparators (e.g., for a safety endpoint for a new cardiac device). Such registries might use prior clinical study data to set the “complication-free rate” for comparison.

There are several situations in which conventional prospective design for control selection is impossible and historical controls may be considered:

- When one cannot ethically continue the use of older treatments or practices, or when clinicians and/or patients refuse to continue their use, so that the researcher cannot identify relevant sites using the older treatments.
- When uptake of a new medical practice has been rapid, concurrent controls may differ so markedly, in regard to factors related to outcomes of interest, that their selection is not feasible or valid.
- When conventional treatment has been consistently unsuccessful and the effect of new intervention is obvious and dramatic (e.g., first use of a new product for a previously untreatable condition).
- When collecting the control data is too expensive.
- When the Hawthorne effect (a phenomenon that refers to changes in the behavior of subjects because they know they are being studied or observed) makes it impossible to replicate actual practice in a comparison group during the same period.
- When the desired comparison is to usual care or “expected” outcomes at a population level, and data collection is too expensive due to the distribution or size of that population.

## Sampling

Various sampling strategies for patients and sites can be considered. Each of these has tradeoffs in terms of validity and information yield. The representativeness of the sample, with regard to the range of characteristics that are reflective of the broader target population, is often a consideration, but representativeness mainly affects generalizability rather than the internal validity of the results. Representativeness should be considered in terms of patients (e.g., men and women, children, the elderly, different racial or ethnic groups) and sites (academic medical centers, community practices). For sites (health care providers, hospitals, etc.), representativeness is often considered in terms of geography, practice size, and academic or private practice type. Reviewing and refining the research question can help researchers define an appropriate target population and a realistic strategy for subject selection.

To ensure that enough meaningful information will be available for analysis, registry studies often restrict eligibility for entry to individuals within a certain range of characteristics. Alternatively, they may use some form of sampling: random selection, systematic sampling, or a nonrandom approach. Often-used sampling strategies include the following:

- Probability sampling: Some form of random selection is used, wherein each person in the population must have a known (often equal) probability of being selected.26,27,28,29 Despite their best intentions, humans cannot choose a sample in a random fashion without a formal randomizing mechanism. Examples are:
  – Census: A census sample includes every individual in a population or group (e.g., all known cases). A census is not feasible when the group is large relative to the costs of obtaining information from individuals.
  – Simple random sampling: The sample is selected in such a way that each person has the same probability of being sampled.
  – Stratified sampling: The group from which the sample is to be taken is first stratified into subgroups on the basis of an important, related characteristic (e.g., age, parity, weight) so that each individual in a subgroup has the same probability of being included in the sample, but the probabilities for different subgroups or strata are different. Stratified random sampling ensures that the different categories of characteristics that are the basis of the strata are sufficiently represented in the sample. However, the resulting data must be analyzed using more complicated statistical procedures (such as Mantel-Haenszel) in which the stratification is taken into account.
  – Systematic sampling: Every nth person in a population is sampled.
  – Cluster (area) sampling: The population is divided into clusters, these clusters are randomly sampled, and then some or all patients within selected clusters are sampled. This technique is particularly useful in large geographic areas or when cluster-level interventions are being studied.
  – Multistage sampling: Multistage sampling can include any combination of the sampling techniques described above.
- Nonprobability sampling: Selection is systematic or haphazard but not random. The following sampling strategies affect the type of inferences that can be drawn; for example, it would be preferable to have a random sample if the goal were to estimate the prevalence of a condition in a population. However, systematic sampling of “typical” patients can generate useful data for many purposes, and is often used in situations where probability sampling is not feasible.30
  – Case series or consecutive (quota) sampling: All consecutive eligible patients treated at a given practice or by a given clinician are enrolled until the enrollment target is reached. This approach is intended to reduce conscious or unconscious selection bias on the part of clinicians as to whom to enroll in the study, especially with regard to factors that may be related to prognosis.
  – Haphazard, convenience, volunteer, or judgmental sampling: This includes any sampling not involving a truly random mechanism. A hallmark of this form of sampling is that the probability that a given individual will be in the sample is unknown before sampling. The theoretical basis for statistical inference is lost, and the result is inevitably biased in unknown ways.
  – Modal instance: The most typical subject is sampled.
  – Purposive: Several predefined groups are deliberately sampled.
  – Expert: A panel of experts judges the representativeness of the sample or is the source that contributes subjects to a registry.

Individual matching of cases and controls is sometimes used as a sampling strategy for controls. Cases are matched with individual controls who have similar confounding factors, such as age, to reduce the effect of the confounding factors on the association being investigated in analytic studies.

Patients are recruited in a fashion that accomplishes individual matching. For example, if a 69-year-old “case” participates in the registry, a comparator near in age will be sought. Individual matching for prospective recruitment is challenging and not customarily used. More often, matching is used to create subgroups for supplemental data collection for case-control studies and cohort studies when subjects are limited and/or stratification is unlikely to provide enough subjects in each stratum for meaningful evaluation.

There are a number of other sampling strategies that have arisen from survey research (e.g., snowball, heterogeneity), but they are of less relevance to registries.

## Registry Size and Duration

Precision in measurement and estimation corresponds to the reduction of random error; it can be improved by increasing the size of the study and modifying the design of the study to increase the efficiency with which information is obtained from a given number of subjects.30

During the registry design stage, it is critical to explicitly state how large the registry will be, how long patients should be followed, and what the justifications are for these decisions. These decisions are based on the overall purpose of the registry. For example, in addressing specific questions of product safety or effectiveness, the desired level of precision to confirm or rule out the existence of an important effect should be specified, and ideally should be linked to policy or practice decisions that will be made based on the evidence. For registries with aims that are descriptive or hypothesis generating, study size may be arrived at through other considerations.

The duration of registry enrollment and followup should be determined both by required sample size (number of patients or person-years to achieve the desired power) and by time-related considerations. The induction period for some outcomes of interest must be considered, and sufficient followup time allowed for the exposure under study to have induced or promoted the outcome. Biological models of disease etiology and causation usually indicate the required time period of observation for an effect to become apparent. Calendar time may be a consideration in studies of changes in clinical practice or interventions that have a clear beginning and end. The need for evidence to inform policy may also determine a timeframe within which the evidence must be made available to decisionmakers.

A detailed discussion of the topic of sample size calculations for registries is provided in Appendix A. For present purposes it is sufficient to briefly describe some of the critical inputs to these calculations that must be provided by the registry developers:

- The expected timeframe of the registry and the time intervals at which analyses of registry data will be performed.
- Either the size of clinically important effects (e.g., minimum clinically important differences) or the desired precision associated with registry-based estimates.
- Whether or not the registry is intended to support regulatory decisionmaking. If the results from the registry will affect regulatory action—for example, the likelihood that a product may be pulled from the market—then the precision of the overall risk estimate is important, as is the necessity to predict and account for attrition.

In a classical calculation of sample size, the crucial inputs that must be provided by the investigators include either the size of clinically important effects or their required precision. For example, suppose that the primary goal of the registry is to compare surgical complication rates in general practice with those in randomized trials. The inputs to the power calculations would include the complication rates from the randomized trials (e.g., 4 percent) and the complication rate in general practice, which would reflect a meaningful departure from this rate (e.g., 6 percent). If, on the other hand, the goal of the registry is simply to track complication rates (and not to compare the registry with an external standard), then the investigators should specify the required width of the confidence interval associated with those rates. For example, in a large registry, the 95-percent confidence interval for a 5-percent complication rate might extend from 4.5 percent to 5.5 percent. If all of the points in this confidence interval lead to the same decision, then an interval of ±0.5 percent is considered sufficiently precise, and this is the input required for the estimation of sample size.

Specifying the above inputs to sample size calculations is a substantial matter and usually involves a combination of quantitative and qualitative reasoning. The issues involved in making this specification are essentially similar for registries and other study designs, though for registries designed to address multiple questions of interest, one or more primary objectives or endpoints must be selected that will drive the selection of a minimum sample size to meet those objectives.

Other considerations that should sometimes be taken into account when estimating sample sizes include:

- whether individual patients can be considered “independent”;
- whether multiple comparisons are being made and subjected to statistical testing; and
- whether levels of expected attrition or lack of adherence to therapy may require a larger number of patients to achieve the desired number of person-years of followup or exposure.

In some cases, patients under study who share some group characteristics, such as patients treated by the same clinician or practice, or at the same institution, may not be entirely independent from one another with regard to some outcomes of interest or when studying a practice-level intervention. To the extent they are not independent, a measure of interdependence, the intraclass correlation (ICC), and so-called “design effect” must be considered in generating the overall sample size calculation. A reference addressing sample size considerations for a study incorporating a cluster-randomized intervention is provided.31 A hierarchical or multilevel analysis may be required to account for one or more levels of “grouping” of individual patients, discussed further in Chapter 13. One approach to addressing multiple comparisons in the surgical complication rate example above is to use control chart methodology, a statistical approach used in process measurement to examine the observed variability and determine whether out-of-control conditions are occurring. Control chart methodology is also used in sample size estimation, largely for studies with repeated measurements, to adjust the sample size as needed and therefore maintain reasonably precise estimates of confidence limits around the point estimate. Accordingly, for registries that involve ongoing evaluation, sample size per time interval could be determined by the precision associated with the related confidence interval, and decision rules for identifying problems could then be based on control chart methodology.

Although most of the emphasis in estimating study size requirements is focused on patients, it is equally important to consider the number of sites needed to recruit and retain enough patients to achieve a reasonably informative number of person-years for analysis. The science of estimating the number of sites needed for study is less well developed than the calculations used to estimate study size in terms of patients and person-years.

In summary, the aims of a registry, the desired precision of information sought, and the hypotheses to be tested, if any, determine the process and inputs for arriving at a target sample size and specifying the duration of followup. Registries with mainly descriptive aims, or those that provide quality metrics for clinicians or medical centers, may not require the choice of a target sample size to be arrived at through power calculations. In either case, the costs of obtaining study data, in monetary terms and in terms of researcher, clinician, and patient time and effort, may set upper as well as lower limits on study size. Limits to study budgets and the number of sites and patients that could be recruited may be apparent at the outset of the study. However, an underpowered study involving substantial data collection that is ultimately unable to satisfactorily answer the research question(s) may prove to be a waste of finite monetary as well as human resources that could better be applied elsewhere.

## Internal and External Validity

The potential for bias refers to opportunities for systematic errors to influence the results. Internal validity is the extent to which study results are free from bias, and the reported association between exposure and outcome is not due to unmeasured or uncontrolled-for variables. Generalizability, also known as external validity, is a concept that refers to the utility of the inferences for the broader population that the study subjects are intended to represent. In considering potential biases and generalizability, we discuss the differences between RCTs and registries, since these are the two principal approaches to conducting clinically relevant prospective research.

The strong internal validity that earns RCTs high grades for evidence comes largely from the randomization of exposures that helps ensure that the groups receiving the different treatments are similar in all measured or unmeasured characteristics, and that, therefore, any differences in outcome (beyond those attributable to chance) can be reasonably attributed to differences in the efficacy or safety of the treatments. However, it is worth noting that RCTs are not without their own biases, as illustrated by the “intent-to-treat” analytic approach, in which people are considered to have used the assigned treatment, regardless of actual compliance. The intent-to-treat analyses can minimize a real difference, known as bias toward the null, by including the experience of people who adhered to the recommended study product along with those who did not.

Another principal difference between registries and RCTs is that RCTs are often focused on a relatively homogeneous pool of patients from which significant numbers of patients are purposefully excluded at the cost of external validity—that is, generalizability to the target population of disease sufferers. Registries, in contrast, usually focus on generalizability so that their population will be representative and relevant to decision makers.

### Generalizability

The strong external validity of registries is achieved by the fact that they include typical patients, which often include more heterogeneous populations than those participating in RCTs (e.g., wide variety of age, ethnicity, and comorbidities). Therefore, registry data can provide a good description of the course of disease and impact of interventions in actual practice and, for some purposes, may be more relevant for decisionmaking than the data derived from the artificial constructs of the clinical trial. In fact, even though registries have more opportunities to introduce bias (systematic error) because of their nonexperimental methodology, well-designed observational studies can approximate the effects of interventions as well as RCTs on the same topic32,33 and, in particular, in the evaluation of health care effectiveness.34

The choice of groups from which patients will be selected directly affects generalizability. No particular method will ensure that an approach to patient recruitment is adequate, but it is worthwhile to note that the way in which patients are recruited, classified, and followed can either enhance or diminish the external validity of a registry. Some examples of how these methods of patient recruitment and followup can lead to systematic error follow.

### Information Bias

If the registry’s principal goal is the estimation of risk, it is possible that adverse events or the number of patients experiencing them will be underreported if the reporter will be viewed negatively for reporting them. It is also possible for those collecting data to introduce bias by misreporting the outcome of an intervention if they have a vested interest in doing so. This type of bias is referred to as information bias (also called detection, observer, ascertainment, or assessment bias), and it addresses the extent to which the data that are collected are valid (represent what they are intended to represent) and accurate. This bias arises if the outcome assessment can be interfered with, intentionally or unintentionally. On the other hand, if the outcome is objective, such as whether or not a patient died or the results of a lab test, then the data are unlikely to be biased.

### Selection Bias

A registry may create the incentive to enroll only patients who either are at low risk of complications or who are known not to have suffered such complications, biasing the results of the registry toward lower event rates. Those registries whose participants derive some sort of benefit from reporting low complication rates, for example, surgeons participating in registries, are at particularly high risk for this type of bias. Another example of how patient selection methods can lead to bias is the use of patient volunteers, a practice which may lead to selective participation from subjects most likely to perceive a benefit, distorting results for studies of patient-reported outcomes.

Enrolling patients who share a common exposure history, such as having used a drug that has been publicly linked to a serious adverse effect, could distort effect estimates for cohort and case-control analyses. Registries can also selectively enroll people who are at higher risk of developing serious side effects, since having a high-risk profile can motivate a patient to participate in a registry.

The term selection bias refers to situations where the procedures used to select study subjects lead to an effect estimate among those participating in the study that is different from the estimate that is obtainable from the target population.35 Selection bias may be introduced if certain subgroups of patients are routinely included or excluded from the registry.

### Channeling Bias (Confounding by Indication)

Channeling bias, also called confounding by indication, is a form of selection bias where drugs with similar therapeutic indications are prescribed to groups of patients with prognostic differences.36 For example, physicians may prescribe new treatments more often to those patients who have failed on traditional first-line treatments.

One approach to designing studies to address channeling bias is to conduct a prospective review of cases, in which external reviewers are blinded as to the treatments that were employed and are asked to determine whether a particular type of therapy is indicated and to rate the overall prognosis for the patient.37 This method of blinded prospective review was developed to support research on ruptured cerebral aneurysms, a rare and serious situation. The results of the blinded review were used to create risk strata for analysis so that comparisons could be conducted only for candidates for whom both therapies under study were indicated, a procedure much like the application of additional inclusion and exclusion criteria in a clinical trial.

A computed “propensity score” (i.e., the predicted probability of use of one therapy over another based on medical history, health care utilization, and other characteristics measured prior to the initiation of therapy) is increasingly incorporated into study designs to address this type of confounding.38,39 Propensity scores may be used to create cohorts of initiators of two different treatments matched with respect to probability of use of one of the two therapies, for stratification or for inclusion as a covariate in a multivariate analysis. Studies incorporating propensity scores as part of their design may be planned prior to and implemented shortly following launch of a new drug as part of a risk management program, with matched comparators being selected over time, so that differences in prescribing patterns following drug launch may be taken into account.40

Instrumental variables, or factors strongly associated with treatment but related to outcome only through their association with treatment, may provide additional means of adjustment for confounding by indication.41 Types of instrumental variables include providers’ preferences for one therapy over another, which exploit variation in practice as a type of natural experiment, as well as variation or changes in insurance coverage or economic factors (e.g. cigarette taxes) that are associated with an exposure.42,43 Variables that serve as effective instruments of this nature are not always available. While use of clinician or study site may, in some specific cases, offer potential as an instrumental variable for analysis, the requirement that use of one therapy over another be very strongly associated with the instrument is often difficult to meet in real-world settings. In most cases, instrumental variable analysis provides an alternative for secondary analysis of study data. Instrumental variable analysis either may support the conclusions drawn on the basis of the initial analysis, or it may raise additional questions regarding the potential impact of confounding by indication.43

In some cases, however, differences in disease severity or prognosis between patients receiving one therapy rather than another may be so extreme and/or unmeasurable that confounding by indication is not remediable in an observational design.44 This represents special challenges for observational studies of comparative effectiveness, as the severity of underlying illness may be a strong determinant of both choice of treatment and treatment outcome.

### Bias From Study of Existing Rather Than New Product Users

If there is any potential for tolerance to affect the use of a product, such that only those who perceive benefit from it or are free from harm continue using it, the recruitment of existing users rather than new users may lead to the inclusion of only those who have tolerated or benefited from the intervention, and would not necessarily capture the full spectrum of experience and outcomes. Selecting only existing users may introduce any number of biases, including incidence/prevalence bias, survivorship bias, and followup bias. By enrolling new users (an inception or incidence cohort), a study ensures that the population will reflect all users of the product, that the longitudinal experience of all users will be captured, and that the ascertainment of their experience will be comparable.45

### Loss to Followup

Loss to followup or attrition of patients and sites threatens generalizability as well as internal validity if there is differential loss; for example, loss of participants with a particular exposure or disease, or with particular outcomes. Loss to followup and attrition are generally a serious concern only when they are nonrandom (that is, when there are systematic differences between those who leave or are lost and those who remain). The magnitude of loss to followup or attrition determines the potential impact of any bias. Given that the differences between patients who remain enrolled and those who are lost to followup are often unknown (unmeasurable), preventing loss to followup in long-term studies to the fullest extent possible will increase the credibility and validity of the results.46 Attrition should be considered with regard to both patients and study sites, as results may be biased or less generalizable if only some sites (e.g., teaching hospitals) remain in the study while others discontinue participation.

### Assessing the Magnitude of Bias

Remaining alert for any source of bias is important, and the value of a registry is enhanced by its ability to provide a formal assessment of the likely magnitude of all potential sources of bias. Any information that can be generated regarding nonrespondents, missing respondents, and the like, is helpful, even if it is just an estimation of their raw numbers. As with many types of survey research, an assessment of differential response rates and patient selection can sometimes be undertaken when key data elements are available for both registry enrollees and nonparticipants. Such analyses can easily be undertaken when the initial data source or population pool is that of a health care organization, employer, or practice that has access to data in addition to key selection criteria (e.g., demographic data or data on comorbidities). Another tool is the use of sequential screening logs, in which all subjects fitting the inclusion criteria are enumerated and a few key data elements are recorded for all those who are screened. This technique allows some quantitative analysis of nonparticipants and assessments of the effects, if any, on representativeness. Whenever possible, quantitative assessment of the likely impact of bias is desirable to determine the sensitivity of the findings to varying assumptions. A recent text on quantitative analysis of bias through validation studies, and on probabilistic approaches to data analysis, provides a guide for planning and implementing these methods.47

Qualitative assessments, although not as rigorous as quantitative approaches, may give users of the research a framework for drawing their own conclusions regarding the effects of bias on study results if the basis for the assessment is made explicit in reporting the results.

Accordingly, two items that can be reported to help the user assess the generalizability of research results based on registry data are a description of the criteria used to select the registry sites, and the characteristics of these sites, particularly those characteristics that might have an impact on the purpose of the registry. For example, if a registry designed for the purpose of assessing adherence to lipid screening guidelines requires that its sites have a sophisticated electronic medical record in order to collect data, it will probably report better adherence than usual practice because this same electronic medical record facilitates the generation of real-time reminders to engage in screening. In this case, a report of rates of adherence to other screening guidelines (for which there were no reminders), even if these are outside the direct scope of inquiry, would provide some insight into the degree of overestimation.

Finally, and most importantly, whether or not study subjects need to be evaluated on their representativeness depends on the purpose and kind of inference needed. For example, for understanding biological effects, it is not necessary to sample in proportion to the underlying distribution in the population. It is more important to demonstrate to the stakeholders the degree to which patients who are included in a registry are representative of the population from which they were derived.

## Summary

In summary, the key points to consider in designing a registry include study design, data sources, patient selection, comparison groups, sampling strategies, and considerations of possible sources of bias and ways to address them to the extent that is practical and achievable.

## References for Chapter 3

1 Strom BL. Pharmacoepidemiology. 3rd ed. Chichester, England. John Wiley. 2000.
2 Chow SC, Chang M, Pong A. Statistical consideration of adaptive methods in clinical development. J Biopharm Stat. 2005;15(4):575-91. [pmid: 16022164].
3 Travis LB, Rabkin CS, Brown LM, et al. Cancer survivorship—genetic susceptibility and second primary cancers: research strategies and recommendations. J Natl Cancer Inst. Jan. 4. 2006;98(1):15-25. [pmid: 16391368].
4 Sackett DL, Haynes RB, Tugwell P. Clinical epidemiology. Boston. Little, Brown and Company. 1985:228.
5 Hennekens CH, Buring JE. Epidemiology in medicine. 1st ed. Boston. Little, Brown and Company. 1987.
6 Schoebel FC, Gradaus F, Ivens K, et al. Restenosis after elective coronary balloon angioplasty in patients with end stage renal disease: a case-control study using quantitative coronary angiography. Heart. 1997;78:337-42. [pmid: 9404246].
7 Rothman K, Greenland S. Modern Epidemiology. 3rd Edition. Philadelphia. Lippincott Williams & Wilkins. 1998:175-9.
8 Oral contraceptive use and the risk of endometrial cancer. The Centers for Disease Control Cancer and Steroid Hormone Study. JAMA. Mar. 25. 1983;249(12):1600-4. [pmid: 6338265].
9 Oral contraceptive use and the risk of ovarian cancer. The Centers for Disease Control Cancer and Steroid Hormone Study. JAMA. Mar. 25. 1983;249(12):1596-9. [pmid: 6338264].
10 Long-term oral contraceptive use and the risk of breast cancer. The Centers for Disease Control Cancer and Steroid Hormone Study. JAMA. Mar. 25. 1983;249(12):1591-5. [pmid: 6338262].
11 Speck CE, Kukull WA, Brenner DE, et al. History of depression as a risk factor for Alzheimer’s disease. Epidemiology. Jul. 1995;6(4):366-9. [pmid: 7548342].
12 Rothman K, Greenland S. Modern epidemiology. Philadelphia. Lippincott Williams & Wilkins. 1998:108.
13 Vigneswaran R, Aitchison SJ, McDonald HM, et al. Cerebral palsy and placental infection: a case-cohort study. BMC Pregnancy Childbirth. 2004;4:1. [pmid: 15005809].
14 Ong AT, Daemen J, van Hout BA, et al. Cost-effectiveness of the unrestricted use of sirolimus-eluting stents vs. bare metal stents at 1 and 2-year follow-up: results from the RESEARCH Registry. Eur Heart J. 2006;27:2996-3003. [pmid: 17114234].
15 Hulley SB, Cumming SR. Designing clinical research. Baltimore. Williams & Wilkins. 1988.
16 Hunter D. First, gather the data. N Engl J Med. 2006;354:329-31. [pmid: 16436764].
17 Mangano DT, Tudor IC, Dietzel C. The risk association with aprotinin in cardiac surgery. Multicenter study of Perioperative Ischemia Research Group and the Ischemia Research and Education Foundation. N Engl J Med. 2006;354:353-65. [pmid: 16436767].
18 Wacholder S, McLaughlin JK, Silverman DT, et al. Selection of controls in case-control studies. I. Principles. Am J Epidemiol. 1992;135:1019-28. [pmid: 1595688].
19 Wacholder S, Silverman DT, McLaughlin JK, et al. Selection of controls in case-control studies. II. Types of controls. Am J Epidemiol. 1992;135:1029-41. [pmid: 1595689].
20 Wacholder S, Silverman DT, McLaughlin JK, et al. Selection of controls in case-control studies. III. Design options. Am J Epidemiol. 1992;135:1042-50. [pmid: 1595690].
21 National Cancer Institute. Surveillance Epidemiology and End Results. Available at: http://seer.cancer.gov. Accessed January 17, 2007.
22 Metropolitan Atlanta Congenital Defects Program (MACDP). National Center on Birth Defects and Developmental Disabilities. Centers for Disease Control and Prevention. Accessed May 15, 2010. http://www.cdc.gov/ncbddd/bd/macdp_research.htm.
23 Chen E, Sapirstein W, Ahn C, et al. FDA perspective on clinical trial design for cardiovascular devices. Annals of Thoracic Surgery. 2006;82(3):773-75. [pmid: 16928481].
24 U.S. Food and Drug Administration, Center for Devices and Radiological Health. The Least Burdensome Provisions of the FDA Modernization Act of 1997; Concept and Principles: Final Guidance for FDA and Industry. Document issued October 4, 2002. Accessed June 28, 2009. from http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm085994.htm#h3.
25 Study designs employing nonconcurrent controls, such as historical controls (e.g., literature, patient records), objective performance criteria (OPC), and patients as their own control. U.S. Food and Drug Administration, Center for Devices and Radiological Health. The Least Burdensome Provisions of the FDA Modernization Act of 1997 (op.cit.). Accessed June 28, 2009.
26 Cochran WG. Sampling Techniques. Third ed. Wiley. 1977.
27 Lohr SL. Sampling: Design and Analysis. Boston. Duxbury. 1999.
28 Sudman S. Applied Sampling. New York. Academic Press. 1976.
29 Henry GT. Practical Sampling. Newbury Park, CA. Sage. 1990.
30 Rothman K, Greenland S. Modern epidemiology. Philadelphia. Lippincott Williams & Wilkins. 1998:116.
31 Raudenbush SW. Statistical analysis and optimal design for cluster randomized trials. Psychological Methods. 1997;2(2):173-85.
32 Concato J, Shah N, Horowitz R. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342:1887-92. [pmid: 10861325].
33 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342:1878-86. [pmid: 10861324].
34 Black N. Why we need observational studies to evaluate the effectiveness of health care. BMJ. May. 11. 1996;212(7040):1215-8. [pmid: 8634569].
35 Rothman K. Modern epidemiology. Boston. Little Brown and Company. 1986:83.
36 Petri H, Urquhart J. Channeling bias in the interpretation of drug effects. Stat Med. Apr. 1991;10(4):577-81. [pmid: 2057656].
37 Johnston SC. Identifying confounding by indication through blinded prospective review. Am J Epidemiol. 2001;154:276-84. [pmid: 11479193].
38 Sturmer T, Joshi M, Glynn RJ, et al. A review of the application of propensity score methods yielded increasing use, advantages in specific settings, but not substantially different estimates compared with conventional multivariable methods. J Clin Epidemiol. 2006;59(5):437-47. [pmid: 16632131].
39 Glynn RJ, Schneeweiss S, Sturmer T. Indications for propensity scores and review of their use in pharmacoepidemiology. Basic Clin Pharmacol Toxicol. 2006;98(3):253-9. [pmid: 16611199].
40 Loughlin J, Seeger JD, Eng PM, et al. Risk of hyperkalemia in women taking ethinylestradiol/drosperenone and other oral contraceptives. Contraception. 2008;78:377-83. [pmid: 18929734].
41 Instrumental Variables for Comparative Effectiveness Research: A Review of Applications. Slide Presentation from the AHRQ 2008 Annual Conference (Text Version). January. 2009. Agency for Healthcare Research and Quality. Rockville, MD. http://www.ahrq.gov/about/annualmtg08/090908slides/Brookhart.htm.
42 Evans WN, Ringel JS. Can higher cigarette taxes improve birth outcomes?. Journal of Public Economics. Elsevier. 1999;72(1):135-54.
43 Schneeweiss S, Seeger JD, Landon J, Walker AM. Aprotinin during coronary-artery bypass grafting and risk of death. N Engl J Med. 2008;358:771-83. [pmid: 18287600].
44 Bosco JL, Silliman RA, Thwin SS, et al. A most stubborn bias: no adjustment method fully resolves confounding by indication in observational studies. J Clin Epidemiol. 2009. [doi: 10.1016/j.jclinepi.2009.03.001].
45 Ray WA. Evaluating medication effects outside of clinical trials: new-user designs. Am J Epidemiol. Nov. 1. 2003;158(9):915-20. [pmid: 14585769].
46 Kristman V, Manno M, Cote P. Loss to follow-up in cohort studies: how much is too much?. Eur Journal Epidemiol. 2004;19(8):751-60.
47 Lash TL, Fox MP, Fink AK. Applying Quantitative Bias Analysis to Epidemiologic Data. Springer Publishing Company. 2009.