# Assessing Quality

## Introduction

Registries are undertaken for many purposes, ranging from descriptive studies intended to contribute to scientific understanding of patient outcomes to studies used to inform policy decisions. Some are undertaken with great urgency, whereas others proceed with more deliberation. Budgetary support ranges from spartan to adequate. Most importantly, registries often serve multiple purposes and change over time to accommodate these various purposes—in fact, these are hallmarks of registries. Although all registries can provide useful information, there are levels of rigor that enhance validity and make the information from some registries more useful for guiding decisions than others.

Prior to the publication of the first edition of this user’s guide, no standards had been developed by which to guide evaluation of registries, and the research into quality aspects of registries still remains sparse.1 Previous chapters of this user’s guide have described various attributes and characteristics that constitute good registries and good registry practice. This chapter provides an overview of key components of the design, execution, and analysis of a registry that promote reliability and validity of data on patient outcomes.

The aim of this chapter is to provide a simple and user-friendly system that allows registries to be described and evaluated in the context of the purpose for which they are conducted. Information is presented to help distinguish between:

- Basic good registry practices that are desirable to meet certain purposes.
- Future directions for practices that could enhance scientific rigor but may not be achievable because of practical constraints.

The items listed as “basic elements of good practice” are applicable to all patient registries. While it may not be practical or feasible to achieve all of the basic elements of good practice, it is useful to consider these characteristics in planning and evaluating registries. The information described in this user’s guide, and particularly in this chapter, is also designed to be used in reporting registry study results, much as CONSORT (Consolidated Standards of Reporting Trials) guidelines have been used to improve reporting of clinical trials2 and STROBE (Strengthening the Reporting of Observational Studies in Epidemiology) guidelines are being used for observational studies.3,4

It is also important to remind readers that some of the fundamental differences between clinical trials and registries will affect how quality is evaluated. For example, a clinical trial will have a schedule of visits and assessment that is rigorously maintained. A clinical trial patient who does not adhere to the schedule may be viewed as noncompliant with the protocol and could potentially be discontinued from the trial. In a registry, treatments and assessments may be recommended, but the registry participant who does not adhere to the schedule would typically be allowed to remain in the registry.

## Defining Quality

This chapter has adapted a definition of quality that was developed for randomized controlled trials;5 the term is used to refer to the confidence that the design, conduct, and analysis of the trial or registry can be shown to protect against bias (systematic error) and errors in inference—that is, erroneous conclusions drawn from a study.6 As used here, quality refers both to the data and to the conclusions drawn from analyses of these data. For more information about the types of biases that can affect observational studies, as well as strategies for addressing and even avoiding these biases to the extent feasible, see Chapters 3 and 13. For more information about bias, validity, and inference, readers are encouraged to consult epidemiologic textbooks.7,8,9,10

## Measuring Quality

There are two major difficulties with assessing quality in registries:

- It can often be difficult to differentiate between the quality of the design, the study conduct, and the information available.
- There is a lack of empirical evidence for evaluating parameters purported to indicate quality and impact on the evidence produced from registries.

In addition, registries vary widely in methodology, scope, and objectives, and therefore attributes that are important in one scenario may be less important in another. Furthermore, registries may be very useful vehicles for providing clinically relevant real-world information, even when they meet relatively few of the basic elements of good practice (typically because of budgetary limitations). In many cases, some data are better than no data, and even registries that fall short of including all the basic elements of good registry practice may still provide valuable insights about real-world medical and consumer practices and disease etiology, and may be particularly valuable for modeling exercises. Evaluations of the quality of any registry must therefore be done with respect to the specific purpose of the registry, must take into account both the internal and external validity of the data, and should be tempered by considerations of cost and feasibility.

The most commonly used method to assess quality of studies is a quality scale; there are numerous quality scales of varying length and complexity in existence, with strong views being expressed both for and against their use.7^(p. 135–61),^11,12 Different scales emphasize distinctive dimensions of quality and therefore can produce disparate results when applied to a given study. In most situations, a summary score is derived by adding individual item scores, with or without weighting. This method, however, ignores whether the various items may lead to a bias toward the null (suggesting the erroneous interpretation that there is no effect) or tend to exaggerate the appearance of an effect when none really exists, and the final score produced does not reflect individual components.13

Rather than develop a checklist, the approach suggested here is to undertake a quality component analysis, an investigation of the components that may affect the results obtained. In the quality component analysis, a differentiation is made between two domains: research quality, which pertains to the scientific process (in this instance, the design and operational aspects of the registry), and evidence quality, which relates to the data/findings emanating from the research process.14,15,16 According to Lohr,14,15,16,17 “The level of confidence one might have in evidence turns on the underlying robustness of the research and the analysis done to synthesize that research.”

To select the quality components for analysis, several key elements identified in previous research studies, among many consulted, were Guidelines for Good Pharmacoepidemiology Practice,18 the ICH (International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use) Guideline on Good Clinical Practice,19 the Council for International Organizations of Medical Sciences (CIOMS) International Guidelines for Ethical Review of Epidemiological Studies,20 various reports on rating scientific evidence from observational studies12,21 and surveillance systems,22 Goldberg’s review of registry evaluation methods,23 the MOOSE (Meta-analysis of Observational Studies in Epidemiology) proposal,24 the EULAR (European League Against Rheumatism) task force on biologic registers,22,25 and Guidance for Reporting Observational Studies maintained by the Equator Network.26

The results of the quality component analysis must be considered in conjunction with context-specific substantive components that relate to the disease area, the type of registry, and the purpose of the registry. (See Table 19.) For example, a disease-specific registry that has been designed to look at natural history should not be deemed low quality simply because it is not large enough to detect rare treatment effects.

Table 19 Overview of Registry Purposes

- Determining clinical effectiveness, cost effectiveness, or comparative effectiveness of a test or treatment, including evaluating the acceptability of drugs, devices, or procedures for reimbursement.; - Measuring or monitoring safety and harm of specific products and treatments, including comparative evaluation of safety and effectiveness.; - Measuring or improving quality of care, including conducting programs to measure and/or improve the practice of medicine and/or public health.; - Assessing natural history, including estimating the magnitude of a problem; determining the underlying incidence or prevalence rate; examining trends of disease over time; conducting surveillance; assessing service delivery and identifying groups at high risk; documenting the types of patients served by a health provider; and describing and estimating survival.

## Quality Domains

The quality domains shown here are the domains described earlier in this user’s guide. For research, the quality domains are research design and processes and procedures, which address planning, design, data elements and data sources, and ethics, privacy, and governance. For evidence, the quality domains are external validity, internal validity, and analysis and reporting.

Table 20 shows the basic elements of good registry practice for research, and Table 21 shows additional practices that have the potential to enhance scientific rigor, and thus the validity and reliability of information resulting from registries, subject, of course, to feasibility and applicability. Similarly, Table 22 shows the basic elements of good registry practice for evidence, and Table 23 shows additional practices that may enhance the evidence quality. It is important to weigh efforts taken to promote the accuracy and completeness of evidence in balance with the public health urgency of a problem, the types of interventions that are available, and the risks to public health from coming to a wrong conclusion. These lists of components are most likely incomplete, but the level of detail provided should be useful for high-level quality distinctions.

Table 20 Research Quality—Basic Elements of Good Practice for Establishing and Operating Registries

Research design; - Develop objectives (main and supporting, as needed).; - Identify the target population, eligibility, and inclusion and exclusion criteria. For registries where practice characteristics may influence outcome, seek to include diverse clinical practices. Where possible, a broad range of patients (few exclusion criteria) is desirable.; - Identify important personal identifiers, exposures, risk factors, and mitigating (or protective) factors, and seek those that are reasonably feasible to collect. Use the literature to inform the choice of data elements.; - Choose outcomes that are clinically meaningful and relevant to patients and to the medical community for decisionmaking. Define patient outcomes clearly, especially for complex conditions or outcomes that may not have uniformly established criteria (e.g., define “injection site reaction” in operational terms).; - Consider the most efficient and reliable means to collect data of sufficient quality to meet the registry’s purpose and whether existing data can be used to supplement or minimize active data collection.; - Use validated scales and tests when such tools exist for the purpose needed.; - Understand the followup time required to detect events of interest and whether or not the objective is feasible to achieve. Ensure that the followup time planned is adequate to address the main objective. Consider the size required to detect an effect should one exist, or to achieve a desired level of precision. Consider whether or not the sample size requirement can be achieved within the available time and budget constraints.; - Plan to report safety events according to regulatory requirements.; - Plan the data analysis, including what comparative information, if any, will be used to support study hypotheses or objectives.
Processes and procedures; - At the outset, reach agreement on key aspects of the registry and document them, including the goals, design, target population, methods for data collection, data elements and sources, high-level data management and data quality review, and how human subjects will be protected. It may be helpful for stakeholders to have input to assure clinical relevance and feasibility.; - Establish a process for documenting any modifications to the plan, since the main objective may change over time as knowledge accumulates, and the plan for data collection and followup may need to be adapted.; - Carefully consider the issues of protection of human subjects—including privacy, informed consent, data security, and study ethics—and address them in accordance with local, national, and international regulations. Obtain review and approval by any required oversight committees (e.g., ethics committee, privacy committee, or institutional review board, as applicable). Consider the additional issues of protection of human subjects if registry data are planned to be linked with other data sources.; - Define the role of any external sponsor, including data access, use, and presentation.; - Provide clear, operational definitions of outcomes and other data elements. Establish a data and coding dictionary to provide explicit definitions and to describe coding used. Whenever possible, use standardized data dictionaries, such as the International Classification of Diseases, and use coding that is consistent with nationally or internationally approved coding systems to promote comparability of information among studies.; - If linkage of registry data to other sources is planned, consider any additional requirements that may influence successful linkage, such as selection of data elements and definitions used.; - Plan for subject and physician recruitment methods and goals, and for monitoring enrollment and retention.; - Plan to expend reasonable efforts to ensure that appropriate patients are enrolled systematically and followed in as unbiased a manner as possible.; - Identify appropriate personnel and facilities, including those for secure data storage. Identify the individual(s) responsible for the integrity of the data, computerized and hard copy, and make sure these individuals have the training and experience to perform the assigned tasks.; - Develop standard instructions for use in training data collectors. For safety studies, create a process for identifying and reporting serious events that is consistent with regulatory requirements. Plan training for study personnel about how to identify serious events, including:; - - Asking about complaints or adverse events in a manner that is clear and specific (e.g., solicited vs. unsolicited).; - - Knowing if and how information should be reported to manufacturers and health authorities.; - Create a quality assurance plan that addresses data editing and verification. Plan an approach for handling missing data.; - Anticipate how study results will be communicated on completion. Specify publication policies in advance of collecting data and reevaluate at regular intervals (e.g., annually).; - Develop a plan for stopping or transitioning the registry, including any archiving or transferring of data and notifying participants, as appropriate.

Table 21 Research Quality—Potential Enhancements to Good Practice for Establishing and Operating Registries

Research design; - Formalize the study plan as a research protocol.; - Consider using concurrent comparators, since they may offer an advantage over historical or external comparison groups, especially in situations where treatments are evolving rapidly. The comparator cohort should be as similar as possible to the exposed cohort, aside from the exposure under study.; - Use formal statistical calculations to specify the number of patients or patient-years of observation needed to measure an effect with a certain level of precision or to meet a specified statistical power to detect an effect should one exist, although the desired size may not be achievable within the practical study constraints. Temper considerations about precision and power with budgetary and feasibility constraints, while also giving heed to the importance of conducting research in areas where little exists.; - Consider collecting enough information to permit linkage with external databases such as the National Death Index, electronic health records, or claims datasets, as appropriate. The desire for long-term followup should be balanced by considerations relating to collecting or re-identifying individually identifiable data, especially with regard to institutional review policies and privacy laws.
Processes and procedures; - A feasibility study or pilot test may be useful in certain situations, such as when studying hard-to-reach populations, when sensitive data are sought, and when critical registry methods are new or have not otherwise been tested.; - When capturing composite scores, collect and record core components, if possible.; - Collect information on start and stop dates of treatments of interest, and dose (if relevant) or other means to discriminate between high and low exposure.; - Data collection methods should not limit site participation to the extent that the representativeness of sites is compromised. Although single methods of data collection are most efficient, multiple methods of data collection may be desirable for some purposes.; - When health information systems are used for active data collection, use open standard approaches to interoperability, since they permit more efficient collection of data from multiple systems.; - Use similar methods of followup for exposure and comparison cohorts, and for all subjects in each cohort, to the extent feasible.; - Rigor can be enhanced by review or monitoring of a sample of data and/or data review by an adjudication committee for complex conditions or endpoints for which established procedures and/or coding are not used. Use a risk-based strategy for quality assurance (QA) focused on detecting and quantifying the most likely causes of error and the types of error most likely to affect the registry purpose. For example, a registry might compare a random sample of patient data (e.g., 5–20 percent of patients and specific data variables) with patient charts, with a sample of registry sites based on “for-cause” reasons, or a combination of these approaches. Adapt levels of QA activities based on observed performance (e.g., increase QA for sites that appear to be having difficulty in study conduct or data entry).; - Maintain appropriate documentation, such as an audit trail, to ensure proper handling of information and to support transparency. Establish processes and standards for creating analytic data files and maintaining such files to support publications and presentations, since registry analyses may be performed on live data (data that may change as the registry continues to collect and verify information through various quality control procedures) or on data that have been locked and have undergone formal review and editing.; - To enhance transparency, consider using an advisory board, particularly a board that includes members who are external to the clinician, center, or company that sponsors the research. An advisory board or steering committee can promote clinical and public health relevance, and may assist with governance and communication.; - Publishing results in the peer-reviewed literature and presenting results at scientific meetings are desirable means of introducing information into the public domain. The quality of publications and presentations is enhanced by review by knowledgeable parties in advance of submission for publication or presentation.; - Consider giving third parties access to data, either during active data collection or after the registry data collection has ended and results have been reported, and the process for any such data access.

Table 22 Evidence Quality—Indicators of Good Evidence Quality for Registries

External validity; - Registry participants were similar to the target population and, to the extent feasible, efforts were devoted to minimizing selection bias (e.g., rules for sequential enrollment were developed and codified in a manner that worked for all sites).; - Completeness of information on eligible patients was evaluated and described. The external validity was described (e.g., registry subjects were shown to be typical of the target population).
Internal validity; - For safety studies, a clear and specific approach was used (e.g., solicited vs. unsolicited) to ask about complaints or adverse events.; - Necessary information was collected for relevant key exposures, risk factors, and mitigating or protective factors.; - Exposure data used to support the main research questions were as specific as possible. For example, a specific product, including manufacturer, was identified to the extent feasible.; - Followup period was reasonably sufficient to capture the main outcomes of interest.; - A sample of data was compared with patient records.; - Reasonable efforts were devoted to minimizing losses to followup, and to ensuring that followup was reasonably complete for the registry purpose.; - Data checks were employed using range and consistency checks.
Analysis and reporting; - The report describes the methods, including target population and selection of study subjects, compliance with applicable regulatory rules and regulations, data collection methods, any transformation of variables and/or construction of composite endpoints, how missing data were handled, statistical methods for data analysis, and any circumstances that may have affected the quality or integrity of the data. The information was reported with enough detail to allow replication of the methods in another study.; - Results were reported for all the main objectives, including estimates of effect for each.; - Accepted analytic techniques were used; these may have been augmented by new or novel approaches.; - Followup time was described to enable assessment of the impact of the observation period on the conclusions drawn.; - The role and impact of missing data and potential confounding factors were considered; - The report includes a clear statement of any conclusions drawn from the analysis of the registry’s primary and secondary objectives and any implications of study results. Alternative explanations for the observed results were considered: a variety of factors, including the strength of the association, biases, and temporal relations, were considered before drawing any causal inferences. The practice of making inferences about causation largely on the outcome of tests of statistical significance is discouraged.; - Only authors who had a meaningful role in the design, conduct, analysis, or interpretation of results were included.

Table 23 Evidence Quality—Indicators of Enhanced Good Evidence Quality for Registries

External validity; - Eligibility (inclusion and exclusion criteria) was confirmed on enrollment.; - Selection bias was evaluated by describing the representativeness of the actual population in terms of how it was selected, how well the characteristics of the actual population match those of the target population, and to whom the results apply.
Internal validity; - Results that can be confirmed by an unbiased observer—such as death, test results, and scores from validated measures for patient-reported results or clinical rating scales—were used to enhance accuracy and reliability.; - Potential sources of errors relating to accuracy and falsification were rigorously evaluated and quantified to the extent feasible (e.g., through database and site reviews).; - Reproducibility of coding was evaluated.
Analysis and reporting; - For safety studies, the risks and/or benefits of products, devices, or processes under study were quantitatively evaluated beyond simply evaluating statistical significance (e.g., rates, proportions, and/or relative risks, as well as confidence intervals, were reported).; - For studies of comparative effectiveness and safety, contemporaneous data were collected for a comparison group, to the extent ethical and feasible, when other reasonably accurate and relevant comparative data were not available.; - Validated analytic tools were used for the main analysis. For example, commercially available analytic packages were used. The data elements used in any models were described.; - Sensitivity analyses were used to examine and quantify the effect on the association between the a priori exposure of interest and the outcome(s) by, for example:; - - Varying the definitions of exposure and outcome.; - - Varying the definitions of potential confounders and outcomes.; - The consistency of results was compared and contrasted with other relevant research.

Most importantly, the basic elements of good practice, as well as the potential enhancements to good practice, depend, to a great extent, on the resources and budget available to support registry-based research.

## References for Chapter 14

1 Gliklich RE, Dreyer NA, editors. Registries for Evaluating Patient Outcomes: A User’s Guide. (Prepared by Outcome DEcIDE Center [Outcome Sciences, Inc. dba Outcome] under Contract No. HHSA29020050035I TO1.) AHRQ Publication No. 07-EHC001-1. Rockville, MD. Agency for Healthcare Research and Quality. April. 2007.
2 Moher D, Schulz KF, Altman D. for the CONSORT group. The CONSORT Statement: revised recommendations for improving the quality of reports of parallel group randomized trials. JAMA. 2001;285:1987-91. [pmid: 11308435].
3 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) Statement: guidelines for reporting observational studies. Ann Intern Med. 2007;147(8):573-7. [pmid: 17938396].
4 Vandenbroucke JP, von Elm E, Altman DG, et al. Strengthening the Reporting of Observational Studies in Epidemiology (STROBE): explanation and elaboration. PLoS Med. 2007;4(10):e297. [pmid: 17941715].
5 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
6 Rothman KJ, editor. Causal inference. Chestnut Hill, MA. Epidemiology Resources Inc. 1988.
7 Rothman KJ, Greenland S. Modern epidemiology. Philadelphia. Lippincott Williams & Wilkins. 1998.
8 Weiss NS. Clinical epidemiology. The study of the outcome of illness. Oxford University Press. 2006.
9 Fletcher RH, Fletcher SW, Fletcher EH. Clinical epidemiology: the essentials. Williams & Wilkins. 1996.
10 Lash T, Fox MP, Fink AK. Applying quantitative bias analysis to epidemiologic data. Springer. 2009.
11 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
12 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evidence Report/Technology Assessment No. 47. Rockville, MD. Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016. April. 2002.
13 Greenland S. A critical look at some popular meta analytic methods. Am J Epidemiol. 1994;140(3):290-6. [pmid: 8030632].
14 National Center for the Dissemination of Disability Research. Available at: http://www.ncddr.org. Accessed January 17, 2007.
15 Mosteller F, Boruch R, editors. Evidence matters: randomized trials in education research. Washington, DC. The Brookings Institute. 2002.
16 Shavelson RJ, Towne L, editors. Scientific research in education. Washington, DC. National Research Council, National Academy Press. 2002.
17 Lohr KN. Rating the strength of scientific evidence: relevance for quality improvement programs. Int J Qual Health Care. 2004;16(1):9-18. [pmid: 15020556].
18 Guidelines for Good Pharmacoepidemiology Practice. Pharmacoepidemiol Drug Safety. 2008;17:200-8.
19 European Medicines Agency. ICH Topic E 6 (R1) Guideline for Good Clinical Practice. Available at: http://www.emea.europa.eu/pdfs/human/ich/013595en.pdf. Accessed July 9, 2009.
20 Council for International Organizations of Medical Sciences. Available at: http://www.cioms.ch/frame_1991_texts_of_guidelines.htm. Accessed July 9, 2009.
21 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;26(10):1013-20. [pmid: 19230606].
22 Klaucke D, Buehler J, Thacker S, et al. Guidelines for evaluating surveillance systems. MMMR. 1988;37(S5):1-18.
23 Goldberg J, Gelfand HM, Levy PS. Registry evaluation methods: a review and case study. Epidemiol Rev. 1980;2:210-20. [pmid: 7000537].
24 Stroup DF, Berlin JA, Morton SC, et al. for the Meta-analysis of Observational Studies in Epidemiology (MOOSE) Group. Meta-analysis of observational studies in epidemiology. A proposal for reporting. JAMA. 2000;283:2008-12. [pmid: 10789670].
25 Dixon WG, Carmona L, Finckh A, et al. EULAR points to consider when establishing, analyzing and reporting safety data of biologics registers in rheumatology. Ann Rheum Dis. 2010. Jun. 4. [Epub].
26 Equator Network. Available at: http://www.equator-network.org/resource-centre/library-of-health-research-reporting/reportingguidelines/observational-studies/#obse. Accessed August 12, 2010.