# Data Collection and Quality Assurance

## Introduction

This chapter focuses on data collection procedures and quality assurance principles for patient registries. Data management—the integrated system for collecting, cleaning, storing, monitoring, reviewing, and reporting on registry data—determines the utility of the data for meeting the goals of the registry. Quality assurance, on the other hand, aims to assure that the data were, in fact, collected in accordance with these procedures and that the data stored in the registry database meet the requisite standards of quality, which are generally defined based on the intended purposes. In this chapter, the term registry coordinating activities is used to refer to the centralized procedures performed for a registry and the term registry coordinating center refers to the entity or entities performing these procedures and overseeing the registry activities at the site and patient levels.

Because the range of registry purposes can be broad, a similar range of data collection procedures may be acceptable, but only certain methodologies may be suitable for particular purposes. Furthermore, certain end users of the data may require that data collection or validation be performed in accordance with their own guidelines or standards. For example, a registry that collects data electronically and intends for those data to be used by the U.S. Food and Drug Administration (FDA) should meet the systems validation requirements of that end user of the data, such as Title 21 of the Code of Federal Regulations Part 11 (21 CFR Part 11). Such requirements may have a substantial effect on the registry procedures. Similarly, registries may be subject to specific processes depending on the type of data collected, the types of authorization obtained, and the applicable governmental regulations.

Requirements for data collection and quality assurance should be defined during the registry inception and creation phases. Certain requirements may have significant cost implications, and these should be assessed on a cost-to-benefit basis in the context of the intended purposes of the registry. This chapter describes a broad range of centralized and distributed data collection and quality assurance activities that are currently in use or expected to become more commonly used in patient registries.

## Data Collection

### Database Requirements and Case Report Forms

Chapter 1 defined key characteristics of patient registries for evaluating patient outcomes. They include specific and consistent data definitions for collecting data elements in a uniform manner for every patient. As in randomized controlled trials, the case report form (CRF) is the paradigm for the data structure of the registry. A CRF is a formatted listing of data elements that can be presented in paper or electronic formats. Those data elements and data entry options in a CRF are represented in the database schema of the registry by patient-level variables. Defining the registry CRFs and corresponding database schema are the first steps in data collection for a registry. Chapter 5 describes the selection of data elements for a registry.

Two related documents should also be considered part of the database specification: the data dictionary (including data definitions and parameters) and the data validation rules, also known as queries or edit checks. The data dictionary and definitions describe both the data elements and how those data elements are interpreted. The data dictionary contains a detailed description of each variable used by the registry, including the source of the variable, coding information if used, and normal ranges if relevant. For example, the term “current smoker” should be defined as to whether “smoker” refers to tobacco or other substances and whether “current” refers to active or within a recent time period. Several cardiovascular registries, such as the Get With The Guidelines^®^ Coronary Artery Disease program,1 define “current smoker” as someone who smoked tobacco within the last year.

Data validation rules refer to the logical checks on data entered into the database against predefined rules for either value ranges (e.g., systolic blood pressure less than 300 mmHg) or logical consistency with respect to other data fields for the same patient; these are described more fully under Cleaning Data, below. While neither registry database structures nor database requirements are standardized, the Clinical Data Interchange Standards Consortium2 is actively working on representative models of data interchange and portability using standardized concepts and formats. Chapter 5 further discusses these models, which are applicable to registries as well as clinical trials.

### Procedures, Personnel, and Data Sources

Data collection procedures need to be carefully considered in planning the operations of a registry. Successful registries depend on a sustainable workflow model that can be integrated into the day-to-day clinical practice of active physicians, nurses, pharmacists, and patients with minimal disruption. (See Chapter 9.) Programs can benefit tremendously from preliminary input from health care workers or study coordinators who are likely to be participants.

#### Pilot Testing

One method of gathering input from likely participants before the full launch of a registry is pilot testing. Whereas feasibility testing, which is discussed in Chapter 2, focuses on whether a registry should be implemented, pilot testing focuses on how it should be implemented. Piloting can range from testing a subset of the procedures, CRFs, or data capture systems, to a full launch of the registry in a limited subset of sites and patients.

The key to effective pilot testing is to conduct it at a point where the results of the pilot can still be used to modify the registry implementation. Through pilot testing, one can assess comprehension, acceptance, feasibility, and other factors that influence how readily the patient registry processes will fit into patient lifestyles and the normal practices of the health care provider. For example, some data sources may or may not be available for all patients. Chapter 5 discusses pilot testing in more detail.

#### Documentation of Procedures

The data collection procedures for each registry should be clearly defined and described in a detailed manual. The term manual here refers to the reference information in any appropriate form, including hard copy, electronic, or via interactive Web or software-based systems. Although the detail of this manual may vary from registry to registry depending on the intended purpose, the required information generally includes protocols, policies, and procedures; the data collection instrument; and a listing of all the data elements and their full definitions. If the registry has optional fields (i.e., fields that do not have to be completed on every patient), these should be clearly specified.

In addition to patient inclusion and exclusion criteria, the screening process should be specified, as should any documentation to be retained at the site level and any plans for monitoring or auditing of screening practices. If sampling is to be performed, the method or systems used should be explained, and tools should be provided to simplify this process for the sites. The manual should clearly explain how patient identification numbers are created or assigned and how duplicate records should be prevented. Any required training for data collectors should also be described.

If paper CRFs are utilized, the manual should describe specifically how the paper CRFs are used and which parts of the forms (e.g., two-part or three-part no-carbon-required forms) should be retained, copied, submitted, or archived. If electronic CRFs are utilized, clear user manuals and instructions should be available. These procedures are an important resource for all personnel involved in the registry (and for external auditors who might be asked to assure the quality of the registry).

The importance of standardizing procedures to ensure that the registry uses uniform and systematic methods for collecting data cannot be overstated. At the same time, some level of customization of data entry methods may be required or permitted to enable the participation of particular sites or subgroups of patients within some practices. As discussed in Chapter 9, if the registry provides payments to sites for participation, then the specific requirements for site payments should be clearly documented, and this information should be provided with the registry documents.

#### Personnel

All personnel involved in data collection should be identified, and their job descriptions and respective roles in data collection and processing should be described. Examples of such “roles” include patient, physician, data entry personnel, site coordinator, help desk, data manager, and monitor. The necessary documentation or qualification required for any role should be specified in the registry documentation. As an example, some registries require personnel documentation such as a curriculum vitae, protocol signoff, attestation of intent to follow registry procedures, or confirmation of completion of specified training.

#### Data Sources

The sources of data for a registry may include new information collected from the patient, new or existing information reported by or derived from the clinician and the medical record, and ancillary stores of patient information, such as laboratories. Since registries for evaluating patient outcomes should employ uniform and systematic methods of data collection, all data-related procedures—including the permitted sources of data; the data elements and their definitions; and the validity, reliability, or other quality requirements for the data collected from each source—should be predetermined and defined for all collectors of data. As described under Quality Assurance, data quality is dependent on the entire chain of data collection and processing. Therefore, the validity and quality of the registry data as a whole ultimately derive from the least rigorous link, not the most.

In Chapter 6, data sources are classified as primary or secondary, based on the relationship of the data to the registry purpose and protocol. Primary data sources incorporate data collected for direct purposes of the registry (i.e., primarily for the registry). Secondary data sources consist of data originally collected for purposes other than the registry (e.g., standard medical care, insurance claims processing). The section below incorporates and expands on these definitions.

#### Patient-Reported Data

Patient-reported data are data specifically collected from the patient for the purposes of the registry rather than interpreted through a clinician or an indirect data source (e.g., laboratory value, pharmacy records). Such data may range from basic demographic information to validated scales of patient-reported outcomes (PROs). From an operational perspective, a wide range of issues should be considered in obtaining data directly from patients. These range from presentation (e.g., font size, language, reading level) to technologies (e.g., paper-and-pencil questionnaires, computer inputs, telephone or voice inputs, or hand-held patient diaries). Mistakes at this level can inadvertently bias patient selection, invalidate certain outcomes, or significantly affect cost. Limiting the access for patient reporting to particular languages or technologies may limit participation. Patients with specific diagnoses may have difficulties with specific technologies (e.g., small font size for visually impaired, paper and pencil for those with rheumatoid arthritis). Other choices, such as providing a patient-reported outcomes instrument in a format or method of delivery that differs from how it was validated (e.g., questionnaire rather than interview), may invalidate the results.

#### Clinician-Reported Data

Clinician-reported or -derived data can also be divided into primary and secondary. As an example, specific clinician rating scales (e.g., National Institutes of Health Stroke Scale)3 may be required for the registry but not routinely captured in clinical encounters. Some variables might be collected directly by the clinician for the registry or obtained from the medical record. Data elements that must be collected directly by the clinician (e.g., because of a particular definition or need to assess a specific comorbidity that may or may not be routinely present in the medical record) should be specified. These designations are important because they determine who can collect the data for a particular registry or what changes must be made in the procedures that the clinician follows in recording a medical record for a patient in a registry. Furthermore, the types of error that arise in registries (discussed under Quality Assurance) will differ by the degree of use of primary and secondary sources, as well as other factors. As an example, registries that utilize medical chart abstracters, as discussed below, may be subject to more interpretive errors.4

#### Data Abstraction

Data abstraction is the process by which a data collector other than the clinician interacting with the patient extracts clinician-reported data. While physical examination findings, such as height and weight, or laboratory findings, such as white blood cell counts, are straightforward, abstraction usually involves varying degrees of judgment and interpretation.

Clarity of description and standardization of definitions are essential to the assurance of data quality and to the prevention of interpretive errors when using data abstraction. Knowledgeable registry personnel should be designated as resources for the data collectors in the field, and processes should be put in place to allow the data collectors in the field continuous access to these designated registry personnel for questions on specific definitions and clinical situations. Registries that span long periods, such as those intended for surveillance, might be well served by a structure that allows for the review of definitions on a periodic basis to ensure the timeliness and completeness of data elements and definitions, and to add new data elements and definitions. A new product or procedure introduced after the start of a registry is a common reason for such an update.

Abstracting data from unformatted hard copy (e.g., a hospital chart) is often an arduous and tedious process, especially if free text is involved, and it usually requires a human reader. The reader, whose qualifications may range from a trained “medical record analyst” or other health professional to an untrained research assistant, may need to decipher illegible handwriting, translate obscure abbreviations and acronyms, and understand the clinical content to sufficiently extract the desired information. Registry personnel should develop formal chart abstraction guidelines, documentation, and coding forms for the analysts and reviewers to use.

Generally, the guidelines include instructions to search for particular types of data that will go into the registry (e.g., specific diagnoses or laboratory results). Often the analyst will be asked to code the data, using either standardized codes from a codebook (e.g., the ICD-9 [International Classification of Diseases, 9th Revision] code) corresponding to a text diagnosis in a chart, or codes that may be unique to the registry (e.g., a severity scale of 1 to 5).

All abstraction and coding instructions must be carefully documented and incorporated into a data dictionary for the registry. Because of the “noise” in unstructured, hard-copy documents (e.g., spurious marks or illegible writing) and the lack of precision in natural language, the clinical data abstracted by different abstracters from the same documents may differ. This is a potential source of error in a registry.

To reduce the potential for this source of error, registries should ensure proper training on the registry protocol and procedures, condition(s), data sources, data collection systems, and most importantly, data definitions and their interpretation. While training should be provided for all registry personnel, it is particularly important for nonclinician data abstracters. Training time depends on the nature of the source (charts or CRFs), complexity of the data, and number of data items. A variety of training methods, from live meetings to online meetings to interactive multimedia recordings, have all been used with success.5 Training often includes test abstractions using sample charts. For some purposes, it is best practice to train abstracters using standardized test charts. Such standardized tests can be further used both to obtain data on the inter-rater reliability of the CRFs, definitions, and coding instructions and to determine whether individual abstracters can perform up to a defined minimum standard for the registry. Registries that rely on medical chart abstraction should consider reporting on the performance characteristics associated with abstraction, such as inter-rater reliability.6 Some key considerations in standardizing medical chart abstractions are:

- Standardized materials (e.g., definitions, instructions).
- Standardized training.
- Testing with standardized charts.
- Reporting of inter-rater reliability.

#### Electronic Medical Record

An electronic medical record (EMR) is an electronic record of health-related information on an individual that can be created, gathered, managed, and consulted by authorized clinicians and staff within one health care organization. More complete than an EMR, an electronic health record (EHR) is an electronic record of health-related information on an individual that conforms to nationally recognized interoperability standards and that can be created, managed, and consulted by authorized clinicians and staff across more than one health care organization.7 For the purposes of this discussion, we will refer to the more limited capabilities of the EMR.

The EMR (and EHR) will play an increasingly important role as a source of clinical data for registries. The medical community is currently in a transition period in which the primary repository of a patient’s medical record is changing from the traditional hard-copy chart to the EMR. The main function of the EMR is to aggregate all clinical electronic data about a patient into one database, in the same way that a hard-copy medical chart aggregates paper records from various personnel and departments responsible for the care of the patient. Depending on the extent of implementation, the EMR may include patient demographics, diagnoses, procedures, progress notes, orders, flow sheets, medications, and allergies. The primary sources of data for the EMR are the health care providers. Data may be entered into the EMR through keyboards or touch-screens in medical offices or at the bedside. In addition, the EMR system is usually interfaced to ancillary systems (discussed below), such as laboratory, pharmacy, radiology, and pathology. Ancillary systems, which usually have their own databases, export relevant patient data to the EMR system, which imports the data into its database.

Since EMRs include the majority of clinical data available about a patient, they can be a major source of patient information for a registry. What an EMR usually does not include is registry-specific (primary source) data that are collected separately from hard-copy or electronic forms. In the next several years, suitable EMR system interfaces may be able to present data needed by registries in accordance with registry-specified requirements, either within the EMR (which then populates the registry) or in an electronic data capture system (which then populates the EMR). EMRs already serve as secondary data sources in some registries, and this practice will continue to grow as EMRs become more widely used. In these situations, data may be extracted from the EMR, transformed into registry format, and loaded into the registry, where they will reside in the registry database together with registry-specific data imported from other sources. In a sense, this is similar to medical chart abstraction except that it is performed electronically. There are two key differences. First, the data are “abstracted” once for all records. In this context, abstraction refers to the mapping and other decisionmaking needed to bring the EMR data into the registry database. It does not eliminate the potential for interpretive errors, as described later in this chapter, but it centralizes that process, making the rules clear and easily reviewed. Second, the data are uploaded electronically, eliminating duplicative data entry, potential errors associated with data reentry, and the related cost of this redundant effort.

When the EMR is used as a data source for a registry, a significant problem occurs when the information needed by the registry is stored in the EMR as free text, rather than codified or structured data. Examples of structured data include ICD-9 diagnoses and laboratory results. In contrast, physician progress notes, consultations, radiology reports, etc., are usually dictated and transcribed as narrative free text. While data abstraction of free text derived from an EMR can be done by a medical record analyst, with the increasing use of EMRs, automated methods of data abstraction from free text have been developed. Natural language processing (NLP) is the term given to this technology. It allows computers to process and extract information from human language. The goal of NLP is to parse free text into meaningful components based on a set of rules and a vocabulary that enable the software to recognize key words, understand grammatical constructions, and resolve word ambiguities. Those components can be extracted and delivered to the registry along with structured data extracted from the EMR, and both can be stored as structured data in the registry database.

An increasing number of NLP software packages are available (e.g., caTIES from the National Cancer Institute,8 i2b2 – Informatics for Integrating Biology at the Bedside,9 and a number of commercial products). However, NLP is still in an early phase of development and cannot yet be used for all-purpose chart abstraction. In general, NLP software operates in specific clinical domains (e.g., radiology, pathology), whose vocabularies have been included in the NLP software’s database. Nevertheless, NLP has been used successfully to extract diagnoses and drug names from free text in various clinical settings.

It is anticipated that EMR/EHR use will grow significantly with the incentives provided under the American Recovery and Reinvestment Act of 2009 (ARRA) health information technology provisions. Currently, only a minority of U.S. patients have their data stored in systems that are capable of retrieval at the level of a data element. Furthermore, only a small number of these systems currently store data in structured formats with standardized data definitions for those data elements that are common across different vendors. A significant amount of attention is currently focused on interchange formats between clinical and research systems (e.g., from Health Level Seven [HL-7]10 to Clinical Data Interchange Standards Consortium11 models). Attention is also focused on problems of data syntax and semantics. (See Chapter 5.) The adoption of common database structures and open interoperability standards will be critical for future interchange between EHRs and registries. This topic is discussed in depth in Chapter 11.

#### Other Data Sources

Some of the clinical data used to populate registries may be derived from repositories other than EMRs. Examples of other data sources include billing systems, laboratory databases, and other registries. Chapter 6 discusses the potential uses of other data sources in more detail.

### Data Entry Systems

Once the primary and any secondary data sources for a registry have been identified, the registry team can determine how data will be entered into the registry database. Many techniques and technologies exist for entering or moving data into the registry database, including paper CRFs, direct data entry, facsimile or scanning systems, interactive voice response systems (IVRS), and electronic CRFs. There are also different models for how quickly those data reach a central repository for cleaning, reviewing, monitoring, or reporting. Each approach has advantages and limitations, and each registry must balance flexibility (the number of options available) with data availability (when the central repository is populated), data validity (whether all methods are equally able to produce clean data), and cost. Appropriate decisions depend on many factors, including the number of data elements, number of sites, location (local preferences that vary by country, language differences, and availability of different technologies), registry duration, followup frequency, and available resources.

#### Paper CRFs

With paper CRFs, the clinician enters clinical data on the paper form at the time of the clinical encounters, or other data collectors abstract the data from medical records after the clinical encounter. CRFs may include a wide variety of clinical data on each patient gathered from different sources (e.g., medical chart, laboratory, pharmacy) and from multiple patient encounters. Before the data on formatted paper forms are entered into a computer, the forms should be reviewed for completeness, accuracy, and validity. Paper CRFs can be entered into the database by either direct data entry or computerized data entry via scanning systems.

With direct data entry, a computer keyboard is used to enter data into a database. Key entry has a variable error rate depending on personnel, so an assessment of error rate is usually desirable, particularly when a high volume of data entry is performed. Double data entry is a method of increasing the accuracy of manually entered data by quantifying error rates as discrepancies between two different data entry personnel; data accuracy is improved by having up to two individuals enter the data and a third person review and manage discrepancies. With upfront data validation checks on direct data entry, the likelihood of data entry errors significantly decreases. Therefore, the choice of single vs. double data entry should be driven by the requirements of the registry for a particular maximal error rate and the ability of each method to achieve that rate in key measures in the particular circumstance. Double data entry, while a standard of practice for registrational trials, may add significant cost. Its use should be guided by the need to reduce an error rate in key measures and the likelihood of accomplishing that by double data entry as opposed to other approaches. In some situations, assessing the data entry error rates by re-entering a sample of the data is sufficient for reporting purposes.

With hard-copy structured forms, entering data using a scanner and special software to extract the data from the scanned image is possible. If data are recorded on a form as marks in checkboxes, the scanning software enables the user to map the location of each checkbox to the value of a variable represented by the text item associated with the checkbox, and to determine whether the box is marked. The presence of a mark in a box is converted by the software to its corresponding value, which can then be transmitted to a database for storage. If the form contains hand-printed or typed text or numbers, optical character recognition (OCR) software is often effective in extracting the printed data from the scanned image. However, the print font must be of high quality to avoid translation errors, and spurious marks on the page can cause errors. Error checking is based on automated parameters specified by the operator of the system for exception handling. The comments on assessing error rates in the section above are applicable for scanning systems as well.

#### Electronic CRFs (eCRFs)

An eCRF is defined as an auditable electronic form designed to record information required by the clinical trial protocol to be reported to the sponsor on each trial subject.12 An eCRF allows clinician-reported data to be entered directly into the electronic system by the data collector (the clinician or other data collector). Site personnel in many registries still commonly complete an intermediate hard-copy worksheet representing the CRF and subsequently enter the data into the eCRF. While this approach increases work effort and error rates, it is not yet practical for all electronic data entry to be performed at the bedside, during the clinical encounter, or in the midst of a busy clinical day.

An eCRF may originate on local systems (including those on an individual computer, a local area network server, or a hand-held device) or directly from a central database server via an Internet-based connection or a private network. For registries that exist beyond a single site, the data from the local system must subsequently communicate with a central data system. An eCRF may be presented visually (e.g., computer screen) or aurally (e.g., telephonic data entry, such as interactive voice response systems). Specific circumstances will favor different presentations. For example, in one clozapine patient registry that is otherwise similar to Case Example 21, both pharmacists and physicians can obtain and enter data via a telephone-based interactive voice response system as well as a Web-based system. The option is successful in this scenario because telephone access is ubiquitous in pharmacies and the eCRF is very brief.

Case Example 30 Managing Care and Quality Improvement for Chronic Diseases

Description | The Tri State Child Health Services Web-based asthma registry is part of an asthma improvement collaborative aimed care at improving evidence-based and outcomes while strengthening improvement capacity of primary care practices.
Sponsor | Physician-Hospital Organization (PHO) affiliated with Cincinnati Children’s Hospital Medical Center
Year Started | 2003
Year Ended | Ongoing
No. of Sites | 39 community-based pediatric practices
No. of Patients | 12,365 children with asthma

###### Challenge

Asthma, a highly prevalent chronic disease managed in the primary care setting, has proven to be amenable to quality improvement initiatives. This collaborative effort between the PHO and Cincinnati Children’s Hospital Medical Center was initiated in 2003 with goals of improving evidence-based care, reducing adverse outcomes, such as asthma-related emergency room visits and missed schooldays, and strengthening the quality of knowledge and capacity within primary care practices. As the asthma initiative spans 39 primary care practices and encompasses approximately 35 percent of the region’s pediatric asthma population, the PHO needed to implement strategies for improving network-level, population-based process and outcome measures.

###### Proposed Solution

To address the project’s focus on improving process and outcome measures across a large network, the asthma collaborative decided to implement a centralized, Web-based asthma registry. Key measures of effective control and management of asthma (based on the National Heart, Lung, and Blood Institute’s guidelines) are captured via a self-reported clinical assessment form and decision support tool completed by parents and physicians at the point of care. The questions address missed schooldays and workdays, parent’s confidence in managing asthma, health resource utilization (e.g., emergency room visits), parent and physician rating of disease control, and other topics. In addition, the clinical assessment form facilitates interactive dialog between the physician and family during office visits.

The Web-based registry allows real-time reporting at the patient, practice, and network level. Reporting is transparent, with comparative practice data that support the identification of best practices and shared learning. In addition, reporting functionalities support tracking of longitudinal data and the identification of high-risk patients. The Web-based registry also provides access to real-time utilization reports with emergency room visit and admission dates. All reports are available to participating practices and physicians at any time.

###### Results

The registry provides essential data for identifying best practices and tracking improvement. The network has documented improvement against standard process and outcome measures.

###### Key Point

Registries can be useful tools for quality improvement initiatives in chronic disease areas. By collecting standardized data and sharing the data in patient-, practice-, and network-level reports, registries can track adherence to guidelines and evidence-based practices, and provide information to support ongoing quality improvement.

###### For More Information

Mandel KE, Kotagal UR. Pay for performance alone cannot drive quality. Arch Pediatr Adolesc Med. 2007;161(7):650-5. [pmid: 17606827].

A common method of electronic data entry is to use Web-based data entry forms. Such forms may be used by patients, providers, and interviewers to enter data into a local repository. The forms reside on servers, which may be located at the site of the registry or colocated anywhere on the Internet. To access a data entry form, a user on a remote computer with an Internet connection opens a browser window and enters the address of the Web server. Typically, a login screen is displayed and the user enters a user identification and password, provided by personnel responsible for the Web site or repository. Once the server authenticates the user, the data entry form is displayed, and the user can begin entering data. As described in Cleaning Data, many electronic systems can perform data validation checks or edits at the time of data entry. When data entry is complete, the user submits the form, which is sent over the Internet to the Web server.

Hand-held devices such as personal digital assistants (PDAs) and cell phones may also be used with Web-based or other forms to submit data to a server. Mobility has recently become an important attribute for clinical data collection. Software has been developed that enables wireless PDAs and cell phones to collect data and transmit them over the Internet to database servers in fixed locations. As wireless technology continues to evolve and data transmission rates increase, these will become more essential data entry devices for patients and clinicians.

### Advantages and Disadvantages of Data Collection Technologies

When the medical record or ancillary data are in electronic format, they may be abstracted to the CRF by a data collector or, in some cases, uploaded electronically to the registry database. The ease of extracting data from electronic systems for use in a registry depends on the design of the interfaces of ancillary and registry systems, and the ability of the EMR or ancillary system software to make the requested data accessible. However, as system vendors increasingly adopt open standards for interoperability, transferring data from one system to another will likely become easier. Many organizations are actively working toward improved standards, including HL7,^10^ the National eHealth Collaborative,13 the National Institute of Standards and Technology (NIST),14 and others. Chapter 11 describes standards and certifications specific to EHR systems.

Electronic interfaces are necessary to move data from one computer to another. If clinical data are entered into a local repository from an eCRF form or entered into an EMR, the data must be extracted from the source dataset in the local repository, transformed into the format required by the registry, and loaded into the registry database for permanent storage. This is called an “extract, transform, and load” (ETL) process. Unless the local repository is designed to be consistent with the registry database in terms of the names of variables and their values, data mapping and transformation can be a complex task. In some cases, manual transfer of the data may be more efficient and less time consuming than the effort to develop an electronic interface. Emerging open standards can enable data to be transferred from an EHR directly into the registry. This topic is discussed in more detail in Chapter 11.

If an interface between a local electronic system and registry system is developed, it is still necessary to communicate to the ancillary system the criteria for retrieval and transmission of a patient record. Typically, the ancillary data are maintained in a relational database, and the system needs to run an SQL (Structured Query Language) query against the database to retrieve the specified information. An SQL query may specify individual patients by an identifier (e.g., a medical record number) or by values or ranges of specific variables (e.g., all patients with hemoglobin A1c over 8 mg/dl). The results of the query are usually stored as a file (e.g., XML, CSV, CDISC ODM) that can be transformed and transferred to the registry system across the interface. A variety of interface protocols may be used to transfer the data.

Because data definitions and formats are not yet nationally standardized, transfer of data from an EMR or ancillary system to a registry database is prone to error. Careful evaluation of the transfer specifications for interpretive or mapping errors is a critical step that should be verified by the registry coordinating center. Furthermore, a series of test transfers and validation procedures should be performed and documented. Finally, error checking must be part of the transfer process because new formats or other errors not in the test databases may be introduced during actual practice, and these need to be identified and isolated from the registry itself. Even though each piece of data may be accurately transferred, the data may have different representations on the different systems (e.g., value discrepancies such as the meaning of “0” vs. “1,” fixed vs. floating point numbers, date format, integer length, and missing values). In summary, any system used to extract EMR records into registry databases should be validated and should include an interval sampling of transfers to ensure that uploading of this information is consistent over time.

The ancillary system must also notify the registry when an error correction occurs in a record already transferred to the registry. Registry software must be able to receive that notification, flag the erroneous value as invalid, and insert the new, corrected value into its database. Finally, it is important to recognize that the use of an electronic-to-electronic interchange requires not only testing but also validation of the integrity and quality of the data transferred. Few ancillary systems or EMR systems are currently validated to a defined standard. For registries that intend to report data to FDA or to other sponsors or data recipients with similar requirements, including electronic signatures, audit trails, and rigorous system validation, the ways in which the registry interacts with these other systems must be carefully considered.

### Cleaning Data

Data cleaning refers to the correction or amelioration of data problems, including missing values, incorrect or out-of-range values, or responses that are logically inconsistent with other responses in the database. While all registries strive for “clean data,” in reality, this is a relative term. How and to what level the data will be cleaned should be addressed upfront in a data management manual that identifies the data elements that are intended to be cleaned, describes the data validation rules or logical checks for out-of-range values, and explains how missing values and values that are logically inconsistent will be handled.

#### Data Management Manual

Data managers should develop formal data review guidelines for the reviewers and data entry personnel to use. The guidelines should include information on how to handle missing data; invalid entries (e.g., multiple selections in a single-choice field, alphabetic data in a numeric field); erroneous entries (e.g., patients of the wrong gender answering gender-based questions); and inconsistent data (e.g., an answer to one question contradicting the answer to another one). The guidelines should also include procedures to attempt to remediate these data problems. For example, with a data error on an interview form, it may be necessary to query the interviewer or the patient, or to refer to other data sources that may be able to resolve the problem. Documentation of any data review activity and remediation efforts, including dates, times, and results of the query, should be maintained.

#### Automated Data Cleaning

Ideally, automated data checks are preprogrammed into the database for presentation at the time of data entry. These data checks are particularly useful for cleaning data at the site level while the patient or medical record is readily accessible. Even relatively simple edit checks, such as range values for laboratories, can have a significant effect on improving the quality of data. Many systems allow for the implementation of more complex data edit checks, and these checks can substantially reduce the amount of subsequent manual data cleaning. A variation of this method is to use data cleaning rules to deactivate certain data fields so that erroneous entries cannot even be made. A combination of these approaches can also be used. For paper-based entry methods, automated data checks are not available at the time the paper CRF is being completed but can be incorporated when the data are later entered into the database.

#### Manual Data Cleaning

Data managers perform manual data checks or queries to review data for unexpected discrepancies. This is the standard approach to cleaning data that are not entered into the database at the site (e.g., for paper CRFs entered via data entry or scanning). By carefully reviewing the data using both data extracts analyzed by algorithms and hand review, data managers identify discrepancies and generate “queries” to send to the sites to resolve. Even eCRF-based data entry with data validation rules may not be fully adequate to ensure data cleaning for certain purposes. Anticipating all potential data discrepancies at the time that the data management manual and edit checks are developed is very difficult. Therefore, even with the use of automated data validation parameters, some manual cleaning is often still performed.

#### Query Reports

The registry coordinating center should generate, on a periodic basis, query reports that relate to the quality of the data received, based on the data management manual and, for some purposes, additional concurrent review by a data manager. The content of these reports will differ depending on what type of data cleaning is required for the registry purpose and how much automated data cleaning has already been performed. Query reports may include missing data, “out-of-range” data, or data that appear to be inconsistent (e.g., positive pregnancy test for a male patient). They may also identify abnormal trends in data, such as sudden increases or decreases in laboratory tests compared to patient historical averages or clinically established normal ranges. Qualified registry personnel should be responsible for reviewing the abnormal trends with designated site personnel. The most effective approach is for sites to provide one contact representative for purposes of queries or concerns by registry personnel. Depending on the availability of the records and resources at the site to review and respond to queries, resolving all queries can sometimes be a challenge. Creating systematic approaches to maximizing site responsiveness is recommended.

#### Data Tracking

For most registry purposes, tracking of data received (paper CRFs), data entered, data cleaned, and other parameters is an important component of active registry management. By comparing indicators, such as expected to observed rates of patient enrollment, CRF completion, and query rates, the registry coordinating center can identify problems and potentially take corrective action—either at individual sites or across the registry as a whole.

#### Coding Data

As further described in Chapter 5, the use of standardized coding dictionaries is an increasingly important tool in the ability to aggregate registry data with other databases. As the health information community adopts standards, registries should routinely apply them unless there are specific reasons not to use such standard codes. While such codes should be implemented in the data dictionaries during registry planning, including all codes in the interface is not always possible. Some free text may be entered as a result. When free text data are entered into a registry, recoding these data using standardized dictionaries (e.g., MedDRA, WHODRUG, SNOMED^®^) may be worthwhile. There is cost associated with recoding, and in general, it should be limited to data elements that will be used in analysis or that need to be combined or reconciled with other datasets, such as when a common safety database is maintained across multiple registries and studies.

#### Storing and Securing Data

When data on a form are entered into a computer for inclusion in a registry, the form itself, as well as a log of the data entered, should be maintained for the regulatory archival period. Data errors may be discovered long after the data have been stored in the registry. The error may have been made by the patient or interviewer on the original form or during the data entry process. Examination of the original form and the data entry log should reveal the source of the error. If the error is on the form, correcting it may require reinterviewing the patient. If the error occurred during data entry, the corrected data should be entered and the registry updated. By then, the erroneous registry data may have been used to generate reports or create cohorts for population studies. Therefore, instead of simply replacing erroneous data with corrected data, the registry system should have the ability to flag data as erroneous without deleting them and to insert the corrected data for subsequent use.

Once data are entered into the registry, the registry must be backed up on a regular basis. There are two basic types of backup, and both types should be considered for use as best practice by the registry coordinating center. The first type is real-time disk backup, which is done by the disk storage hardware used by the registry server. The second is a regular (e.g., daily) backup of the registry to removable media (e.g., tape, CD-ROM, DVD). In the first case, as data are stored on disk in the registry server, they are automatically replicated to two or more physical hard drives. In the simplest example, called “mirroring,” registry data are stored on a primary disk and an exact replica is stored on the mirrored disk. If either disk fails, data continue to be stored on the mirrored disk until the failed disk is replaced. This failure can be completely transparent to the user, who may continue entering and retrieving data from the registry database during the failure. More complex disk backup configurations exist, in which arrays of disks are used to provide protection from single disk failures.

The second type of periodic backup is needed for disaster recovery. Ideally, a daily backup copy of the registry database stored on removable media should be maintained off site. In case of failure of the registry server or disaster that closes the data center, the backup copy can be brought to a functioning server and the registry database restored, with the only potential loss of data being for the interval between the regularly scheduled backups. The lost data can usually be reloaded from local data repositories or re-entered from hard copy. Other advanced and widely available database solutions and disaster recovery techniques may support a “standby” database that can be located at a remote data center. In case of a failure at the primary data center, the standby database can be utilized, minimizing downtime and preventing data loss.

### Managing Change

As with all other registry processes, the extent of change management will depend on the types of data being collected, the source(s) of the data, and the overall timeframe of the registry. There are two major drivers behind the need for change during the conduct of a registry: internal-driven change to refine or improve the registry or the quality of data collected, and external-driven change that comes as a result of changes in the environment in which the registry is being conducted.

Internal-driven change is generally focused on changes to data elements or data validation parameters that arise from site feedback, queries, and query trends that may point to a question, definition, or CRF field that was poorly designed or missing. If this is the case, the registry can use the information coming back from sites or data managers to add, delete, or modify the database requirements, CRFs, definitions, or data management manual as required. At times, more substantive changes, such as the addition of new forms or changes to the registry workflow, may be desirable to examine new conditions or outcomes. External-driven change generally arises in multiyear registries as new information about the disease and/or product under study becomes available, or as new therapies or products are introduced into clinical practice. Change and turnover in registry personnel is another type of change, and one that can be highly disruptive if procedures are not standardized and documented.

A more extensive form of change may occur when a registry either significantly changes its CRFs or changes the underlying database. Longstanding registries address this issue from time to time as information regarding the condition or procedure evolves and data collection forms and definitions require updating. One approach to managing the change is to lock the prior database and begin anew. However, more often, there is a desire to make prior datasets available for review by the sites or inclusion in reports. This requires data migration.

Data migration involves moving data from one data source to another with a modified or different structure. The process involves extracting data from the previous data source and loading the data into the current version of the registry. If this process is performed manually, which can be done for small amounts of data, then the considerations will be similar to those listed for manual data entry or for data abstraction if there are more substantial differences between the two systems (e.g., if data elements are defined or collected differently in the two systems). For larger amounts of data, migration is normally performed electronically. A detailed mapping document should be created for the data migration, describing how each data element and value in the source system maps to an associated data element and value in the destination system. General assumptions, such as how to treat inconsistent data, need to be documented at the outset of the data migration project and maintained as new assumptions are introduced based on any issues that are discovered during the migration process. The data being moved to the destination system should be checked to make sure that they comply with the receiving system’s data dictionary and data validation parameters. Once the data are migrated, the accuracy of the migration should be confirmed through a quality control process.

Proper management of change is crucial to the maintenance of the registry. A consistent approach to change management, including decisionmaking, documentation, data mapping, and validation, is an important aspect of maintaining the quality of the registry and the validity of the data. While the specific change management processes might depend on the type and nature of the registry, change management in registries that are designed to evaluate patient outcomes requires, at the very least, the following structures and processes:

- Detailed manual of procedures: As described earlier, a detailed manual that is updated on a regular basis—containing all the registry policies, procedures, and protocols, as well as a complete data dictionary listing all the data elements and their definitions—is vital for the functioning of a registry. The manual is also a crucial component for managing and documenting change management in a registry.
- Governing body: As described in Chapter 2, registries require oversight and advisory bodies for a number of purposes. One of the most important is to manage change on a regular basis. Keeping the registry manual and data definitions up to date is one of the primary responsibilities of this governing body. Large prospective registries, such as the National Surgical Quality Improvement Program, have found it necessary to delegate the updating of data elements and definitions to a special definitions committee.
- Infrastructure for ongoing training: As mentioned above, change in personnel is a common issue for registries. Specific processes and an infrastructure for training should be available at all times to account for any unanticipated changes and turnover of registry personnel or providers who regularly enter data into the registry. (See Case Example 29.)
- Method to communicate change: Since registries frequently undergo change, there should be a standard approach and timeline for communicating to sites when changes will take place.

Case Example 29 Data Collection Challenges in Rare Disease Registries

Description | Fabry disease is a rare lysosomal storage disorder caused by deficiency of the enzyme α-galactosidase A. The Fabry Outcome Survey (FOS) was established in 2001 to increase understanding of the natural history of Fabry disease and assess patients’ response to enzyme replacement therapy with agalsidase alfa (Replagal^®^). Development and analysis of FOS data are driven by the participating physicians. An Executive Committee and International Board oversee the types of data collected and any changes required. In addition, a number of working groups (e.g., pediatric, renal, cardiac) are responsible for analyzing and improving data collection for their specialties.
Sponsor | Shire HGT
Year Started | 2001
Year Ended | Ongoing
No. of Sites | 140 centers in 21 countries
No. of Patients | 1,795 patients

##### Challenge

Rare disease registries such as the Fabry Outcome Survey face unique challenges in data collection and quality assurance. Because there are very few patients with the disease of interest, most participating physicians have only one to two patients in the registry. The registry is not part of their daily, or even weekly, practice, and many of the physicians have difficulty remembering what to collect for the registry and how to capture the data when they do see an eligible patient. The FOS registry is also a global project, and the standards of care for patients with a rare disease often differ among physicians and among countries. As a result, a laboratory value or other data element that is routinely captured at one site may not be readily available at another site, leading to missing data. Finally, FOS is a long-term registry, with no defined end date. As physicians learn more about the disease and new treatments become available, the registry must adapt and update its data collection tools. This creates a need for continual training with participating physicians.

Despite these challenges, it is essential that the registry collect high-quality data to fulfill its goal of increasing knowledge about Fabry disease. A recent major objective of the registry staff has been to improve collection and quality of the data, so as to provide a more robust dataset for analysis.

##### Proposed Solution

Beginning in 2006, three measures were implemented to improve the collection and quality of data: development of a core dataset to ensure evaluation of variables relevant to disease progression and the effect of treatment; increased concentration on centers that have enrolled 20 or more patients in FOS; and use of clinical projects associates to monitor data capture and quality.

The clinical projects associates are employees of the registry sponsor who generally have experience with clinical trial monitoring. For FOS, a clinical projects associate is typically assigned to a specific geographical area to serve as the contact person for the centers, examine centers’ data for inconsistencies, and help with training center staff. The registry staff developed guidelines for the clinical projects associates to use when examining the data for inconsistencies, with particular focus on core variables. The clinical projects associates visit the sites in person to examine the data and provide targeted training based on any inconsistencies that they may find. The data examination is not monitoring, as in a clinical trial, as there is no source validation. Instead, it is a review for logical inconsistencies and missing data.

##### Results

A random sample (25 percent) of all enrolled patients was taken before and after the introduction of the above measures to assess their effectiveness. This sample consisted of 197 out of 815 patients enrolled in 2005, and 404 out of 1,616 patients enrolled in 2008.

Increases in data capture were found for 9 of the 10 core variables, the only exception being patient weight, which remained unchanged at 90 percent for both time points. Data capture increased from 66 percent to 83 percent for signs and symptoms, from 89 percent to 91 percent for serum creatinine, from 48 percent to 55 percent for left ventricular mass, and from 84 percent to 87 percent for NYHA (New York Heart Association) score. The proportion of females enrolled increased from 48 percent to 54 percent, which is more representative of the true Fabry population.

During 2008, results from three important patient subgroups were also analyzed: patients who had received agalsidase alfa treatment for at least 5 years, females who had received agalsidase alfa for at least 3 years, and children who had received agalsidase alfa for at least 2 years. Data capture from the core variables increased in all three subgroups during 2008; for example, data capture increased by 20 percent for proteinuria and by 19 percent for left ventricular mass in the 153 females who were available for evaluation.

##### Key Point

Periodic review of a random sample of data can provide important information on the quality of data in a registry. Due to the unique challenges facing rare disease registries, additional efforts may be necessary to improve data collection and data quality. These efforts may include site visits, ongoing training programs, and regular audits of the data for completeness. Because these efforts may require significant resources, it is important to conduct assessments of the effectiveness of the efforts and to alter the strategies as needed.

##### For More Information

Mehta A, Beck M, Elliott P, et al. Enzyme replacement therapy with agalsidase alfa in patients with Fabry’s disease: an analysis of registry data. Lancet 2009;Dec 12;374(9706):1986-96.
Mehta A, Clarke JTR, Giugliani R, et al. Natural course of Fabry disease: changing pattern of causes of death in FOS - Fabry Outcome Survey. J Med Genet. 2009;46:548-52. [pmid: 19473999].
Feriozzi S, Schwarting A, Sunder-Plassmann G, et al. Agalsidase alfa slows the decline in renal function in patients with Fabry disease. Am J Nephrol. 2009;29:353-61. [pmid: 18974635].
Deegan PB, Baehner AF, Barba Romero M-Á, et al. Natural history of Fabry disease in females in the Fabry Outcome Survey. J Med Genet. 2006;43:347-52. [pmid: 16227523].

In addition to instituting these structures, registries should also plan for change from a budget perspective (Chapter 2) and from an analysis perspective (Chapter 13).

### Using Data for Care Delivery, Coordination, and Quality Improvement

#### Improving Care

As registries increasingly collect data in electronic format, the time between care delivery and data collection is being reduced. This shorter timeframe offers significant opportunities to utilize registry functionalities to improve care delivery at the patient and population levels. These functionalities (Table 15) include generating outputs that promote care delivery and coordination at the individual patient level (e.g., decision support, patient reports, reminders, notifications, lists for proactive care, educational content) and providing tools that assist with population management, quality improvement, and quality reporting (e.g., risk adjustment, population views, benchmarks, quality report transmissions). A number of registries are designed primarily for this purpose. (See Case Example 30.) Several large national registries15,16,17,18 have shown large changes in performance during the course of hospital or practice participation in the registry. For example, in one head-to-head study that used hospital data from Hospital Compare, an online database created by the Centers for Medicare & Medicaid Services, patients in hospitals enrolled in the American Heart Association’s Get With The Guidelines^®^ Coronary Artery Disease (CAD) registry, which includes evidence-based reminders and real-time performance measurement reports, fared significantly better in measures of guidelines compliance than those in hospitals not enrolled in the registry.19

Table 15 Registry Functionalities

Inputs: Obtaining data | - Identify/enroll representative patients (e.g., sampling); - Collect data from multiple sources and settings (providers, patients, labs, pharmacies) at key points; - Use uniform data elements and definitions (risk factors, treatments, and outcomes); - Check and correct data (validity, coding, etc.); - Link data from different sources at patient level (manage patient identifiers); - Maintain security and privacy (e.g., access control, audit trail)
Outputs: Care delivery and coordination | - Provide real-time feedback with decision support (evidence/guidelines); - Generate patient-level reports and reminders (longitudinal reports, care gaps, summary lists/plans, health status); - Send relevant notifications to providers and patients (care gaps, prevention support, self-management); - Share information with patients and other providers; - List patients/subgroups for proactive care; - Link to relevant patient education
Outputs: Population measurement and quality improvement | - Provide population-level reports; – Real-time/rapid cycle; – Risk adjusted; – Including standardized measures; – Including benchmarks; – Enabling different reports for different levels of users; - Enable ad hoc reports for exploration; - Provide tools to manage populations or subgroups; - Generate dashboards that facilitate action; - Facilitate third-party quality reporting (transmission)

#### Special Case: Performance-Linked Access System

A performance-linked access system (PLAS), also known as a restricted access or limited distribution system, is another application of a registry to serve more than an observational goal. Unlike a disease and exposure registry, a PLAS is part of a detailed risk-minimization action plan that sponsors develop as a commitment to enhance the risk-benefit balance of a product when approved for the market. The purpose of a PLAS is to mitigate a certain known drug-associated risk by ensuring that product access is linked to a specific performance measure. Examples include systems that monitor laboratory values, such as white blood cell counts during clozapine administration to prevent severe leukopenia, or routine pregnancy testing during thalidomide administration to prevent in utero exposure to this known teratogenic compound. Additional information on PLAS can be found in Guidance for Industry: Development and Use of Risk Minimization Action Plans.20 (See Case Example 31.)

Case Example 31 Developing a Performance-Linked Access System

Description | The Teva Clozapine Patient Registry is one of several national patient registries for patients taking clozapine. The registry is designed as a performance-linked access system (PLAS) mandated by the U.S. Food and Drug Administration (FDA) to comply with a Risk Evaluation Mitigation Strategy (REMS). The goal is to prevent clozapine rechallenge in patients at risk for developing clozapine- induced agranulocytosis by monitoring lab data for signs of leukopenia or granulocytopenia.
Sponsor | Teva Pharmaceuticals USA
Year Started | 1997
Year Ended | Ongoing
No. of Sites | 48,000 active physicians and pharmacies
No. of Patients | 49,000 active patients

###### Challenge

Clozapine is indicated for patients with severe schizophrenia who fail standard therapy, and for reducing the risk of recurrent suicidal behavior in schizophrenia or schizoaffective disorder. However, it has potentially serious side effects that require careful medical supervision. The primary goal of the registry is to prevent clozapine from being prescribed and dispensed to patients with a known history of clozapine-induced agranulocytosis and to detect leukopenic events (decrease in white blood cell counts).

Because of the potential serious side effects, FDA requires manufacturers of clozapine to maintain a patient monitoring system. Designed as a performance-linked access system, the registry needs to assure the eligibility of patients, pharmacies, and physicians; monitor white blood cell (WBC) and absolute neutrophil (ANC) reports for low counts; assure compliance with lab report submission timelines; and respond to inquiries and reports of adverse events.

###### Proposed Solution

The registry was developed to meet these goals. Patients must be enrolled prior to receiving clozapine, and they must be assigned to a dispensing pharmacy and treating physician. After the patient has initiated therapy, a current and acceptable WBC count and ANC value are required prior to dispensing clozapine. Once a patient is enrolled and eligibility is confirmed, a 1-, 2-, or 4-week supply of clozapine can be dispensed, depending on patient experience and the physician’s prescription

Health care professionals are required to submit laboratory reports to the registry based on the patients’ monitoring frequency. Patients are monitored weekly for the first 6 months. If there are no low counts, the patient can be monitored every 2 weeks for an additional 6 months. Afterward, the patient may qualify for monitoring every 4 weeks (depending on the physician’s prescription). The registry provides reminders if laboratory data are not submitted according to the schedule. If a low count is identified, registry staff inform the health care providers to make sure that they are aware of the event and appropriate action is taken.

###### Results

By linking access to clozapine to a strict schedule of laboratory data submissions, the sponsor can ensure that only eligible patients are taking the drug. The sponsor is also able to detect low counts, prevent inappropriate rechallenge (or re-exposure) in at-risk patients, and monitor the patient population for any adverse events. This system provides the sponsor with data on the frequency and severity of adverse events while ensuring that only the proper patient population receives the drug.

###### Key Point

A PLAS can ensure that only appropriate patients receive treatment. These systems can also help sponsors monitor the patient population to learn more about adverse events and the frequency of these events.

###### For More Information

Reid WH. Access to care: clozapine in the public sector. Hosp Community Psychiatry. 1990;40(8):870-3. [pmid: 2119334].
Honigfeld G. The Clozapine National Registry System: forty years of risk management. J Clin Psychiatry Monograph. 1996;14(2):29-32.
U.S. Food and Drug Administration. Summary Minutes of the Psychopharmacologic Drugs Advisory Committee Meeting. 2003. Available at: http://www.fda.gov/ohrms/dockets/ac/03/minutes/3959M1.htm. Accessed June 29, 2010.

## Quality Assurance

In determining the utility of a registry for decisionmaking, it is critical to understand the quality of the procedures used to obtain the data and the quality of the data stored in the database. As patient registries that meet sufficient quality criteria (discussed in Chapters 1 and 14) are increasingly being seen as important means to generate evidence regarding effectiveness, safety, and quality of care, the quality of data within the registry must be understood in order to evaluate its suitability for use in decisionmaking. Registry planners should consider how to assure quality to a level sufficient for the intended purposes (as described below) and should also consider how to develop appropriate quality assurance plans for their registries. Those conducting the registry should assess and report on those quality assurance activities.

Methods of quality assurance will vary depending on the intended purpose of the registry. A registry intended to serve as key evidence for decisionmaking21 (e.g., coverage determinations, product safety evaluations, or performance-based payment) will require higher levels of quality assurance than a registry describing the natural history of a disease. Quality assurance activities generally fall under three main categories: (1) quality assurance of data, (2) quality assurance of registry procedures, and (3) quality assurance of computerized systems. Since many registries are large, the level of quality assurance that can be obtained may be limited by budgetary constraints.

To balance the need for sufficient quality assurance with reasonable resource expenditure for a particular purpose, a risk-based approach to quality assurance is highly recommended. A risk-based approach focuses on the most important sources of error or procedural lapses from the perspective of the registry’s purpose. Such sources of error should be defined during inception and design phases. As described below, registries with different purposes may be at risk for different sources of error and focus on different practices and levels of assessment. Standardization of methods for particular purposes (e.g. national performance measurement) will likely become more common in the future if results are to be combined or compared between registries.

### Assurance of Data Quality

Structures, processes, policies, and procedures need to be put in place to ascertain the quality of the data in the registry and to ensure against several types of errors, including:

- Errors in interpretation or coding: An example of this type of error would be two abstracters looking for the same data element in a patient’s medical record but extracting different data from the same chart. Variations in coding of specific conditions or procedures also fall under the category of interpretive errors. Avoidance or detection of interpretive error includes adequate training on definitions, testing against standard charts, testing and reporting on inter-rater reliability, and re-abstraction.
- Errors in data entry, transfer, or transformation accuracy: These occur when data are entered into the registry inaccurately—for example, a laboratory value of 2.0 is entered as 20. Avoidance or detection of accuracy errors can be achieved through upfront data quality checks (such as ranges and data validation checks), reentering samples of data to assess for accuracy (with the percent of data to be sampled depending on the study purpose), and rigorous attention to data cleaning.
- Errors of intention: Examples of intentional distortion of data (often referred to as “gaming”) are inflated reporting of preoperative patient risk in registries that compare risk-adjusted outcomes of surgery, or selecting only cases with good outcomes to report (“cherry-picking”). Avoidance or detection of intentional error can be challenging. Some approaches include checking for consistency of data between sites, assessing screening log information against other sources (e.g., billing data), and performing onsite audits (including monitoring source records) either at random or “for cause.”

Steps for assuring data quality include:

- Training: Educate data collectors/abstracters in a structured manner.
- Data completeness: When possible, provide sites with immediate feedback on issues such as missing or out-of-range values and logical inconsistencies.
- Data consistency: Compare across sites and over time.
- Onsite audits for a sample of sites: Review screening logs and procedures and/or samples of data.
- For-cause audits: Use both predetermined and data-informed methods to identify potential sites at higher suspicion for inaccuracy or intentional errors, such as discrepancies between enrollment and screening logs, narrow data ranges, and overly high or low enrollment.

To further minimize or identify these errors and to ensure the overall quality of the data, the following should be considered.

#### A Designated Individual Accountable for Data Quality at Each Site

Sites submitting data to a registry should have at least one person who is accountable for the quality of these data, irrespective of whether the person is collecting the data as well. The site coordinator should be fully knowledgeable of all protocols, policies, procedures, and definitions in a registry. The site coordinator should ensure that all site personnel involved in the registry are knowledgeable and that all data transmitted to registry coordinating centers are valid and accurate.

#### Assessment of Training and Maintenance of Competency of Personnel

Thorough training and documentation of maintenance of competency, for both site and registry personnel, are imperative to the quality of the registry. A detailed and comprehensive operations manual, as described earlier, is crucial for the proper training of all personnel involved in the registry. Routine cognitive testing (surveys) of health care provider knowledge of patient registry requirements and appropriate product use should be performed to monitor maintenance of the knowledge base and compliance with patient registry requirements. Retraining programs should be initiated when survey results provide evidence of lack of knowledge maintenance. All registry training programs should provide means by which the knowledge of the data collectors about their registries and their competence in data collection can be assessed on a regular basis, particularly when changes in procedures or definitions are implemented.

#### Data Quality Audits

As described above, the level to which registry data will be cleaned is influenced by the objectives of the registry, the type of data being collected (e.g., clinical data vs. economic data), the sources of the data (e.g., primary vs. secondary), and the timeframe of the registry (e.g., 3-month followup vs. 10-year followup). These registry characteristics often affect the types and number of data queries that are generated, both electronically and manually. In addition to identifying missing values, incorrect or out-of-range values, or responses that are logically inconsistent with other responses in the database, specifically trained registry personnel can review the data queries to identify possible error trends and to determine whether additional site training is required. For example, such personnel may identify a specific patient outcome question or eCRF field that is generating a larger than average proportion of queries, either from one site or across all registry sites. Using this information, the registry personnel can conduct targeted followup with the sites to retrain them on the correct interpretation of the outcome question or eCRF field, with the goal of reducing the future query rate on that particular question or field. These types of “training tips” can also be addressed in a registry newsletter as a way to maintain frequent but unobtrusive communication with the registry sites.

If the registry purpose requires more stringent verification of the data being entered into the database by registry participants, registry planners may decide to conduct audits of the registry sites. Like queries discussed above, the audit plan for a specific registry will be influenced by the purpose of the registry, the type of data being collected, the source of the data, and the overall timeframe of the registry. In addition, registry developers must find the appropriate balance between the extensiveness of an audit and the impact on overall registry costs. Based on the objectives of the registry, a registry developer can define specific data fields (e.g., key effectiveness variables or adverse event data) on which the audit can be focused.

The term audit may describe examination or verification, may take place onsite (sometimes called monitoring) or offsite, and may be extensive or very limited. The audit can be conducted on a random sample of participating sites (e.g., 5–20 percent of registry sites); “for cause” (meaning only when there is an indication of a problem, such as one site being an outlier compared with most others); on a random sample of patients; or using sampling techniques based on geography, practice setting (academic center vs. community hospital), patient enrollment rate, or query rate (“risk-based” audit strategy).

The approach to auditing the quality of the data should reflect the most significant sources of error with respect to the purpose of the registry. For example, registries used for performance measurement may have a higher risk of exclusion of higher risk patients (“cherry-picking”), and the focus of an audit might be on external sources of data to verify screening log information (e.g., billing data) in addition to data accuracy. (See Case Example 32.) Finally, the timeframe of the registry may help determine the audit plan. A registry with a short followup period (e.g., 3 months) may require only one round of audits at the end of the study, prior to database lock and data analysis. For example, in the OPTIMIZE-HF registry (Case Example 26), a data quality audit was performed, based on predetermined criteria, on a 5-percent random sample of the first 10,000 patient records verified against source documents.22 For registries with multiyear followup, registry personnel may conduct site audits every 1 or 2 years for the duration of the registry.

Case Example 32 Using Audits To Monitor Data Quality

Description | The Vascular Study Group of Northern New England (VSGNNE) is a voluntary, cooperative group of clinicians, hospital administrators, and research personnel, organized to improve the care of patients with vascular disease. The purpose of the registry is to collect and exchange information to support continuous improvements in the quality, safety, effectiveness, and cost of caring for patients with vascular disease.
Sponsor | Funded by participating institutions. (Initial funding was provided by the Centers for Medicare & Medicaid Services [CMS]).
Year Started | 2002
Year Ended | Ongoing
No. of Sites | 11 hospitals in Massachusetts, Maine, New Hampshire, and Vermont
No. of Patients | Over 11,000 patients

###### Challenge

VSGNNE established a registry in 2002 as part of an effort to improve quality of care for patients undergoing carotid endarterectomy, carotid stenting, lower extremity arterial bypass, and open and endovascular repair of abdominal aortic aneurysms. The registry collects more than 80 patient, process, and outcome variables for each procedure at the time of hospitalization, and 1-year results are collected during a followup visit at the surgeon’s office. All patients receiving one of the procedures of interest at a participating hospital are eligible for enrollment in the registry.

In considering the areas of greatest risk in evaluating the quality of this registry, the registry developers determined that incomplete enrollment of eligible patients was one major potential area for bias. It was determined that an audit of included vs. eligible patients could reasonably address whether this was a significant issue. However, the group needed to overcome two logistical challenges: (1) the audit had to review thousands of eligible patients at participating hospitals in a timely, cost-effective manner; and (2) the audit could not overburden the hospitals, as they participate in the study voluntarily.

###### Proposed Solution

The registry team developed a plan to conduct the audit using electronic claims data files from the hospitals. Each hospital was asked to send claims data files for the appropriate time periods and procedures of interest to the registry. The registry team at Dartmouth-Hitchcock Medical Center then matched the claims data to the registry enrollment using ICD-9 (International Classification of Diseases, 9th Revision) codes with manual review of some patient files that did not match using a computer-matching process.

###### Results

The audit found that approximately 7 percent of eligible patients had not been enrolled in the registry. Because of concerns that the missing patients may have had different outcomes than the patients who had been enrolled in the registry, the registry team asked participating hospitals to complete registry forms for all missing patients. This effort increased the percentage of eligible patients enrolled in the registry to over 99 percent. The team also compared the discharge status of the missing patients and the enrolled patients, and found no significant differences in outcomes. The team concluded that the patients had been missed at random and that there were no systematic enrollment issues. Discussions with the hospitals identified the reasons for not enrolling patients as confusion about eligibility requirements, training issues, and questions about informed consent requirements.

The first audit was completed in 2003. Additional audits were completed in 2006 and 2008.

###### Key Point

For many registries, audits are an important tool for ensuring that the data are reliable and valid. However, registries that rely on voluntary site participation must be cautious to avoid overburdening sites during the audit process. A remote audit using readily available electronic files, such as claims files, provided a reasonable assessment of the percentage of eligible patients enrolled in the registry without requiring large amounts of time or resources from participating sites.

###### For More Information

Cronenwett JL, Likosky DS, Russell MT, et al. A regional registry for quality assurance and improvement: the Vascular Study Group of Northern New England (VSGNNE). J Vasc Surg. 2007;46:1093-1102. [pmid: 17950568].

In addition to the site characteristics mentioned above, sites that have undergone significant staffing changes during a multiyear registry should be considered prime audit targets to help confirm adequate training of new personnel and to quickly address possible inter-rater variability. To minimize any impact on the observational nature of the registry, the audit plan should be documented in the registry manual.

Registries that are designed for the evaluation of patient outcomes and the generation of scientific information, and that utilize medical chart abstracters, should assess inter-rater reliability in data collection with sufficient scientific rigor for their intended purpose(s). For example, in one registry that uses abstractions extensively, a detailed system of assessing inter-rater reliability has been devised and published; in addition to requiring that abstracters achieve a certain level of proficiency, a proportion of charts are scheduled for re-abstraction on the basis of predefined criteria. Statistical measures of reliability from such re-abstractions are maintained and reported (e.g., kappa statistic).23

Subsequent to audits (onsite or remote), communication of findings with site personnel should be conducted face to face, along with followup written communication of findings and opportunities for improvement. As appropriate to meet registry objectives, the sponsor may request corrective actions from the site. Site compliance may also be enhanced with routine communication of data generated from the patient registry system to the site for reconciliation.

### Registry Procedures and Systems

#### External Audits of Registry Procedures

If registry developers determine that external audits are necessary to assure the level of quality for the specific purpose(s) of the registry, they should be conducted in accordance with preestablished criteria. Preestablished criteria could include monitoring of sites with high patient enrollment or prior audit history with findings that require attention, or monitoring could be based on level of site experience, rate of serious adverse event reporting, or identified problems. The registry coordinating center may perform monitoring of a sample of sites, which could be focused on one or several areas. This approach could range from reviewing procedures and interviewing site personnel, to checking screening logs, to monitoring individual case records.

The importance of having a complete and detailed registry manual that describes policies, structures, and procedures cannot be overemphasized in the context of quality assurance of registry procedures. Such a manual serves both as a basis for conducting the audits and as a means of documenting changes emanating from these audits. As with data quality audits, feedback of the findings of registry procedure audits should be communicated to all stakeholders and documented in the registry manual.

#### Assurance of System Integrity and Security

All aspects of data management processes should fall under a rigorous life-cycle approach to system development and quality management. Each process is clearly defined and documented. The concepts described below are consistent across many software industry standards and health care industry standards (e.g., 21 CFR Part 11, legal security standards), although some specifics may vary. The processes and procedures described should be regularly audited by an internal quality assurance function at the registry coordinating center. When third parties other than the registry coordinating center perform activities that interact with the registry systems and data, they are typically assessed for risk and are subject to regular audits by the registry coordinating center.

#### System Development and Validation

All software systems used for patient registries should follow the standard principles of software development, including following one of the standard software development life cycle (SDLC) models that are well described in the software industry.

In parallel, quality assurance of system development utilizes approved specifications to create a validation plan for each project. Test cases are created by trained personnel and systematically executed, with results recorded and reviewed. Depending on regulatory requirements, a final validation report is often written and approved. Unresolved product and process issues are maintained and tracked in an issue tracking or CAPA (Corrective Action/Preventive Action) system.

Processes for development and validation should be similarly documented and periodically audited. The information from these audits is captured, summarized, and reviewed with the applicable group, with the aim of ongoing process improvement and quality improvement.

### Security

All registries maintain health information, and therefore security is an important issue. This section discusses security regulations that are applicable to U.S. registries; registries collecting data in other countries may need to comply with additional or different regulations. The HIPAA (Health Insurance Portability and Accountability Act of 1996) Security Rule lists the standards for security for electronic protected health information to be implemented by health plans, health care clearinghouses, and certain health care providers.24 Although these standards are specific to electronic protected health information, the principles themselves are more broadly applicable. Security is achieved not simply by technology but by clear processes and procedures. Overall responsibility for security is typically assigned. Security procedures are well documented and posted. The documentation is also used to train staff. Some registries may also maintain personal information, such as information needed to contact patients to remind them to gather or submit patient-reported outcome information. The Federal Government, as well as most U.S. States and territories, have enacted legislation regarding the safekeeping of personal information and requirements for reporting notification of certain security breaches involving personal information. Specific requirements vary by State.

#### System Security Plan

A system security plan consists of documented policies and standard operating procedures defining the rules of systems, including administrative procedures, physical safeguards, technical security services, technical security mechanisms, electronic signatures, and audit trails, as applicable. The rules delineate roles and responsibilities. Included in the rules are the policies specifying individual accountability for actions, access rights based on the principle of least privilege, and the need for separation of duties. These principles and the accompanying security practices provide the foundation for the confidentiality and integrity of registry data. The rules also detail the consequences associated with noncompliance.

#### Security Assessment

Clinical data maintained in a registry can be assessed for the appropriate level of security. Standard criteria exist for such assessments and are based on the type of data being collected. Part of the validation process is a security assessment of the systems and operating procedures. One of the goals of such an assessment is effective risk management, based on determining possible threats to the system or data and identifying potential vulnerabilities.

#### Education and Training

All staff members of the registry coordinating center should be provided with periodic training on aspects of the overall systems, security requirements, and any special requirements of specific patient registries. Individuals should receive training relating to their specific job responsibilities and document that appropriate training has been received.

#### Access Rights

Access to systems and data should be based on the principles of least privilege and separation of duties. No individual should be assigned access privileges that exceed job requirements, and no individual should be in a role that includes access rights that would allow circumvention of controls or the repudiation of actions within the system. In all cases, access should be limited to authorized individuals.

#### Access Controls

Access controls provide the basis for authentication and logical access to critical systems and data. Since the authenticity, integrity, and auditability of data stored in electronic systems depend on accurate individual authentication, management of electronic signatures (discussed below) is an important topic.

Logical access to systems and computerized data should be controlled in a way that permits only authorized individuals to gain access to the system. This is normally done through a unique access code, such as a unique user ID and password combination that is assigned to the individual whose identity has been verified and whose job responsibilities require such access. The system should require the user to change the password periodically and should detect possible unauthorized access attempts, such as multiple failed logins, and automatically deauthorize the user account if they occur. The identification code can also be an encrypted digital certificate stored on a password-protected device or a biometric identifier that is designed so that it can be used only by the designated individual.

Rules should be established for situations in which access credentials are compromised. New password information should be sent to the individual by a secure method.

Intrusion detection and firewalls should be employed on sites accessible to the Internet, with appropriate controls and rules in place to limit access to authorized users. Desktop systems should be equipped with antivirus software, and servers should run the most recent security patches. System security should be reviewed throughout the course of the registry to ensure that management, operational, personnel, and technical controls are functioning properly.

#### Data Enclaves

With the growth of clinical data and demands for increasing amounts of clinical data by multiple parties and researchers, new approaches to access are evolving. Data enclaves are secure, remote-access systems that allow researchers to share respondents’ information in a controlled and confidential manner.25 The data enclave utilizes statistical, technical, and operational controls at different levels chosen for the specific viewer. This can be useful both for enhancing protection of the data and for enabling certain organizations to access data in compliance with their own organization or agency requirements. Data enclaves also can be used to allow other researchers to access a registry’s data in a controlled manner. With the growth of registries and their utility for a number of stakeholders, data enclaves will become increasingly important.

#### Electronic Signatures

Electronic signatures provide one of the foundations of individual accountability, helping to ensure an accurate change history when used in conjunction with secure, computer-generated, time-stamped audit trails. Most systems utilize an electronic signature. For registries that report data to FDA, such signatures must meet criteria specified in 21 CFR Part 11 for general signature composition, use, and control (11.100, 11.200, and 11.300). However, even registries that do not have such requirements should view these as reasonable standards. Before an individual is assigned an electronic signature, it is important to verify the person’s identity and train the individual in the significance of the electronic signature. In cases where a signature consists of a user ID and a password, both management and technical means should be used to ensure uniqueness and compliance with password construction rules. Password length, character composition, uniqueness, and validity life cycle should be based on industry best practices and guidelines published by the NIST. Passwords that are used in electronic signatures should abide by the same security and aging constraints as those listed for system access controls.

#### Validation

Systems that store electronic records (or depend on electronic or handwritten signatures of those records) that are required to be acceptable to FDA must be validated according to the requirements set forth in the 21 CFR Part 11 Final Rule,26 dated March 20, 1997. The rule describes the requirements and controls for electronic systems that are used to fulfill records requirements set forth in agency regulations (often called “predicate rules”) and for any electronic records submitted to the agency. FDA publishes nonbinding guidance documents from time to time that outline its current thinking regarding the scope and application of the regulation. The current guidance document is Guidance for Industry, Part 11, Electronic Records; Electronic Signatures – Scope and Application,27 dated August 2003. Other documents that are useful for determining validation requirements of electronic systems are Guidance for Industry, Computerized Systems Used in Clinical Investigations,28 dated May 2007, and General Principles of Software Validation; Final Guidance for Industry and FDA Staff,29 dated January 11, 2002.

## Resource Considerations

Costs for registries can be highly variable, depending on the overall goals. Costs are also associated with the total number of sites, the total number of patients, and the geographical reach of the registry program. Each of the elements described in this chapter has an associated cost. Table 16 provides a list of some of the activities of the registry coordinating center as an example. Not all registries will require or can afford all of the functions, options, or quality assurance techniques described in this chapter. Registry planners must evaluate benefit vs. available resources to determine the most appropriate approach to achieve their goals.

Table 16 Data Activities Performed During Registry Coordination

Data management | - Defines all in-process data quality control steps, procedures, and metrics.; - Defines the types of edit checks that are run against the data.; - Defines required file-format specifications for electronic files, as well as schedules and processes for transfers of data.; - Defines quality acceptance criteria for electronic data, as well as procedures for handling exceptions.; - Develops guidelines for data entry.; - Identifies areas of manual review where electronic checks are not effective.; - Develops and maintains process for reviewing, coding, and reporting adverse event data.; - Develops and maintains archiving process.; - Develops and documents the process for change management.; - Develops and maintains process for query tracking and creates standard reports to efficiently identify outstanding queries, query types per site, etc.; - Relates queries to processes and activities (e.g., CRF design) requiring process improvements.; - Follows up on query responses and errors identified in data cleaning by performing accurate database updates.; - Defines registry-specific dictionaries and code lists.; - Performs database audits as applicable.; - Conducts user testing of systems and applications per written specifications.; - Establishes quality criteria and quality error rate acceptance limits.; - Evaluates data points that should be audited and identifies potential sources of data errors for audits.; - Identifies root cause of errors in order to recommend change in process/technology to assure the error does not occur again (continuous improvement).; - Ensures that sampling audit techniques are valid and support decisions made about data.; - Outlines all other data flow, including external data sources.
Documentation | - Documents the process, procedures, standards, and checklist(s) and provides training.; - Documents and maintains process and standards for identifying signals and trends in data.; - Documents database quality control actions performed.
Reporting | - Generates standard reports of missing data from the patient database.; - Creates tools to track and inventory CRFs, and reports anticipated vs. actual CRF receipts.

Note: CRF = case report form.

## References for Chapter 10

1 American Heart Association. Get With The Guidelines. Available at: http://www.americanheart.org/presenter.jhtml?identifier=1165. Accessed July 7, 2009.
2 Clinical Data Interchange Standards Consortium. Available at: www.cdisc.org. Accessed July 7, 2009.
3 National Institutes of Health National Institutes of Health Stroke Scale. Available at: http://www.ninds.nih.gov/doctors/NIH_Stroke_Scale.pdf. Accessed July 7, 2009.
4 Luck J, Peabody JW, Dresselhaus TR, et al. How well does chart abstraction measure quality? A prospective comparison of standardized patients with the medical record. Am J Med. Jun. 1. 2000;108(8):642-9. [pmid: 10856412].
5 Reisch LM, Fosse JS, Beverly K, et al. Training, quality assurance, and assessment of medical record abstraction in a multisite study. Am J Epidemiol. 2003;157:546-51. [pmid: 12631545].
6 Neale R, Rokkas P, McClure RJ. Inter-rater reliability of injury coding in the Queensland Trauma Registry. Emerg Med (Fremantle). Feb. 2003;15(1):38-41. [pmid: 12656785].
7 Halamka J. A Healthcare IT Primer. Available at: http://geekdoctor.blogspot.com/2009/03/healthcare-it-primer.html. Accessed July 7, 2009.
8 National Cancer Institute. Available at: https://cabig.nci.nih.gov/tools/caties. Accessed July 7, 2009.
9 Informatics for Integrating Biology and the Bedside. Available at: https://www.i2b2.org. Accessed July 7, 2009.
10 Health Level Seven. Available at: http://www.hl7.org. Accessed July 7, 2009.
11 Clinical Data Interchange Standards Consortium. Available at: http://www.cdisc.org. Accessed July 7, 2009.
12 U.S. Food and Drug Administration. Available at: www.fda.gov/oral/compliance_ref/bimo/ffinalcct.pdf. Accessed June 16, 2006.
13 National eHealth Collaborative. Available at: http://www.nationalehealth.org. Accessed July 7, 2009.
14 National Institute of Standards and Technology. Available at: http://www.nist.gov/. Accessed July 7, 2009.
15 American Heart Association. Get With The Guidelines. Available at: http://www.americanheart.org/presenter.jhtml?identifier=1165. Accessed August 4, 2009.
16 OPTIMIZE-HF. Organized Program to Initiate LifeSaving Treatment in Hospitalized Patients with Heart Failure. Available at: http://www.optimize-hf.org/. Accessed August 4, 2009.
17 Fonarow GC, Heywood JT, Heidenreich PA, et al. Temporal trends in clinical characteristics, treatments, and outcomes for heart failure hospitalizations, 2002 to 2004: findings from Acute Decompensated Heart Failure National Registry (ADHERE). Am Heart J. 2007;153(6):1021-8. [pmid: 17540205].
18 IMPROVE HF. Available at: https://www.improvehf.com/login.html. Accessed August 4, 2009.
19 Lewis WR, Peterson ED, Cannon CP, et al. An organized approach to improvement in guideline adherence for acute myocardial infarction: results with the Get With The Guidelines quality improvement program. Arch Intern Med. 2008;168(16):1813-9. [pmid: 18779470].
20 U.S. Food and Drug Administration. Guidance for Industry: Development and Use of Risk Minimization Action Plans. Available at: http://www.fda.gov/cder/Guidance/6358fnl.htm. Accessed August 19, 2006.
21 Mangano DT, Tudor IC, Dietzel C. The risk associated with aprotinin in cardiac surgery. N Engl J Med. Jan. 26. 2006;354(4):353-65. [pmid: 16436767].
22 Gheorghiade M, Abraham W, Albert N, et al. Systolic blood pressure at admission, clinical characteristics, and outcomes in patients hospitalized with acute heart failure. JAMA. Nov. 8. 2006;296(8):2217-26. [pmid: 17090768].
23 Fink AS, Campbell DA, Mentzer RM, et al. The National Surgical Quality Improvement Program in non-Veterans Administration hospitals: initial demonstration of feasibility. Ann Surg. Sept. 2002;236(3):344-54. [pmid: 12192321].
24 The HIPAA Security Rule: Health Insurance Reform: Security Standards, February 20, 2003. 68 FR 8334.
25 National Institutes of Health. Available at: http://grants.nih.gov/grants/policy/data_sharing/data_sharing_guidance.htm#enclave. Accessed July 7, 2009.
26 U.S. Food and Drug Administration. Available at: http://www.accessdata.fda.gov/SCRIPTs/cdrh/cfdocs/cfcfr/CFRSearch.cfm?CFRPart=11&showFR=1. Accessed July 3, 2009.
27 U.S. Food and Drug Administration. Available at: http://www.fda.gov/downloads/RegulatoryInformation/Guidances/ucm125125.pdf. Accessed July 3, 2009.
28 U.S. Food and Drug Administration. Available at: http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM070266.pdf. Accessed July 2, 2009.
29 U.S. Food and Drug Administration. Available at: http://www.fda.gov/downloads/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/UCM085371.pdf. Accessed July 2, 2009.