# Reviewers

[The findings and conclusions in this document are those of the contributors and reviewers. The contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. No statement in this document should be construed as an official position of any organization represented here.]

Chapter 1. Patient Registries
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Janet Hiller, M.P.H., Ph.D. Professor of Public Health Director, Adelaide Health Technology Assessment (AHTA) University of Adelaide Adelaide, Australia
Chapter 2. Planning a Registry
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Patrice Desvigne-Nickens, M.D. Medical Officer Heart Failure and Arrhythmia Branch Division of Cardiovascular Science National Heart, Lung, and Blood Institute Bethesda, MD
Paul Eggers, Ph.D. Program Director for Kidney and Urology Epidemiology National Institute of Diabetes and Digestive and Kidney Diseases Bethesda, MD
Gregg C. Fonarow, M.D. Professor of Medicine/Cardiology Director, Ahmanson-UCLA Cardiomyopathy Center Associate Chief, UCLA Division of Cardiology The Eliot Corday Chair in Cardiovascular Medicine and Science David Geffen School of Medicine at UCLA Los Angeles, CA
Catherine Koepper Associate Director, Global Registry Program Genzyme Corporation Cambridge, MA
Bruce C. Marshall, M.D. Vice President of Clinical Affairs Cystic Fibrosis Foundation Bethesda, MD
Hugh Tilson, M.D., Dr.P.H. Adjunct Professor of Epidemiology, Health Policy, and Public Health Leadership University of North Carolina School of Public Health Chapel Hill, NC Adjunct Professor of Medicine Duke University Durham, NC
John Yee, M.D., M.P.H. Vice President, US and Global Medical Affairs Genzyme Corporation Cambridge, MA
Section of Chapter 2:Planning for the End of a Registry
Susan Adams, J.D. Director, Committee for the Protection of Human Subjects Dartmouth College Hanover, NH
Nancy A. Dreyer, M.P.H., Ph.D. Chief of Scientific Affairs Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Leslye K. Fitterman, Ph.D. Centers for Medicare & Medicaid Services Baltimore, MD
Richard E. Gliklich, M.D. President Outcome Sciences, Inc. d/b/a Outcome Principal Investigator, Outcome DEcIDE Center Professor, Harvard Medical School Cambridge, MA
Rosemarie Hakim, Ph.D. Senior Epidemiologist Centers for Medicare & Medicaid Services Baltimore, MD
Steven E. Nissen, M.D. Chairman, Department of Cardiovascular Medicine Cleveland Clinic Cleveland, OH
Steve E. Phurrough, M.D., M.P.A. Medical Officer Agency for Healthcare Research and Quality Rockville, MD
Anne E. Trontell, M.D., M.P.H. Program Director, Centers for Education and Research on Therapeutics Center for Outcomes and Evidence Agency for Healthcare Research and Quality Rockville, MD
Chapter 3. Registry Design
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Paul Eggers, Ph.D. Program Director for Kidney and Urology Epidemiology National Institute of Diabetes and Digestive and Kidney Diseases Bethesda, MD
Sarah Garner, Ph.D., B.Pharm., M.R.Pharm.S Associate Director, Research and Development National Institute for Health and Clinical Excellence (NICE) London, United Kingdom
Rosemarie Hakim, Ph.D. Senior Epidemiologist Centers for Medicare & Medicaid Services Baltimore, MD
Kenneth J. Rothman, Dr.P.H. Vice President, Epidemiology Research RTI Health Solutions Research Triangle Park, NC
Chapter 4. Use of Registries in Product Safety Assessment
Jeffrey Brown, Ph.D. Research Director, Therapeutics Research and Infectious Disease Epidemiology Program Lecturer, Department of Population Medicine Harvard Pilgrim Health Care Institute/Harvard Medical School Boston, MA
Leslye K. Fitterman, Ph.D. Centers for Medicare & Medicaid Services Baltimore, MD
Richard E. Gliklich, M.D. President Outcome Sciences, Inc. d/b/a Outcome Principal Investigator, Outcome DEcIDE Center Professor, Harvard Medical School Cambridge, MA
Thomas Gross, M.D., M.P.H. Deputy Director, Postmarket Science Office of Surveillance and Biometrics Center for Devices and Radiological Health Food and Drug Administration Rockville, MD
Joanna Haas, M.D., M.Sc. Vice President, Global Patient Safety and Risk Management Genzyme Corporation Cambridge, MA
Michael Ibara, Pharm.D. Head of Pharmacovigilance Information Management Pfizer, Inc. New York, NY
Steven E. Nissen, M.D. Chairman, Department of Cardiovascular Medicine Cleveland Clinic Cleveland, OH
Richard Platt, M.D., M.Sc. Professor and Chair, Department of Population Medicine Harvard Medical School and Harvard Pilgrim Health Care Institute Boston, MA
Kenneth J. Rothman, Dr.P.H. Vice President, Epidemiology Research RTI Health Solutions Research Triangle Park, NC
Juergen Schmider M.D., Ph.D. Corporate Safety Officer and Vice President, Global Pharmacovigilance & Epidemiology Cephalon, Inc. Frazer, PA
Chapter 5. Data Elements for Registries
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Gregg C. Fonarow, M.D. Professor of Medicine/Cardiology Director, Ahmanson-UCLA Cardiomyopathy Center Associate Chief, UCLA Division of Cardiology The Eliot Corday Chair in Cardiovascular Medicine and Science David Geffen School of Medicine at UCLA Los Angeles, CA
Janet Hiller, M.P.H., Ph.D. Professor of Public Health Director, Adelaide Health Technology Assessment (AHTA) University of Adelaide Adelaide, Australia
Robert Reynolds, Sc.D. Senior Director, Global Head, Epidemiology Safety and Risk Management Pfizer, Inc. New York, NY
Chapter 6. Data Sources for Registries
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Marcus D. Wilson, Pharm.D. President HealthCore Wilmington, DE
Chapter 7. Linking Registry Data: Technical and Legal Considerations
Rachel S. Dokholyan, M.P.H. Project Leader Duke Clinical Research Institute Durham, NC
Nancy A. Dreyer, M.P.H., Ph.D. Chief of Scientific Affairs Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Richard E. Gliklich, M.D. President Outcome Sciences, Inc. d/b/a Outcome Principal Investigator, Outcome DEcIDE Center Professor, Harvard Medical School Cambridge, MA
Thomas Gross, M.D., M.P.H. Deputy Director, Postmarket Science Office of Surveillance and Biometrics Center for Devices and Radiological Health Food and Drug Administration Rockville, MD
Julia I. Lane National Science Foundation Washington, DC
Lawrence Muhlbaier, Ph.D. Duke Clinical Research Institute Durham, NC
Eric Peterson, M.D., M.P.H. Physician Investigator Duke Clinical Research Institute Durham, NC
Victoria M. Prescott, J.D. CEO McBroom Consulting, LLC Tampa, FL
Gerald F. Riley, M.S.P.H. Social Science Research Analyst Office of Research, Development, and Information Centers for Medicare & Medicaid Services Baltimore, MD
Anne E. Trontell, M.D., M.P.H. Program Director, Centers for Education and Research on Therapeutics Center for Outcomes and Evidence Agency for Healthcare Research and Quality Rockville, MD
Cunlin Wang, M.D., Ph.D. Medical Epidemiologist, Center for Device and Radiological Health Food and Drug Administration Silver Spring, MD Assistant Professor Johns Hopkins Medical Institutions Baltimore, MD
Marcy Wilder, J.D. Partner Hogan & Hartson LLP Washington, DC
Chapter 8. Principles of Registry Ethics, Data Ownership, and Privacy
Stephen W. Bernstein, J.D. Head, Health Industry Practice Group McDermott Will & Emery LLP Boston, MA
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Steve E. Phurrough, M.D., M.P.A. Medical Officer Agency for Healthcare Research and Quality Rockville, MD
Chapter 9. Recruiting and Retaining Participants in the Registry
Pamela S. Douglas, M.D., FACC Ursula Geller Professor of Research in Cardiovascular Diseases Director of Imaging Program at Duke Clinical Research Institute Duke University Durham, NC
Gregg C. Fonarow, M.D. Professor of Medicine/Cardiology Director, Ahmanson-UCLA Cardiomyopathy Center Associate Chief, UCLA Division of Cardiology The Eliot Corday Chair in Cardiovascular Medicine and Science David Geffen School of Medicine at UCLA Los Angeles, CA
Bruce C. Marshall, M.D. Vice President of Clinical Affairs Cystic Fibrosis Foundation Bethesda, MD
Charles R. McKay, M.D., FACC Professor of Medicine, Chief, Division of Cardiology Los Angeles Biomedical Research Institute at Harbor-UCLA Medical Center Torrance, CA
Kristi R. Mitchell, M.P.H. Senior Director, Research, Development, and Quality Products American College of Cardiology Washington, DC
Grannum R. Sant, M.D., FRCS, FACS Vice President and Interim Head, Oncology Medical Unit, Head of Urology Portfolio Sanofi-aventis U.S. Bridgewater, NJ Adjunct Professor of Urology, Tufts University School of Medicine Boston, MA
Chapter 10. Data Collection and QualityAssurance
Daniel Caños Epidemiologist, Division of Epidemiology Office of Surveillance and Biometrics Center for Devices and Radiological Health, Food and Drug Administration Silver Spring, MD
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Brenda K. Edwards, Ph.D. Associate Director, Surveillance Research Program Division of Cancer Control and Population Sciences National Cancer Institute Bethesda, MD
Robert Reynolds, Sc.D. Senior Director, Global Head, Epidemiology Safety and Risk Management Pfizer, Inc. New York, NY
Chapter 11. Interfacing Registries with Electronic Health Records
Susan Adams, J.D. Director, Committee for the Protection of Human Subjects Dartmouth College Hanover, NH
Nancy A. Dreyer, M.P.H., Ph.D. Chief of Scientific Affairs Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Jonathan S. Einbinder, M.D., M.P.H. Brigham and Women’s Hospital Boston, MA
Thomas Gross, M.D., M.P.H. Deputy Director, Postmarket Science Office of Surveillance and Biometrics Center for Devices and Radiological Health Food and Drug Administration Rockville, MD
John D. Halamka, M.D., M.S. Beth Israel Deaconess Medical Center Harvard Medical School New England Health Electronic Data Interchange Network (NEHEN) MA-SHARE U.S. Healthcare Information Technology Standards Panel (HITSP) Boston, MA
Michael A. Ibara Head of Pharmacovigilance Information Management Pfizer, Inc. New York, NY
Rebecca D. Kush, Ph.D. President and CEO Clinical Data Interchange Standards Consortium (CDISC) Austin, TX
Steve E. Phurrough, M.D., M.P.A. Medical Officer Agency for Healthcare Research and Quality Rockville, MD
Michael T. Rapp, M.D., J.D., FACEP Centers for Medicare & Medicaid Services Baltimore, MD
Anne E. Trontell, M.D., M.P.H. Program Director, Centers for Education and Research on Therapeutics Center for Outcomes and Evidence Agency for Healthcare Research and Quality Rockville, MD
Chapter 12. Adverse Event Detection, Processing, and Reporting
Thomas Gross, M.D., M.P.H. Deputy Director, Postmarket Science Office of Surveillance and Biometrics Center for Devices and Radiological Health Food and Drug Administration Rockville, MD
Susan T. Sacks, Ph.D. Director, Epidemiology Roche Biometrics Nutley, NJ
Chapter 13. Analysis and Interpretation of Registry Data To Evaluate Outcomes
Steve E. Phurrough, M.D., M.P.A. Medical Officer Agency for Healthcare Research and Quality Rockville, MD
Rosemarie Hakim, Ph.D. Senior Epidemiologist Centers for Medicare & Medicaid Services Baltimore, MD
Chapter 14. Evaluating Registries
Peter Littlejohns, M.D. Clinical and Public Health Director National Institute for Health and Clinical Excellence (NICE) London, UK
Suzanne L. West, M.P.H, Ph.D. Health, Social, and Economics Research RTI International Research Triangle Park, NC

We would also like to acknowledge the reviewers who contributed to the first version of the user’s guide. These reviewers are listed below in alphabetical order.

Steven J. Atlas, M.D., M.P.H. Assistant Professor of Medicine Harvard Medical School Associate Physician, General Medicine Division Massachusetts General Hospital Boston, MA
Stephen W. Bernstein, J.D. Head, Health Industry Practice Group McDermott Will & Emery LLP Boston, MA
Michael A. Carome, M.D. Captain, U.S. Public Health Service Associate Director for Regulatory Affairs Office for Human Research Protections Rockville, MD
Patrice Desvigne-Nickens, M.D. Medical Officer Heart Failure and Arrhythmia Branch Division of Cardiovascular Science National Heart, Lung, and Blood Institute Bethesda, MD
Brenda K. Edwards, Ph.D. Associate Director, Surveillance Research Program Division of Cancer Control and Population Sciences National Cancer Institute Bethesda, MD John P. Fanning, LL.B. Retired Washington, D.C.
Shamiram Feinglass, M.D., M.P.H. Senior Medical Officer Coverage and Analysis Group Office of Clinical Standards and Quality Centers for Medicare & Medicaid Services U.S. Public Health Service Baltimore, MD
Sally Flanzer, Ph.D., CIP Regional Program Manager, Child Welfare Administration for Children and Families Region IX San Francisco, CA Formerly Human Protections Administrator Office of Extramural Research, Education and Priority Populations Agency for Healthcare Research and Quality Rockville, MD
Gregg C. Fonarow, M.D. Professor of Medicine/Cardiology Director, Ahmanson-UCLA Cardiomyopathy Center Associate Chief, UCLA Division of Cardiology The Eliot Corday Chair in Cardiovascular Medicine and Science David Geffen School of Medicine at UCLA Los Angeles, CA
Sarah Garner, Ph.D., B.Pharm., M.R.Pharm.S. Associate Director, Research and Development National Institute for Health and Clinical Excellence (NICE) London, United Kingdom
Marie R. Griffin, M.D., M.P.H. Professor of Preventive Medicine Professor of Medicine Vanderbilt University School of Medicine Nashville, TN
Thomas Gross, M.D., M.P.H. Deputy Director, Postmarket Science Office of Surveillance and Biometrics Center for Devices and Radiological Health Food and Drug Administration Rockville, MD
Stephen C. Hammill, M.D. Professor of Medicine Mayo Clinic College of Medicine Director, Electrocardiography Laboratory Rochester, MN
Christina Heide Senior Health Information Privacy Policy Specialist Office for Civil Rights U.S. Department of Health and Human Services Washington, D.C.
Janet Hiller, M.P.H., Ph.D. Professor of Public Health Director, Adelaide Health Technology Assessment (AHTA) University of Adelaide Adelaide, Australia
Peter I. Juhn, M.D., M.P.H. President Therapeutic Resource Centers Medco Health Solutions, Inc. Franklin Lakes, NJ
Catherine Koepper Associate Director, Global Registry Program Genzyme Corporation Cambridge, MA
Joseph A. Ladapo, M.D., Ph.D. Beth Israel Deaconess Medical Center Boston, MA
Peter Littlejohns, M.D. Clinical and Public Health Director National Institute for Health and Clinical Excellence (NICE) London, UK
Susan McAndrew, J.D. Deputy Director for Health Information Privacy Office for Civil Rights U.S. Department of Health and Human Services Washington, D.C.
Newell McElwee, Pharm.D., M.S.P.H. Senior Director/Team Leader Global Outcomes Research Pfizer, Inc. New York, NY
J. Michael McGinnis, M.D., M.P.P. Senior Scholar Institute of Medicine National Academy of Sciences Washington, DC
Gareth Parry, Ph.D. Director, Quality Measurement & Analysis Department of Medicine Children’s Hospital Boston, MA
Steven Pearson, M.D. Associate Professor of Ambulatory Care and Prevention Harvard Medical School Boston, MA
Robert Reynolds, Sc.D. Senior Director, Global Head, Epidemiology Safety and Risk Management Pfizer, Inc. New York, NY
Sara Rosenbaum, J.D. Hirsh Professor and Chair, Department of Health Policy The George Washington University Medical Center School of Public Health and Health Services Washington, DC
Kenneth J. Rothman, Dr.P.H. Vice President, Epidemiology Research RTI Health Solutions Research Triangle Park, NC
Susan T. Sacks, Ph.D. Director, Epidemiology Roche Biometrics Nutley, NJ
Grannum R. Sant, M.D., FRCS, FACS Vice President and Interim Head, Oncology Medical Unit, Head of Urology Portfolio Sanofi-aventis U.S. Bridgewater, NJ Adjunct Professor of Urology, Tufts University School of Medicine Boston, MA
William B. Saunders, Ph.D., M.P.H. Manager, Research & Analytics GE Medical Charlotte, NC
Walter L. Straus, M.D., M.P.H. Global Director for Scientific Affairs - Vaccines Merck Research Laboratories Adjunct Scholar, Center for Clinical Epidemiology and Biostatistics University of Pennsylvania School of Medicine Upper Gwynedd, PA
Hugh Tilson, M.D., Dr.P.H. Adjunct Professor of Epidemiology, Health Policy, and Public Health Leadership University of North Carolina School of Public Health Chapel Hill, NC Adjunct Professor of Medicine Duke University Durham, NC
Jack V. Tu, M.D., Ph.D. Senior Scientist Institute for Clinical Evaluative Sciences Ontario, Canada
Suzanne L. West, M.P.H, Ph.D. Research Associate Professor Department of Epidemiology School of Public Health University of North Carolina at Chapel Hill Chapel Hill, NC
Marcus D. Wilson, Pharm.D. President HealthCore Wilmington, DE