# Case Example Contributors

[The findings and conclusions in this document are those of the contributors and reviewers. The contributors and reviewers participated as individuals and not necessarily as representatives of their organizations. No statement in this document should be construed as an official position of any organization represented here.]

Case Example 1: Using Registries To Understand Rare Diseases
Betsy Bogard, M.S Associate Director, Program Management Genzyme Corporation Cambridge, MA
Cathy Koepper Associate Director, Global Registry Program Genzyme Corporation Cambridge, MA
John Yee, M.D., M.P.H. Vice President, US and Global Medical Affairs Genzyme Corporation Cambridge, MA
Case Example 2: Creating a Registry To Fulfill Multiple Purposes and Using a Publications Committee To Review Data Requests
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Edna J. Stoehr Global Study Manager Genentech, Inc. South San Francisco, CA
Case Example 3: Using a Registry To Track Emerging Infectious Diseases
Nancy A. Dreyer, M.P.H., Ph.D. Chief of Scientific Affairs Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Laura Whiteside Research Assistant Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 4: Using a Collaborative Approach To Plan and Implement a Registry
Laura Whiteside Research Assistant Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 5: Using a Scientific Advisory Board To Support Investigator Research Projects
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Michael D. Taylor, Pharm.D., Ph.D. Senior Epidemiologist Genentech South San Francisco, CA
Case Example 6: Determining When To Stop an Open-Ended Registry
Ann Mallard, M.P.H. Associate Director, Registries and Health Outcomes Kendle International Inc Wilmington, NC
Pattra Mattox, M.Sc. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 7: Designing a Registry for a Health Technology Assessment
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Hannah Patrick Consultant Clinical Advisor to the IP Programme National Institute for Health and Clinical Excellence (NICE) London, United Kingdom
Case Example 8: Assessing the Safety of Products Used During Pregnancy
Deborah Covington, Dr.P.H. Global Head Observational Studies and Pregnancy Registries PPD Wilmington, NC
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 9: Designing a Registry To Study Outcomes
Sidney A. Cohen, M.D., Ph.D. Vice President, Medical Affairs Cordis Corporation and Conor Medsystems Menlo Park, CA
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 10: Analyzing Clinical Effectiveness and Comparative Effectiveness in an Observational Study
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Barbara Lippe, M.D. Principal Medical Director Genentech, Inc. South San Francisco, CA
Case Example 11: Using a Registry To Assess Long-Term Product Safety
Sarah Garner, Ph.D., B.Pharm., M.R.Pharm.S. Associate Director, Research and Development National Institute for Health and Clinical Excellence (NICE) London, United Kingdom
Pattra Mattox, M.Sc. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Deborah Symmons, M.D. Professor of Rheumatology and Musculoskeletal Epidemiology University of Manchester Manchester, UK
Case Example 12: Using a Registry To Monitor Long-Term Product Safety
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Rachel E. Sobel, Dr.P.H. Senior Director, Epidemiology Pfizer New York, NY
Case Example 13: Identifying and Responding to Adverse Events Found in a Registry Database
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Liz Paxton, M.A. Director Kaiser Permanente National Implant Registries Southern California Permanente Medical Group San Diego, CA
Case Example 14: Selecting Data Elements for a Registry
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Scott McKenzie, M.D. Regional Director Outcomes Research Ortho Biotech Clinical Affairs LLC Dallas, TX
Case Example 15: Using Performance Measures To Develop a Dataset
Kenneth A. LaBresh, M.D. Senior Vice President, Chief Medical Officer MassPRO Waltham, MA
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Louise Morgan, M.S.N., CPHQ National Director, Get With The Guidelines^®^ American Heart Association Scotch Plains, NJ
Lee H. Schwamm, M.D. Professor of Neurology Harvard Medical School Vice Chair of Neurology and Director TeleStroke & Acute Stroke Services Massachusetts General Hospital Boston, MA
Kathleen Turner, M.B.A. Formerly Senior Manager, Quality Improvement Initiatives American Heart Association Dallas, TX
Case Example 16: Developing and Validating a Patient-Administered Questionnaire
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Grannum R. Sant, M.D., FRCS, FACS Vice President and Interim Head Oncology Medical Unit Head of Urology Portfolio Sanofi-aventis U.S. Bridgewater, NJ Adjunct Professor of Urology, Tufts University School of Medicine Boston, MA
Case Example 17: Understanding the Needs and Goals of the Registry Participants
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
John Spertus, M.D., M.P.H., FACC, FAHA Deputy Editor, Circulation: Cardiovascular Quality and Outcomes Research Professor, University of Missouri – Kansas City Clinical Director of Outcomes Research Mid America Heart Institute of Saint Luke’s Hospital Kansas City, MO
Case Example 18: Using Validated Measures To Collect Patient-Reported Outcomes
Kathleen M. Fox, Ph.D., M.H.S. President Strategic Healthcare Solutions, LLC Monkton, MD
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 19: Integrating Data from Multiple Sources With Patient ID Matching
Noam H. Arzt, Ph.D. President HLN Consulting, LLC San Diego, CA
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 20: Linking Registries at the International Level
Luigi Naldi, M.D. Director, Centro Studi GISED Fondazione per la Ricerca Ospedale Maggiore (FROM) Presidio Ospedaliero Matteo Rota Bergamo, Italy
Laura Whiteside Research Assistant Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 21: Linking a Procedure-Based Registry With Claims Data To Study Long-Term Outcomes
Mark J. Fox Associate Director, Account Management and Contract Administration National Cardiovascular Data Registry American College of Cardiology Foundation Washington, DC
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 22: Linking Registry Data To Examine Long-Term Survival
Richard Feltbower, Ph.D. Senior Research Fellow, Paediatric Epidemiology GroupCentre for Epidemiology & Biostatistics, University of Leeds Leeds, United Kingdom
Pattra Mattox, M.Sc. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Patricia McKinney, Ph.D. Professor of Paediatric Epidemiology, Paediatric Epidemiology Group Centre for Epidemiology & Biostatistics, University of Leeds Leeds, United Kingdom
Roger Parslow, Ph.D. Senior Lecturer, Paediatric Epidemiology Group Centre for Epidemiology and Biostatistics, Leeds Institute of Genetics, Health & Therapeutics (LIGHT) Leeds, United Kingdom
Marlous Van Laar, M.Sc. Research Statistician, Paediatric Epidemiology Group Centre for Epidemiology & Biostatistics, University of Leeds Leeds, United Kingdom
Case Example 23: Considering the Institutional Review Board Process During Registry Design
Brian P. Carey, J.D. Foley Hoag LLP Boston, MA
Barry A. Siegel, M.D. Professor of Radiology and Medicine Director, Division of Nuclear Medicine Washington University School of Medicine St. Louis, MO
Case Example 24: Issues With Obtaining Informed Consent
Moira K. Kapral, M.D., M.Sc., FRCPC Associate Professor of Medicine, University of Toronto Senior Scientist, Institute for Clinical Evaluative Sciences Ontario, Canada
Janice A. Richards, R.N., B.A. Project Manager Registry of the Canadian Stroke Network Toronto, Ontario, Canada
Jack V. Tu, M.D., Ph.D. Senior Scientist Institute for Clinical Evaluative Sciences Ontario, Canada
Case Example 25: Building Value as a Means To Recruit Hospitals
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Kathleen Turner, M.B.A. Formerly Senior Manager, Quality Improvement Initiatives American Heart Association Dallas, TX
Case Example 26: Using Registry Tools To Recruit Sites
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 27: Using Proactive Awareness Activities To Recruit Patients for a Pregnancy Exposure Registry
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Susan Sinclair Roberts, Ph.D. Assistant Professor, Clinical Research Program University of North Carolina Wilmington Wilmington, NC
Case Example 28: Using Reimbursement as an Incentive for Participation
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Kristi R. Mitchell, M.P.H. Senior Director, Research, Development, and Quality Products American College of Cardiology Washington, DC
Case Example 29: Data Collection Challenges in Rare Disease Registries
Joe Thomas Clarke, M.D. Paediatrician Centre Hospitalier Universitaire Sherbrooke QC, Canada
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 30: Managing Care and Quality Improvement for Chronic Diseases
Carl Donisi Director of Clinical Operations, Physician-Hospital Organization Tri-State Child Health Service, Cincinnati Children’s Hospital Cincinnati, OH
Keith Mandel, M.D. Vice President of Medical Affairs, Physician Hospital Organization Cincinnati Children’s Hospital Medical Center Cincinnati, OH
Pattra Mattox, M.Sc. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Randy Woodward Senior Application Developer Division of Emergency Medicine, Center for Simulation and Research Cincinnati Children’s Hospital Medical Center Cincinnati, OH
Case Example 31: Developing a Performance-Linked Access System
Michael Karukin, P.A., Ph.D. Director, Registries Teva Pharmaceuticals USA Miami, FL
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 32: Using Audits To Monitor Data Quality
Jack L. Cronenwett, M.D. Professor of Surgery Dartmouth-Hitchcock Medical Center Lebanon, NH
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 33: Challenges in Creating Electronic Interfaces Between Registries and Electronic Health Records
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Kristi R. Mitchell, M.P.H. Senior Director, Research, Development, and Quality Products American College of Cardiology Washington, DC
Case Example 34: Creating a Registry Interface To Incorporate Data From Multiple Electronic Health Records
Jen Moore Senior Director, Operations MMC Physician-Hospital Organization Portland, ME
Laura Whiteside Research Assistant Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 35: Technical and Security Issues of Creating a Health Information Exchange
Jenifer Hughes, MedIT Senior Vice President, Administrative Network, Inc Oakland Southfield Physicians, PC Southfield, MI
Michelle Bertagna Leavy, MPH Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 36: Developing a New Model for Gathering and Reporting Adverse Events
Dan Levy, M.S. Vice President of Engineering Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Case Example 37: Using Registry Data To Evaluate Outcomes by Practice
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA
Jeffrey Wagener, M.D. Medical Director Genentech, Inc. South San Francisco, CA
Case Example 38: Using Registry Data To Study Patterns of Use and Outcomes
Marnie L. Boron, Pharm.D Associate Director, Medical Affairs MedImmune, Inc. Gaithersburg, MD
Michelle Bertagna Leavy, M.P.H. Research Associate Outcome Sciences, Inc. d/b/a Outcome Cambridge, MA