# References

1 Institute of Medicine. Crossing the quality chasm: A new health system for the 21st century. Washington DC. The National Academies Press. 2001.
2 Wolff JL, Starfield B, Anderson G. Prevalence, expenditures, and complications of multiple chronic conditions in the elderly. Arch Intern Med. November. 11. 2002;162(20):2269-76. [pmid: 12418941].
3 Bodenheimer T, B-M R. Care Management of Patients with Complex Health Care Needs. The Synthesis Project: Princeton. 2009:1-36.
4 Boult C, Green AF, Boult LB, et al. Successful models of comprehensive care for older adults with chronic conditions: evidence for the institute of medicine's “Retooling for an aging America” report. J Am Geriatr Soc. 2009;57(12):2328-37. [pmid: 20121991].
5 Kane RL. What can improve chronic disease care?. J Am Geriatr Soc. 2009;57(12):2338-45. [pmid: 20121992].
6 McDonald KM, Sundaram V, Bravata DM, et al. Care Coordination. Vol 7. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under contract 290-02-0017). AHRQ Publication No. 04(07)-0051-7. Agency for Healthcare Research and Quality. Rockville, MD. June. 2007.
7 Kersbergen AL. Case management: A rich history of coordinating care to control costs. Nurs Outlook. 1996;44(4):169-72. [pmid: 8871998].
8 Knollmueller R. Case management: what's in a name?. Nurs Manage. 1989;20(10):38-42. [pmid: 2586933].
9 Shueman S. A model of case management for mental health services. Q Rev Bull. 1987;13:314-7.
10 Johnson P, Rubin A. Case management in mental health: a social work domain?. Social Work. 1983;28:49-55. [pmid: 10314015].
11 Intagliata J. Improving the quality of community care for the chronically mentally disabled: the role of case management. Schizophr Bull. 1982;8:655-74. [pmid: 7178854].
12 Lamb G. Conceptual and methodological issues in nurse case management research. Adv Nurs Sci. 1992;15(2):16-24.
13 McCall N, Cromwell J. Results of the Medicare Health Support disease-management pilot program. N Engl J Med. Nov. 3. 2011;365(18):1704-12. [pmid: 22047561].
14 Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. Sep. 26. 2006;114(13):1432-45. [pmid: 16952985].
15 Capitman JA, Haskins B, Bernstein J. Case management approaches in coordinated community-oriented long-term care demonstrations. Gerontologist. Aug. 1986;26(4):398-404. [pmid: 3089878].
16 Zawadski RT, Eng C. Case management in capitated long-term care. Health Care Financ Rev. Dec. Spec No. 1988:75-81. [pmid: 10312976].
17 Long MJ. Case management model or case manager type? That is the question. Health Care Manag. Jun. 2002;20(4):53-65. [pmid: 12083179].
18 Mor V, Wool M, Guadagnoli E, et al. The impact of short term case management on cancer patients' concrete needs and quality of life. Adv Med Sociol. 1995;6:269-94.
19 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. Feb. 17. 1999;281(7):613-20. [pmid: 10029122].
20 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. [pmid: 15086645].
21 Coleman EA, Parry C, Chalmers S, et al. The care transitions intervention: results of a randomized controlled trial. Arch Intern Med. Sep. 25. 2006;166(17):1822-8. [pmid: 17000937].
22 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259].
23 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
24 U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. July. 2008. www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.
25 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov.
26 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
27 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
28 Fan VS, Gaziano JM, Lew R, et al. A comprehensive care management program to prevent chronic obstructive pulmonary disease hospitalizations: a randomized, controlled trial. Ann Intern Med. May. 15. 2012;156(10):673-83. [pmid: 22586006].
29 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. Mar. 14. 2011;171(5):460-6. [pmid: 21403043].
30 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. [pmid: 17302651].
31 Mittelman MS, Haley WE, Clay OJ, et al. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. 2006;67(9):1592-9. [pmid: 17101889].
32 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries. JAMA. February. 11. 2009. 2009;301(6):603-18. [pmid: 19211468].
33 Schore JL, Brown RS, Cheh VA. Case management for high-cost Medicare beneficiaries. Health Care Financ Rev. Summer. 1999;20(4):87-101. [pmid: 11482127].
34 Schore J, Brown R, Cheh V, et al. Costs and Consequences of Case Management for Medicare Beneficiaries. Report prepared for the Health Care Financing Administration. Princeton (NJ). Mathematica Policy Research, Inc. 1997.
35 Newcomer R, Maravilla V, Faculjak P, et al. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. Dec. 2004;27(4):323-48. [pmid: 15492046].
36 Newcomer R, Miller R, Clay T, et al. Effects of the Medicare Alzheimer's Disease Demonstration on Medicare expenditures. Health Care Financ Rev. 1999;20(4):45-65. [pmid: 11482124].
37 Miller R, Newcomer R, Fox P. Effects of the Medicare Alzheimer's Disease Demonstration on nursing home entry. Health Serv Res. Aug. 1999;34(3):691-714. [pmid: 10445898].
38 Martin DC, Berger ML, Anstatt DT, et al. A randomized controlled open trial of population-based disease and case management in a Medicare Plus Choice health maintenance organization. Prev Chronic Dis. Oct. 2004;1(4):A05. [pmid: 15670436].
39 Fitzgerald JF, Smith DM, Martin DK, et al. A case manager intervention to reduce readmissions. Arch Intern Med. Aug. 8. 1994;154(15):1721-9. [pmid: 8042889].
40 Latour CH, de Vos R, Huyse FJ, et al. Effectiveness of post-discharge case management in general-medical outpatients: a randomized, controlled trial. Psychosomatics. Sep-Oct. 2006;47(5):421-9. [pmid: 16959931].
41 Latour CH, Bosmans JE, van Tulder MW, et al. Cost-effectiveness of a nurse-led case management intervention in general medical outpatients compared with usual care: an economic evaluation alongside a randomized controlled trial. J Psychosom Res. Mar. 2007;62(3):363-70. [pmid: 17324688].
42 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. Dec. 2008;56(12):2195-202. [pmid: 19093919].
43 Kruse RL, Zweig SC, Nikodim B, et al. Nurse care coordination of older patients in an academic family medicine clinic: 5-year outcomes. J Clin Outcomes Manage. 2010;17(5):209-15.
44 Gravelle H, Dusheiko M, Sheaff R, et al. Impact of case management (Evercare) on frail elderly patients: controlled before and after analysis of quantitative outcome data. Br Med J. Jan. 6. 2007;334(7583):31. [pmid: 17107984].
45 Picariello G, Hanson C, Futterman R, et al. Impact of a geriatric case management program on health plan costs. Popul Health Manag. Aug. 2008;11(4):209-15. [pmid: 18942926].
46 Bird SR, Kurowski W, Dickman GK, et al. Integrated care facilitation for older patients with complex health care needs reduces hospital demand. Aust Health Rev. Aug. 2007;31(3):451-61. discussion 49-50. [pmid: 17669069].
47 Huws DW, Cashmore D, Newcombe RG, et al. Impact of case management by advanced practice nurses in primary care on unplanned hospital admissions: a controlled intervention study. BMC Health Serv Res. 2008;8:115. [pmid: 18510730].
48 Keating P, Sealy A, Dempsey L, et al. Reducing unplanned hospital admissions and hospital bed days in the over 65 age group: results from a pilot study. J Integr Care. 2008;16(1):3-8.
49 Lu KY, Lin PL, Tzeng LC, et al. Effectiveness of case management for community elderly with hypertension, diabetes mellitus, and hypercholesterolemia in Taiwan: a record review. Int J Nurs Stud. Nov. 2006;43(8):1001-10. [pmid: 16384558].
50 Luzinski CH, Stockbridge E, Craighead J, et al. The community case management program: for 12 years, caring at its best. Geriatr Nurs. May-Jun. 2008;29(3):207-15. [pmid: 18555162].
51 Moran G, Coleman V, Heaney S, et al. An alternative model for case management in Flintshire. Br J Community Nurs. May. 2008;13(5):227-31. [pmid: 18771186].
52 Onder G, Liperoti R, Soldato M, et al. Case management and risk of nursing home admission for older adults in home care: results of the AgeD in HOme Care Study. J Am Geriatr Soc. Mar. 2007;55(3):439-44. [pmid: 17341249].
53 Duke C. The frail elderly community-based case management project. Geriatr Nurs. Mar-Apr. 2005;26(2):122-7. [pmid: 15824728].
54 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. Spring. 2000;24(3):12-20. [pmid: 10986928].
55 Schifalacqua MM, Ulch PO, Schmidt M. How to make a difference in the health care of a population. One person at a time. Nurs Adm Q. Jan-Mar. 2004;28(1):29-35. [pmid: 14986505].
56 Hansen JC, Hewitt M. PACE provides a sense of belonging for elders. Generations. Spring. 2012. 2012;36(1):37-43.
57 Ritchie CA, Thomas DR. Home-based primary care in the VA setting, with a focus on Birmingham, Alabama. J Long Term Home Health Care. 1998;17(4):18-25. [pmid: 10187110].
58 Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. Dec. 12. 2007;298(22):2623-33. [pmid: 18073358].
59 Oliva NL. A closer look at nurse case management of community-dwelling older adults: observations from a longitudinal study of care coordination in the chronically ill. Prof Case Manag. Mar-Apr. 2010;15(2):90-100. [pmid: 20234292].
60 Schore J, Peikes D, Peterson G, et al. Fourth Report to Congress on the Evaluation of the Medicare Coordinated Care Demonstration. Mathematica Reference Number: 6555-440. (Prepared by Mathematica Policy Research, Inc. under contract number HHSM-500-2005-00025I (0012)). Baltimore, MD. Centers for Medicare & Medicaid Services. March. 2011.
61 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of guided care on family caregivers. Gerontologist. Aug. 2010;50(4):459-70. [pmid: 19710354].
62 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. Mar. 2010;25(3):235-42. [pmid: 20033622].
63 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. Mar. 2008;63(3):321-7. [pmid: 18375882].
64 Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. Br Med J. May. 1998;316(7141):1348-51. [pmid: 9563983].
65 Kristensson J, Ekwall AK, Jakobsson U, et al. Case managers for frail older people: a randomised controlled pilot study. Scand J Caring Sci. Dec. 2010;24(4):755-63. [pmid: 20409057].
66 Marshall BS, Long MJ, Voss J, et al. Case management of the elderly in a health maintenance organization: the implications for program administration under managed care. J Healthc Manag. Nov-Dec. 1999;44(6):477-91. discussion 92-3. [pmid: 10662433].
67 Gagnon AJ, Schein C, McVey L, et al. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. Sep. 1999;47(9):1118-24. [pmid: 10484257].
68 Applebaum R, Straker J, Mehdizadeh S, et al. Using high-intensity care management to integrate acute and long-term care services: substitute for large scale system reform?. Care Manag J. Spring. 2002;3(3):113-9. [pmid: 12632877].
69 Leung AC, Yau DC, Liu CP, et al. Reducing utilisation of hospital services by case management: a randomised controlled trial. Aust Health Rev. 2004;28(1):79-86. [pmid: 15525254].
70 Leung AT, Liu CP, Chow NS, et al. Cost-benefit analysis of a case management project for the community-dwelling frail elderly in Hong Kong. J Appl Gerontol. 2004;23(1):70-85.
71 Chi YC, Chuang KY, Wu SC, et al. The assessment of a hospital-based care management model for long-term care services. J Nurs Res. Dec. 2004;12(4):317-26. [pmid: 15619182].
72 Morales-Asencio JM, Gonzalo-Jimenez E, Martin-Santos FJ, et al. Effectiveness of a nurse-led case management home care model in Primary Health Care. A quasi-experimental, controlled, multi-centre study. BMC Health Serv Res. 2008;8:193. [pmid: 18811927].
73 Schraeder C, Fraser C, Clark I, et al. Evaluation of a primary care nurse case management intervention for chronically ill community dwelling older people. J Nurs Healthc Chronic Illn. 2008;17:407-17.
74 Fletcher K, Mant J. A before and after study of the impact of specialist workers for older people. J Eval Clin Pract. Apr. 2009;15(2):335-40. [pmid: 19335494].
75 Hammer BJ. Community-based case management for positive outcomes. Geriatr Nurs. Sep-Oct. 2001;22(5):271-5. [pmid: 11606909].
76 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. Aug. 2003;49:992-7. [pmid: 12943358].
77 Schein C, Gagnon AJ, Chan L, et al. The association between specific nurse case management interventions and elder health. J Am Geriatr Soc. Apr. 2005;53(4):597-602. [pmid: 15817004].
78 Long MJ, Marshall BS. What price an additional day of life? A cost-effectiveness study of case management. Am J Manag Care. Aug. 2000;6(8):881-6. [pmid: 11186500].
79 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of dementia in the United States: The Aging, Demographics, and Memory Study. Neuroepidemiology. 2007;29(1-2):125-32. [pmid: 17975326].
80 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May. 10. 2006. 2006;295(18):2148-57. [pmid: 16684985].
81 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: A randomized trial. J Am Geriatr Soc. 2001;49(10):1282-7. [pmid: 11890485].
82 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200-8. [pmid: 20121986].
83 Jansen A, van Hout H, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. 2011;48(8):933-43. [pmid: 21356537].
84 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care. Ann Intern Med. November. 21. 2006. 2006;145(10):713-26. [pmid: 17116916].
85 Mittelman MS, Brodaty H, Wallen AS, et al. A Three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: Effects on caregiver depression. Am J Geriatr Psychiatry. 2008;16(11):893-904. [pmid: 18978250].
86 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. 2008;59(4). [pmid: 18378844].
87 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. Apr. 2010;25(4):395-402. [pmid: 19606455].
88 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early stage Alzheimer's patients and their families. Am J Alzheimers Dis. 2000;15(5):284-90.
89 Eggert GM, Zimmer JG, Hall WJ, et al. Case management: a randomized controlled study comparing a neighborhood team and a centralized individual model. Health Serv Res. Oct. 1991;26(4):471-507. [pmid: 1917502].
90 Zimmer JG, Eggert GM, Chiverton P. Individual versus team case management in optimizing community care for chronically ill patients with dementia. J Aging Health. Aug. 1990;2(3):357-72. [pmid: 10170566].
91 Clark P, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging Ment Health. 2004;8(1):40-51. [pmid: 14690867].
92 Challis D, von Abendorff R, Brown P, et al. Care management, dementia care and specialist mental health services: an evaluation. Int J Geriatr Psychiatry. Apr. 2002;17(4):315-25. [pmid: 11994884].
93 Specht J, Bossen A, Hall GR, et al. The effects of a dementia nurse care manager on improving caregiver outcomes outcomes. Am J Alzheimers Dis Other Demen. Jun-Jul. 2009;24(3):193-207. [pmid: 19246574].
94 Jansen AP, van Hout HP, van Marwijk HW, et al. (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. [pmid: 16343336].
95 Mittelman M, Roth D, Coon D, et al. Sustained benefit of supportive intervention for depressive symptoms in Alzheimer's caregivers. Am J Psychiatry. 2004;161:850-6. [pmid: 15121650].
96 Mittelman M, Roth D, Haley W, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems inpatients with Alzheimer's Disease: Results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. 2004;59(1):27-34. [pmid: 14722336].
97 Roth DL, Mittelman MS, Clay OJ, et al. Changes in social support as mediators of the impact of a psychosocial intervention for spouse caregivers of persons with Alzheimer's disease. Psychol Aging. Dec. 2005;20(4):634-44. [pmid: 16420138].
98 Brodaty H, Mittelman M, Gibson L, et al. The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. Sep. 2009;17(9):734-43. [pmid: 19705519].
99 Newcomer R, Yordi C, DuNah R, et al. Effects of the Medicare Alzheimer's Disease Demonstration on caregiver burden and depression. Health Serv Res. Aug. 1999;34(3):669-89. [pmid: 10445897].
100 Newcomer R, Spitalny M, Fox P, et al. Effects of the Medicare Alzheimer's Disease Demonstration on the use of community-based services. Health Serv Res. Aug. 1999;34(3):645-67. [pmid: 10445896].
101 Shelton P, Schraeder C, Dworak D, et al. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc. Dec. 2001;49(12):1600-5. [pmid: 11843991].
102 Duru OK, Ettner SL, Vassar SD, et al. Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. 2009;15(8):521-8. [pmid: 19670955].
103 Medicare Payment Advisory Commission. A Data Book: Healthcare Spending and the Medicare Program. Washington, D.C. Medicare Payment Advisory Commission. 2009.
104 Rosamond W, Flegal K, Furie K, et al. Heart Disease and Stroke Statistics--2008 Update: A Report From the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. 2008;117(4):e25-146. [pmid: 18086926].
105 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2004 Oct 19;141(8):I58; PMID: 15492334]. Ann Intern Med. Oct. 19. 2004;141(8):606-13. [pmid: 15492340].
106 Jaarsma T, van der Wal MH, Lesman-Leegte I, et al. Effect of moderate or intensive disease management program on outcome in patients with heart failure: Coordinating Study Evaluating Outcomes of Advising and Counseling in Heart Failure (COACH). Arch Intern Med. Feb. 11. 2008;168(3):316-24. [pmid: 18268174].
107 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. [pmid: 11823086].
108 Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. [pmid: 20478035].
109 Sisk JE, Hebert PL, Horowitz CR, et al. Improving patient care. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. 2006;145(4):273. [pmid: 16908918].
110 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 2003;163(7):809-17. [pmid: 12695272].
111 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. [pmid: 7565975].
112 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. [pmid: 11911726].
113 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. [pmid: 16624687].
114 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. MEDSURG Nursing. 2001;10(2):71-8.
115 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. [pmid: 8289096].
116 Creason H. Congestive heart failure telemanagement clinic. Lippincotts Case Manag. Jul-Aug. 2001;6(4):146-56. [pmid: 16398064].
117 National Institute of Diabetes and Digestive and Kidney Diseases NDIC. Fast facts on diabetes. 2011. diabetes.niddk.nih.gov/dm/pubs/statistics/in dex.aspx#fast.
118 Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27(7):1570-6. [pmid: 15220230].
119 Ishani A, Greer N, Taylor BC, et al. Effect of nurse case management compared with usual care on controlling cardiovascular risk factors in patients with diabetes: a randomized controlled trial. Diabetes Care. Aug. 2011;34(8):1689-94. [pmid: 21636796].
120 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. Feb. 2009;36(1):113-26. [pmid: 19188371].
121 Gary TL, Batts-Turner M, Bone LR, et al. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Feb. 2004;25(1):53-66. [pmid: 14980748].
122 Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med. Jul. 2003;37(1):23-32. [pmid: 12799126].
123 Gary TL, Batts-Turner M, Yeh HC, et al. The effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. Oct. 2009;169(19):1788-94. [pmid: 19858437].
124 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educ. 2005;31(6):880-9. [pmid: 16288095].
125 Krein SL, Klamerus ML, Vijan S, et al. Case management for patients with poorly controlled diabetes: a randomized trial. Am J Med. Jun. 1. 2004;116(11):732-9. [pmid: 15144909].
126 California Medi-Cal Type 2 Diabetes Study Group. Closing the gap: effect of diabetes case management on glycemic control among low-income ethnic minority populations: the California Medi-Cal type 2 diabetes study. Diabetes Care. Jan. 2004;27(1):95-103. [pmid: 14693973].
127 Pettitt DJ, Okada Wollitzer A, Jovanovic L, et al. Decreasing the risk of diabetic retinopathy in a study of case management: the California Medi-Cal Type 2 Diabetes Study. Diabetes Care. Dec. 2005;28(12):2819-22. [pmid: 16306539].
128 Shea S, Starren J, Weinstock RS, et al. Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) Project: rationale and design. J Am Med Inform Assoc. Jan-Feb. 2002;9(1):49-62. [pmid: 11751803].
129 Shea S, Weinstock RS, Starren J, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc. Jan-Feb. 2006;13(1):40-51. [pmid: 16221935].
130 Shea S, Weinstock RS, Teresi JA, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus: 5 year results of the IDEATel study. J Am Med Inform Assoc. Jul-Aug. 2009;16(4):446-56. [pmid: 19390093].
131 Palmas W, Shea S, Starren J, et al. Medicare payments, healthcare service use, and telemedicine implementation costs in a randomized trial comparing telemedicine case management with usual care in medically underserved participants with diabetes mellitus (IDEATel). J Am Med Inform Assoc. Mar-Apr. 2010;17(2):196-202. [pmid: 20190064].
132 Trief PM, Morin PC, Izquierdo R, et al. Depression and glycemic control in elderly ethnically diverse patients with diabetes: the IDEATel project. Diabetes Care. Apr. 2006;29(4):830-5. [pmid: 16567823].
133 Trief PM, Teresi JA, Izquierdo R, et al. Psychosocial outcomes of telemedicine case management for elderly patients with diabetes: the randomized IDEATel trial. Diabetes Care. May. 2007;30(5):1266-8. [pmid: 17325261].
134 Izquierdo R, Meyer S, Starren J, et al. Detection and remediation of medically urgent situations using telemedicine case management for older patients with diabetes mellitus. Ther Clin Risk Manag. Jun. 2007;3(3):485-9. [pmid: 18488079].
135 Brown SA, Garcia AA, Winter M, et al. Integrating education, group support, and case management for diabetic. Hispanics Ethn Dis. 2011;21(1):20-6. [pmid: 21462725].
136 Wolf AM, Siadaty M, Yaeger B, et al. Effects of lifestyle intervention on health care costs: Improving Control with Activity and Nutrition (ICAN). J Am Diet Assoc. Aug. 2007;107(8):1365-73. [pmid: 17659904].
137 Curtis J, Lipke S, Effland S, et al. Effectiveness and safety of medication adjustments by nurse case managers to control hyperglycemia. Diabetes Educ. Sep-Oct. 2009;35(5):851-6. [pmid: 19713556].
138 Wilson C, Curtis J, Lipke S, et al. Nurse case manager effectiveness and case load in a large clinical practice: implications for workforce development. Diabet Med. Aug. 2005;22(8):1116-20. [pmid: 16026383].
139 Dorr DA, Wilcox A, Donnelly SM, et al. Impact of generalist care managers on patients with diabetes. Health Serv Res. Oct. 2005;40(5 Pt 1):1400-21. [pmid: 16174140].
140 Dorr DA, Wilcox A, Jones S, et al. Care management dosage. J Gen Intern Med. Jun. 2007;22(6):736-41. [pmid: 17415620].
141 Meier DE, Thar W, Jordan A, et al. Integrating case management and palliative care. Journal of Palliat Med. Feb. 2004;7(1):119-34. [pmid: 15000796].
142 Engelhardt JB, McClive-Reed KP, Toseland RW, et al. Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care. Feb. 2006;12(2):93-100. [pmid: 16464138].
143 Goodwin JS, Satish S, Anderson ET, et al. Effect of nurse case management on the treatment of older women with breast cancer. J Am Geriatr Soc. Sep. 2003;51(9):1252-9. [pmid: 12919237].
144 Moore S, Corner J, Haviland J, et al. Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. Br Med J. Nov. 16. 2002;325(7373):1145. [pmid: 12433764].
145 McCorkle R, Benoliel JQ, Donaldson G, et al. A randomized clinical trial of home nursing care for lung cancer patients. Cancer. Sep. 15. 1989;64(6):1375-82. [pmid: 2670188].
146 Ritz LJ, Nissen MJ, Swenson KK, et al. Effects of advanced nursing care on quality of life and cost outcomes of women diagnosed with breast cancer. Oncol Nurs Forum. Jul. 2000;27(6):923-32. [pmid: 10920832].
147 Jennings-Sanders A, Anderson ET. Older women with breast cancer: perceptions of the effectiveness of nurse case managers. Nurs Outlook. May-Jun. 2003;51(3):108-14. [pmid: 12830102].
148 Jennings-Sanders A, Kuo YF, Anderson ET, et al. How do nurse case managers care for older women with breast cancer?. Oncol Nurs Forum. May. 2005;32(3):625-32. [pmid: 15897937].
149 Sorensen JL, Dilley J, London J, et al. Case management for substance abusers with HIV/AIDS: a randomized clinical trial. Am J Drug Alcohol Abuse. 2003;29(1):133-50. [pmid: 12731685].
150 Wohl AR, Garland WH, Valencia R, et al. A randomized trial of directly administered antiretroviral therapy and adherence case management intervention. Clin Infect Dis. Jun. 2006;42(11):1619-27. [pmid: 16652320].
151 Husbands W, Browne G, Caswell J, et al. Case management community care for people living with HIV/AIDS (PLHAs). AIDS Care. Sep. 2007;19(8):1065-72. [pmid: 17852006].
152 McCoy HV, Dodds S, Rivers JE, et al. Case management services for HIV-seropositive IDUs. NIDA Res Monogr. 1992;127:181-207. [pmid: 1435995].
153 Nickel JT, Salsberry PJ, Caswell RJ, et al. Quality of life in nurse case management of persons with AIDS receiving home care. Res Nurs Health. Apr. 1996;19(2):91-9. [pmid: 8606987].
154 Kushel MB, Colfax G, Ragland K, et al. Case management is associated with improved antiretroviral adherence and CD4+ cell counts in homeless and marginally housed individuals with HIV infection. Clin Infect Dis. Jul. 15. 2006;43(2):234-42. [pmid: 16779752].
155 Fleishman JA, Mor V, Piette J. AIDS case management: the client's perspective. Health Serv Res. Oct. 1991;26(4):447-70. [pmid: 1917501].
156 Pugh GL. Exploring HIV/AIDS case management and client quality of life. J HIV AIDS Soc Serv. 2009;8(2):202-18.
157 Andersen M, Hockman E, Smereck G, et al. Retaining women in HIV medical care. J Assoc Nurses AIDS Care. May-Jun. 2007;18(3):33-41. [pmid: 17570298].
158 Lehrman SE, Gentry D, Yurchak BB, et al. Outcomes of HIV/AIDS case management in New York. AIDS Care. Aug. 2001;13(4):481-92. [pmid: 11454269].
159 Bouey PD, Druan BE. The Ahalaya case-management program for HIV-infected American Indians, Alaska Natives, and Native Hawaiians: quantitative and qualitative evaluation of impacts. Am Indian Alsk Native Ment Health Res. 2000;9(2):36-52. [pmid: 11279557].
160 Nyamathi AM, Christiani A, Nahid P, et al. A randomized controlled trial of two treatment programs for homeless adults with latent tuberculosis infection. Int J Tuberc Lung Dis. Jul. 2006;10(7):775-82. [pmid: 16848340].
161 Nyamathi A, Stein JA, Schumann A, et al. Latent variable assessment of outcomes in a nurse-managed intervention to increase latent tuberculosis treatment completion in homeless adults. Health Psychol. Jan. 2007;26(1):68-76. [pmid: 17209699].
162 Hsieh CJ, Lin LC, Kuo BI, et al. Exploring the efficacy of a case management model using DOTS in the adherence of patients with pulmonary tuberculosis. J Clin Nurs. Apr. 2008;17(7):869-75. [pmid: 17850292].
163 Mangura B, Napolitano E, Passannante M, et al. Directly observed therapy (DOT) is not the entire answer: an operational cohort analysis. Int J Tuberc Lung Dis. Aug. 2002;6(8):654-61. [pmid: 12150475].
164 Lin RL, Lin FJ, Wu CL, et al. Effect of a hospital-based case management approach on treatment outcome of patients with tuberculosis. J Formos Med Assoc. Aug. 2006;105(8):636-44. [pmid: 16935764].
165 Sansom SL, Anthony MN, Garland WH, et al. The costs of HIV antiretroviral therapy adherence programs and impact on health care utilization. AIDS Patient Care STDs. 2008;22(2):131-8. [pmid: 18260804].
166 Ma J, Berra K, Haskell WL, et al. Case management to reduce risk of cardiovascular disease in a county health care system. Arch Intern Med. Nov. 2009;169(21):1988-95. [pmid: 19933961].
167 Berra K, Ma J, Klieman L, et al. Implementing cardiac risk-factor case management: lessons learned in a county health system. Crit Pathw Cardiol. Dec. 2007;6(4):173-9. [pmid: 18091408].
168 Ma J, Lee KV, Berra K, et al. Implementation of case management to reduce cardiovascular disease risk in the Stanford and San Mateo Heart to Heart randomized controlled trial: study protocol and baseline characteristics. Implement Sci. 2006;1:21. [pmid: 17005050].
169 Sadowski LS, Kee RA, VanderWeele TJ, et al. Effect of a housing and case management program on emergency department visits and hospitalizations among chronically ill homeless adults: a randomized trial. JAMA. May. 6. 2009;301(17):1771-8. [pmid: 19417194].
170 Rice KL, Dewan N, Bloomfield HE, et al. Disease management program for chronic obstructive pulmonary disease: a randomized controlled trial. Am J Respir Crit Care Med. Oct. 1. 2010;182(7):890-6. [pmid: 20075385].
171 Dewan NA, Rice KL, Caldwell M, et al. Economic evaluation of a disease management program for chronic obstructive pulmonary disease. COPD. Jun. 2011;8(3):153-9. [pmid: 21513435].
172 Bourbeau J, Julien M, Maltais F, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention. Arch Intern Med. Mar. 10. 2003;163(5):585-91. [pmid: 12622605].
173 Bourbeau J, Collet JP, Schwartzman K, et al. Economic benefits of self-management education in COPD. Chest. Dec. 2006;130(6):1704-11. [pmid: 17166985].
174 Chow SKY, Wong FK. Health-related quality of life in patients undergoing peritoneal dialysis: effects of a nurse-led case management programme. J Adv Nurs. 2010;66(8):1780-92. [pmid: 20557392].
175 Claiborne N. Efficiency of a care coordination model: a randomized study with stroke patients. Res Social Work Prac. 2006;16(1):57-66. [pmid: 16776026].
176 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. [pmid: 17903862].
177 Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient's personal physician on the outcome of stroke. Age Ageing. Jan. 2008;37(1):32-8. [pmid: 18006510].
178 Tatum WO, Al-Saadi S, Orth TL. Outpatient case management in low-income epilepsy patients. Epilepsy Res. Dec. 2008;82(2-3):156-61. [pmid: 18801643].
179 Wetta-Hall R. Impact of a collaborative community case management program on a low-income uninsured population in Sedgwick County, KS. App Nurs Res. 2007;20(4):188-94. [pmid: 17996805].
180 Shah R, Chen C, O'Rourke S, et al. Evaluation of care management for the uninsured. Med Care. Feb. 2011;49(2):166-71. [pmid: 21206292].
181 Okin RL, Boccellari A, Azocar F, et al. The effects of clinical case management on hospital service use among ED frequent users. Am J Emerg Med. Sep. 2000;18(5):603-8. [pmid: 10999578].
182 Jowers J, Corsello P, Shafer A, et al. Partnering specialist care with nurse case management: a pilot project for asthma. J Clin Outcomes Manage. 2000;7(5):17-22.
183 Poole PJ, Chase B, Frankel A, et al. Case management may reduce length of hospital stay in patients with recurrent admissions for chronic obstructive pulmonary disease. Respirology. Mar. 2001;6(1):37-42. [pmid: 11264761].
184 Wulff CN, Thygesen M, Sondergaard J, et al. Case management used to optimize cancer care pathways: a systematic review. BMC Health Serv Res. 2008;8:227. [pmid: 18986554].
185 McCorkle R, Strumpf NE, Nuamah IF, et al. A specialized home care intervention improves survival among older post-surgical cancer patients. J Am Geriatr Soc. Dec. 2000;48(12):1707-13. [pmid: 11129765].
186 Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database Syst Rev. Aug. 4. 2011;(8):CD007228. [pmid: 20687083].
187 Windham BG, Bennett RG, Gottlieb S. Care management interventions for older patients with congestive heart failure. Am J Manag Care. Jun. 2003;9(6):447-59. quiz 60-1. [pmid: 12816174].
188 Gohler A, Januzzi JL, Worrell SS, et al. A systematic meta-analysis of the efficacy and heterogeneity of disease management programs in congestive heart failure. J Card Fail. Sep. 2006;12(7):554-67. [pmid: 16952790].
189 Whellan DJ, Hasselblad V, Peterson E, et al. Metaanalysis and review of heart failure disease management randomized controlled clinical trials. Am Heart J. Apr. 2005;149(4):722-9. [pmid: 15990759].
190 Roccaforte R, Demers C, Baldassarre F, et al. Effectiveness of comprehensive disease management programmes in improving clinical outcomes in heart failure patients. A meta-analysis. Eur J Heart Fail. Dec. 2005;7(7):1133-44. [pmid: 16198629].
191 Yu DS, Thompson DR, Lee DT. Disease management programmes for older people with heart failure: crucial characteristics which improve post-discharge outcomes. Eur Heart J. Mar. 2006;27(5):596-612. [pmid: 16299021].
192 Jaana M, Paré G. Home telemonitoring of patients with diabetes: a systematic assessment of observed effects. J Eval Clin Pract. 2007;13(2):242-53. [pmid: 17378871].
193 Ingersoll S, Valente SM, Roper J, Larrabee JH. Using the best evidence to change practice. Nurse care coordination for diabetes: a literature review and synthesis. J Nurs Care Qual. 2005;20(3):208-14. [pmid: 15965384].
194 Norris S, Nichols P, Caspersen C, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. 2002;22:15-38. [pmid: 11985933].
195 Centers for Disease Control and Prevention. Strategies for reducing morbidity and mortality from diabetes through health-care system interventions and diabetes self-management education in community settings: a report on recommendations of the Task Force on Community Preventive Services. MMWR Recomm Rep. 2001;50(RR-16):1-16. [pmid: 11594724].
196 Nowak F, Nagle L, Bernardo A. Review: case management programmes improve patient outcomes (commentary on Ferguson JA, Weinberger M. Case management programs in primary care. J Gen Intern Med 1998 Feb;13:123-6). Evidence Based Nursing. October. 1. 1998. 1998;1(4):128.
197 Sutherland D, Hayter M. Structured review: evaluating the effectiveness of nurse case managers in improving health outcomes in three major chronic diseases. J Clin Nurs. 2009;18(21):2978-92. [pmid: 19747197].