# Peer Reviewers

Thomas Bodenheimer, M.D., M.P.H.

Adjunct Professor

University of California, San Francisco

RWJ Foundation

San Francisco, CA

Matthew Burke, M.D.

Senior Clinical Advisor

Health Resources and Services Administration

Rockville, MD

Neil Kirschner, Ph.D.

Senior Associate

Regulatory and Insurer Affairs

American College of Physicians

Washington, DC

Margaret Leonard, M.S., R.N.-B.C., FNP

President of the Board of Directors

Case Management Society of America

Niskayuna, NY

Pamela Mitchell, Ph.D., R.N.

Professor Emeritus

University of Washington School of Nursing

Seattle, WA

Cheryl Schraeder, Ph.D., R.N.

Clinical Associate Professor

University of Illinois at Chicago

Mahomet, IL

Hussein A Tahan, D.N.Sc., R.N.

Consultant

International Health Care Management & Consulting

Secaucus, NJ