# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodological approaches do not necessarily represent the views of individual technical and content experts.

Dena M. Bravata, M.D., M.S.

Affiliate and Investigator

Center for Health Policy, Stanford University

Stanford, CA

Charles Boult, M.D, M.P.H., M.B.A.

Professor, Johns Hopkins School of Public Health

Director, Lipitz Center for Integrated Health Care; the Eugene and Mildred Lipitz

Professor in Health Care Policy

Baltimore, MD

Kenneth S. Fink, M.D., M.G.A., M.P.H.

Division Administrator

Med-Quest Division, Hawaii State Medicaid

Kapolei, HI

Margaret Leonard, M.S., R.N.-B.C., FNP

President of the Board of Directors

Case Management Society of America

Niskayuna, NY

Kathryn M. McDonald, M.M.

Executive Director, Senior Scholar

Center for Health Policy, Stanford University

Stanford, CA

Hussein A. Tahan, D.N.Sc., R.N.

Consultant

International Health Care Management & Consulting

Secaucus, NJ

Edward H. Wagner, M.D., M.P.H., FACP

Director

Group Health Cooperative of Puget Sound

Senior Investigator of the MacColl Institute

Seattle, WA