# Key Informants

Charles Boult, M.D, M.P.H., M.B.A.

Professor, Johns Hopkins School of Public Health

Director, Lipitz Center for Integrated Health Care; the Eugene and Mildred Lipitz

Professor in Health Care Policy

Baltimore, MD

Kenneth S. Fink, M.D., M.G.A., M.P.H.

Division Administrator

Med-Quest Division, Hawaii State Medicaid

Kapolei, HI

David Labby, M.D.

Medical Director

Care Oregon

Portland, OR

Margaret Leonard, M.S., R.N.-B.C., F.N.P.

President of the Board of Directors

Case Management Society of America

Niskayuna, NY

Michael O'Dell, M.D., M.S.H.A., F.A.A.F.P.

Chair, Department of Family and Community Medicine

University of Missouri–Kansas City

Kansas City, MO

Lois Wessel, R.N., C.F.N.P.

Associate Director for Programs

Association of Clinicians for the Underserved

Tysons Corner, VA