# Conclusions

The main findings of this review are summarized in Table 17, below, and Appendix H provides details about how the estimates of the strength of the evidence were derived. Due to heterogeneity in the characteristics of case management (CM) interventions and the limitation of small sample sizes in many studies, the strength of evidence for the conclusions often is only low or moderate. This applies to statements about both positive effects and the lack of effect on outcomes. However, in some cases there were consistent findings in large clinical trials of uniform populations. In such cases, the evidence statements were assigned high strength of evidence ratings. Table 17 does not summarize outcomes for which there is insufficient evidence to draw a conclusion. For some patient populations there were few studies that examined certain outcomes. In other cases (such as results about hospitalization rates in people with diabetes), the findings were highly heterogeneous across the studies, leading to a conclusion that the evidence was insufficient.

Table 17 Summary evidence table: Outpatient case management for adults with medical illness and complex care needs

Key Question | Condition/Disease | Conclusion | Strength of Evidence
Key Question 1a: In adults with chronic medical illness and complex care needs, is case management effective in improving patient-centered outcomes, including mortality, quality of life, disease-specific health outcomes, avoidance of nursing home placement, and patient satisfaction with care? | Older adults with one or more chronic diseases | Mortality. CM programs that serve patients with one or more chronic diseases do not reduce overall mortality (9 studies). | High
Key Question 1a | Older adults with one or more chronic diseases | Functional status. CM programs that serve patients with one or more chronic diseases do not result in clinically important improvements in functional status (3 studies). | High
Key Question 1a | Frail elderly | Mortality. CM does not affect mortality in frail elders (5 studies). | Low
Key Question 1a | Frail elderly | Nursing home admissions. CM programs that serve frail elderly patients do not decrease nursing home admissions (2 studies). | Low
Key Question 1a | Dementia | Mortality. Patients with dementia who receive services from CM programs do not have lower mortality rates (12 studies). | High
Key Question 1a | Dementia | Problematic behavioral symptoms. CM programs that serve patients with dementia do not reduce problematic behavioral symptoms. | Moderate
Key Question 1a | Dementia | Caregiver depression and strain (burden). CM programs that serve patients with dementia do reduce depression and strain among caregivers (13 studies). | Moderate
Key Question 1a | Dementia | Time to nursing home placement. CM programs that serve patients with dementia and have duration of no longer than 2 years do not confer clinically important delays in time to nursing home placement (9 studies). | Moderate
Key Question 1a | Congestive heart failure | Mortality. CM programs that serve adults with CHF do not reduce mortality (6 studies). | Low
Key Question 1a | Congestive heart failure | Patient satisfaction. CM programs that serve patients with CHF do increase patient satisfaction (3 studies). | Moderate
Key Question 1a | Congestive heart failure | Quality of life. CM programs that serve patients with CHF do improve CHF-related quality of life (6 studies). | Low
Key Question 1a | Diabetes mellitus | Glucose management. CM programs that serve adults with diabetes do improve glucose management (12 studies). | Moderate
Key Question 1a | Diabetes mellitus | Lipids, BMI/weight. CM programs that serve adults with diabetes do not improve measures of lipid management or BMI/weight. (8 studies). | Moderate
Key Question 1a | Diabetes mellitus | Mortality. CM programs that serve adults with diabetes do not reduce mortality (1 study). | Low
Key Question 1a | Diabetes mellitus | Glucose control. CM improves glucose control among adults with diabetes. | Low
Key Question 1a | Cancer | Satisfaction with care. CM programs that serve patients with cancer do improve satisfaction with care (4 studies). | Moderate
Key Question 1a | Cancer | Cancer-related symptoms, functioning, quality of life, survival. CM does improve selected cancer-related symptoms and functioning (physical, psychosocial, and emotional) but not overall quality of life or survival (8 studies). | Low
Key Question 1a | HIV | Mortality. CM programs that serve adults with HIV infection do not improve survival (2 studies). | Low
Key Question 1b: In adults with chronic medical illness and complex care needs, is case management effective in improving quality of care, as indicated by disease-specific process measures, receipt of recommended health care services, adherence to therapy, missed appointments, patient self-management, and changes in health behavior? | Older adults with one or more chronic diseases | Patient perception of care coordination. CM programs that serve patients with one or more chronic diseases do increase patients' perceptions of the coordination of their care (2 studies). | High
Key Question 1b | Dementia | Clinical guideline adherence. CM programs that focus on clinical guideline measures for care of dementia do increase adherence to those measures (1 study). | Low
Key Question 1b | Congestive heart failure | Self-management behaviors. CM does increase patients' adherence to self-management behaviors recommended for patients with CHF (3 studies). | Moderate
Key Question 1b | Cancer | Appropriate treatment. CM programs that serve patients with cancer do increase the receipt of appropriate (i.e., guideline-recommended) cancer treatment (2 studies). | Moderate
Key Question 1b | Tuberculosis | Treatment success. Short-term CM programs that emphasize medication adherence do improve rates of successful treatment for tuberculosis in vulnerable populations (4 studies). | Moderate
Key Question 1c: In adults with chronic medical illness and complex care needs, is case management effective in improving resource utilization, including overall financial cost, hospitalization rates, days in the hospital, emergency department use, and number of clinic visits (including primary care and other provider visits)? | Older adults with one or more chronic diseases | Medicare expenditures. CM programs that serve patients with one or more chronic diseases do not reduce Medicare expenditures (3 studies). | High
Key Question 1c | Older adults with one or more chronic diseases | Hospitalization rates. CM programs that serve patients with one or more chronic diseases do not reduce overall rates of hospitalization (17 studies). | Moderate
Key Question 1c | Frail elderly | Hospitalization rates. CM does not decrease acute hospitalizations in the frail elderly (11 studies). | Low
Key Question 1c | Dementia | Health care expenditures. CM does not change total health care expenditures for patients with dementia (6 studies). | Moderate
Key Question 1c | Diabetes | Hospital readmission rates. CM does not reduce hospitalization rates among adults with diabetes. | Low
Key Question 1c | Cancer | Health care expenditures. CM programs that serve patients with cancer do not affect overall health care utilization and cost of care (5 studies). | Low
Key Question 1c | Other medical problems | Emergency department visits. CM programs that serve populations that have chronic obstructive pulmonary disease (COPD) or are homeless do reduce emergency department visits (3 studies). | Low
Key Question 2: Does the effectiveness of case management differ according to patient characteristics, including but not limited to: particular medical conditions, number or type of comorbidities, patient age and socioeconomic status, social support, and/or level of formally assessed health risk? | Older adults with one or more chronic diseases | Disease burden. CM programs that serve patients with one or more chronic diseases are more effective for reducing hospitalization rates among patients with greater disease burden (2 studies). | Low
Key Question 3: Does the effectiveness of case management differ according to intervention characteristics, including but not limited to: practice or health care system setting; case manager experience, training, or skills; case management intensity, duration, and integration with other care providers; and the specific functions performed by case managers? | Older adults with one or more chronic diseases | Personal contact. CM programs that serve patients with one or more chronic diseases are more effective for preventing hospitalizations when case managers have greater personal contact with patients and physicians (4 studies). | Low
Key Question 3 | Dementia | Duration. CM programs that serve patients with dementia who have in-home spouse caregivers and continue services for longer than 2 years are more effective for delaying nursing home placement than programs providing services for 2 years or less (1 study). | Low
Key Question 3 | Congestive heart failure | Integration with multidisciplinary team. CM is more effective in improving outcomes among CHF patients when case managers are part of a multidisciplinary team of health care providers. | Low
Key Question 3 | Cancer | Intensity, integration, training, protocols. CM programs that serve patients with cancer are more effective when the CM is more intensive, better integrated with patients' usual care providers, and employs preintervention training and care protocols (3 studies). | Low

CM = case management; BMI = body mass index; CHF = congestive heart failure; COPD = chronic obstructive pulmonary disease

Note: this table does not include statements for which the evidence was insufficient to draw a conclusion.

The cumulative evidence about CM is sufficient to draw several conclusions that apply to specific patient populations. Because CM programs generally are customized to the patient groups served, it usually is not possible to apply the results to other patient populations. In this review, we found that, on balance, CM had limited impact on patient-centered outcomes, quality of care, and resource utilization among patients with chronic medical illness. The most positive findings are that CM improves the quality of care, particularly for patients with serious illnesses that require complex treatments (cancer and tuberculosis). For a variety of medical conditions, CM improves medication adherence and self-management skills. CM also improves quality of life (QOL) in some populations (congestive heart failure [CHF] and cancer) and tends to improve satisfaction with care. For the caregivers of patients with dementia, targeted CM programs improve levels of stress, burden, and depression.

The available evidence has not demonstrated that CM programs decrease resource utilization and lead to resultant cost savings. For general populations of patients who receive CM for chronic diseases, there is a high strength of evidence that the programs do not reduce Medicare expenditures. However, the impact of CM may have beengreatest when the CM was targeted towards patients with the highest previous levels of health care utilization. The implication of this finding is that those with the greatest need for assistance with clinical management and care coordination, patients with low levels of social support, and/or patients at highest risk for poor outcomes might be more likely to benefit from CM. CM may be best suited for only the highest risk patients, who are most likely to benefit from high intensity engagement that addresses a wide variety of needs. It may have more limited impact for patients with more focused (less complex) care needs. While the effectiveness of CM may depend on selection of the appropriate target population, the published studies suggest that this type of careful case selection is difficult to implement.

The results of trials across different clinical conditions suggested that CM effectiveness was greater when the intervention was more prolonged, included more patient contact, and included face-to-face (rather than telephone only) interactions. This finding validates the premise that the relationship between case manager and patient is likely to be a key ingredient for successful CM interventions. CM also appears to be most effective when the case manager works closely with patients' usual care providers (usually primary care physicians) and/or collaborates with a physician (or multidisciplinary team of health care providers) with expertise in managing the targeted medical condition. This finding suggests that CM may be most effective when case managers are embedded within a collaborative, team-based intervention model. Finally, there also is some evidence that CM is successful in achieving outcomes when the intervention includes specific training modules and protocols that are tailored towards those outcomes. This suggests that the breadth and flexibility of CM may need to be complemented by focused efforts—including specific training, guidelines, and protocols—to achieve explicitly targeted outcomes.

## Consistency With Previous Systematic Reviews

We identified no prior systematic reviews that evaluated studies of CM across multiple disease categories, and most prior systematic reviews used definitions of CM that differed from that used in this review. One recent systematic review of CM among patients with cancer used a CM definition and study inclusion criteria similar to ours.184 That review focused on whether CM optimizes cancer care pathways. Of the seven studies included in that systematic review, six were included in our review. We excluded one study that was included in that review because it was a short-term intervention (4 weeks) intended to manage patients in the postoperative period after cancer surgery.185 The authors of the prior systematic review concluded that the heterogeneity of CM studies made it impossible to comment on the effectiveness of CM in cancer care.184 They also concluded that the poor specification around CM implementation (i.e., the “black box” nature of CM studies) precluded an analysis of effective elements of CM.

Other prior systematic reviews evaluated interventions that include some components of the CM models examined in this report. These prior reviews evaluated community-based interventions for CHF and diabetes. A recent Cochrane Collaboration review examined interventions including structured telephone support and telemonitoring for patients with CHF.186 While that review included some of the studies in our review that involved a telephone care component, the majority of the studies did not involve CM. Five other reviews examined “care management”187 and “disease management”188-191 interventions for patients with CHF. While these reviews included many of the studies included in our review, they also included other studies of primarily nurse-led interventions that did not meet our criteria for being considered CM. There was significant heterogeneity in the nature and duration of the interventions examined in these reviews. Nevertheless, meta-analysis demonstrated a significant reduction in hospitalization rates with disease management in three of the reviews188-190 and a reduction in all-cause mortality in two reviews.188, 190 All of these reviews included largely the same group of individual studies. Gohler et al. also conducted a meta-regression of 36 disease management studies and found that rehospitalization rates were significantly lower in interventions that involved multidisciplinary teams and in those that included face-to-face contact with patients, as opposed to telephone contact alone.188 Windham et al. conducted a qualitative analysis of differences in outcomes among studies of care management for CHF.187 They found that 15 of 32 studies demonstrated improved outcomes with care management and 15 showed nonsignificant trends towards improvement. Common elements observed in successful interventions included more frequent clinical monitoring, collaboration between a physician and nurse in delivering the intervention, and patient education in self-management skills.187 Yu et al. similarly reviewed 21 clinical trials of CHF disease management interventions and compared and contrasted “effective” and “ineffective” interventions. They found that effective interventions were characterized by: an in-hospital phase of care, intensive patient education, self-care support, optimization of medical regimens, and ongoing surveillance and management of clinical deterioration.191

In considering the potential impact of CM on care for patients with diabetes, there have been six systematic reviews of related interventions.192-197 All used substantially different definitions of CM than was used in this report.