# Appendix References

1 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
2 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259].
3 U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. July. 2008. http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.
4 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. [pmid: 17903862].
5 Applebaum R, Straker J, Mehdizadeh S, et al. Using high-intensity care management to integrate acute and long-term care services: substitute for large scale system reform?. Care Manag J. Spring. 2002;3(3):113-9. [pmid: 12632877].
6 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. Feb. 2009;36(1):113-26. [pmid: 19188371].
7 Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. May. 1998;316(7141):1348-51. [pmid: 9563983].
8 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. Mar. 14. 2011;171(5):460-6. [pmid: 21403043].
9 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of guided care on family caregivers. Gerontologist. Aug. 2010;50(4):459-70. [pmid: 19710354].
10 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. Mar. 2008;63(3):321-7. [pmid: 18375882].
11 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. Mar. 2010;25(3):235-42. [pmid: 20033622].
12 Bourbeau J, Julien M, Maltais F, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention. Arch Intern Med. Mar. 10. 2003;163(5):585-91. [pmid: 12622605].
13 Bourbeau J, Collet JP, Schwartzman K, et al. Economic benefits of self-management education in COPD. Chest. Dec. 2006;130(6):1704-11. [pmid: 17166985].
14 Brown SA, Garcia AA, Winter M, et al. Integrating education, group support, and case management for diabetic. Hispanics Ethn Dis. 2011;21(1):20-6. [pmid: 21462725].
15 California Medi-Cal Type 2 Diabetes Study Group. Closing the gap: effect of diabetes case management on glycemic control among low-income ethnic minority populations: the California Medi-Cal type 2 diabetes study. Diabetes Care. Jan. 2004;27(1):95-103. [pmid: 14693973].
16 Pettitt DJ, Okada Wollitzer A, Jovanovic L, et al. Decreasing the risk of diabetic retinopathy in a study of case management: the California Medi-Cal Type 2 Diabetes Study. Diabetes Care. Dec. 2005;28(12):2819-22. [pmid: 16306539].
17 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May. 10. 2006. 2006;295(18):2148-57. [pmid: 16684985].
18 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. 2008;59(4). [pmid: 18378844].
19 Chow SKY, Wong FK. Health-related quality of life in patients undergoing peritoneal dialysis: effects of a nurse-led case management programme. J Adv Nurs. 2010;66(8):1780-92. [pmid: 20557392].
20 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early stage Alzheimer's patients and their families. Am J Alzheimers Dis. 2000;15(5):284-90.
21 Claiborne N. Efficiency of a care coordination model: a randomized study with stroke patients. Res Social Work Prac. 2006;16(1):57-66. [pmid: 16776026].
22 Clark P, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging Ment Health. 2004;8(1):40-51. [pmid: 14690867].
23 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2004 Oct 19;141(8):I58; PMID: 15492334]. Ann Intern Med. Oct. 19. 2004;141(8):606-13. [pmid: 15492340].
24 Eggert GM, Zimmer JG, Hall WJ, et al. Case management: a randomized controlled study comparing a neighborhood team and a centralized individual model. Health Serv Res. Oct. 1991;26(4):471-507. [pmid: 1917502].
25 Zimmer JG, Eggert GM, Chiverton P. Individual versus team case management in optimizing community care for chronically ill patients with dementia. J Aging Health. Aug. 1990;2(3):357-72. [pmid: 10170566].
26 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: A randomized trial. J Am Geriatr Soc. 2001;49(10):1282-7. [pmid: 11890485].
27 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200-8. [pmid: 20121986].
28 Engelhardt JB, McClive-Reed KP, Toseland RW, et al. Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care. Feb. 2006;12(2):93-100. [pmid: 16464138].
29 Fan VS, Gaziano JM, Lew R, et al. A comprehensive care management program to prevent chronic obstructive pulmonary disease hospitalizations: a randomized, controlled trial. Ann Intern Med. May. 15. 2012;156(10):673-83. [pmid: 22586006].
30 Fitzgerald JF, Smith DM, Martin DK, et al. A case manager intervention to reduce readmissions. Arch Intern Med. Aug. 8. 1994;154(15):1721-9. [pmid: 8042889].
31 Gagnon AJ, Schein C, McVey L, et al. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. Sep. 1999;47(9):1118-24. [pmid: 10484257].
32 Schein C, Gagnon AJ, Chan L, et al. The association between specific nurse case management interventions and elder health. J Am Geriatr Soc. Apr. 2005;53(4):597-602. [pmid: 15817004].
33 Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med. Jul. 2003;37(1):23-32. [pmid: 12799126].
34 Gary TL, Batts-Turner M, Bone LR, et al. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Feb. 2004;25(1):53-66. [pmid: 14980748].
35 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educ. 2005;31(6):880-9. [pmid: 16288095].
36 Gary TL, Batts-Turner M, Yeh HC, et al. The effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. Oct. 2009;169(19):1788-94. [pmid: 19858437].
37 Goodwin JS, Satish S, Anderson ET, et al. Effect of nurse case management on the treatment of older women with breast cancer. J Am Geriatr Soc. Sep. 2003;51(9):1252-9. [pmid: 12919237].
38 Jennings-Sanders A, Anderson ET. Older women with breast cancer: perceptions of the effectiveness of nurse case managers. Nurs Outlook. May-Jun. 2003;51(3):108-14. [pmid: 12830102].
39 Jennings-Sanders A, Kuo YF, Anderson ET, et al. How do nurse case managers care for older women with breast cancer?. Oncol Nurs Forum. May. 2005;32(3):625-32. [pmid: 15897937].
40 Hsieh CJ, Lin LC, Kuo BI, et al. Exploring the efficacy of a case management model using DOTS in the adherence of patients with pulmonary tuberculosis. J Clin Nurs. Apr. 2008;17(7):869-75. [pmid: 17850292].
41 Husbands W, Browne G, Caswell J, et al. Case management community care for people living with HIV/AIDS (PLHAs). AIDS Care. Sep. 2007;19(8):1065-72. [pmid: 17852006].
42 Ishani A, Greer N, Taylor BC, et al. Effect of nurse case management compared with usual care on controlling cardiovascular risk factors in patients with diabetes: a randomized controlled trial. Diabetes Care. Aug. 2011;34(8):1689-94. [pmid: 21636796].
43 Jaarsma T, van der Wal MH, Lesman-Leegte I, et al. Effect of moderate or intensive disease management program on outcome in patients with heart failure: Coordinating Study Evaluating Outcomes of Advising and Counseling in Heart Failure (COACH). Arch Intern Med. Feb. 11. 2008;168(3):316-24. [pmid: 18268174].
44 Jansen A, van Hout H, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. 2011;48(8):933-43. [pmid: 21356537].
45 Jansen AP, van Hout HP, van Marwijk HW, et al. (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. [pmid: 16343336].
46 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. [pmid: 11823086].
47 Krein SL, Klamerus ML, Vijan S, et al. Case management for patients with poorly controlled diabetes: a randomized trial. Am J Med. Jun. 1. 2004;116(11):732-9. [pmid: 15144909].
48 Kristensson J, Ekwall AK, Jakobsson U, et al. Case managers for frail older people: a randomised controlled pilot study. Scand J Caring Sci. Dec. 2010;24(4):755-63. [pmid: 20409057].
49 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. Apr. 2010;25(4):395-402. [pmid: 19606455].
50 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 2003;163(7):809-17. [pmid: 12695272].
51 Latour CH, de Vos R, Huyse FJ, et al. Effectiveness of post-discharge case management in general-medical outpatients: a randomized, controlled trial. Psychosomatics. Sep-Oct. 2006;47(5):421-9. [pmid: 16959931].
52 Latour CH, van der Windt DA, de Jonge P, et al. Nurse-led case management for ambulatory complex patients in general health care: a systematic review. J Psychosom Res. Mar. 2007;62(3):385-95. [pmid: 17324690].
53 Leung AC, Yau DC, Liu CP, et al. Reducing utilisation of hospital services by case management: a randomised controlled trial. Aust Health Rev. 2004;28(1):79-86. [pmid: 15525254].
54 Leung AT, Liu CP, Chow NS, et al. Cost-benefit analysis of a case management project for the community-dwelling frail elderly in Hong Kong. J Appl Gerontol. 2004;23(1):70-85.
55 Ma J, Berra K, Haskell WL, et al. Case management to reduce risk of cardiovascular disease in a county health care system. Arch Intern Med. Nov. 2009;169(21):1988-95. [pmid: 19933961].
56 Berra K, Ma J, Klieman L, et al. Implementing cardiac risk-factor case management: lessons learned in a county health system. Crit Pathw Cardiol. Dec. 2007;6(4):173-9. [pmid: 18091408].
57 Ma J, Lee KV, Berra K, et al. Implementation of case management to reduce cardiovascular disease risk in the Stanford and San Mateo Heart to Heart randomized controlled trial: study protocol and baseline characteristics. Implement Sci. 2006;1:21. [pmid: 17005050].
58 Marshall BS, Long MJ, Voss J, et al. Case management of the elderly in a health maintenance organization: the implications for program administration under managed care. J Healthc Manag. Nov-Dec. 1999;44(6):477-91. discussion 92-3. [pmid: 10662433].
59 Long MJ, Marshall BS. What price an additional day of life? A cost-effectiveness study of case management. Am J Manag Care. Aug. 2000;6(8):881-6. [pmid: 11186500].
60 Long MJ. Case management model or case manager type? That is the question. Health Care Manager. Jun. 2002;20(4):53-65. [pmid: 12083179].
61 Martin DC, Berger ML, Anstatt DT, et al. A randomized controlled open trial of population-based disease and case management in a Medicare Plus Choice health maintenance organization. Prev Chronic Dis. Oct. 2004;1(4):A05. [pmid: 15670436].
62 Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient's personal physician on the outcome of stroke. Age Ageing. Jan. 2008;37(1):32-8. [pmid: 18006510].
63 McCorkle R, Benoliel JQ, Donaldson G, et al. A randomized clinical trial of home nursing care for lung cancer patients. Cancer. Sep. 15. 1989;64(6):1375-82. [pmid: 2670188].
64 McCoy HV, Dodds S, Rivers JE, et al. Case management services for HIV-seropositive IDUs NIDA. Res Monogr. 1992;127:181-207. [pmid: 1435995].
65 Mittelman MS, Haley WE, Clay OJ, et al. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. 2006;67(9):1592-9. [pmid: 17101889].
66 Mittelman M, Roth D, Coon D, et al. Sustained benefit of supportive intervention for depressive symptoms in Alzheimer's caregivers. Am J Psychiatry. 2004;161:850-6. [pmid: 15121650].
67 Mittelman M, Roth D, Haley W, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems inpatients with Alzheimer's Disease: Results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. 2004;59(1):27-34. [pmid: 14722336].
68 Roth DL, Mittelman MS, Clay OJ, et al. Changes in social support as mediators of the impact of a psychosocial intervention for spouse caregivers of persons with Alzheimer's disease. Psychol Aging. Dec. 2005;20(4):634-44. [pmid: 16420138].
69 Mittelman MS, Brodaty H, Wallen AS, et al. A Three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: Effects on caregiver depression. Am J Geriatr Psychiatry. 2008;16(11):893-904. [pmid: 18978250].
70 Brodaty H, Mittelman M, Gibson L, et al. The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. Sep. 2009;17(9):734-43. [pmid: 19705519].
71 Moore S, Corner J, Haviland J, et al. Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. BMJ. Nov. 16. 2002;325(7373):1145. [pmid: 12433764].
72 Mor V, Wool M, Guadagnoli E, et al. The impact of short term case management on cancer patients' concrete needs and quality of life. Advances in Medical Sociology. 1995;6:269-94.
73 Newcomer R, Yordi C, DuNah R, et al. Effects of the Medicare Alzheimer's Disease Demonstration on caregiver burden and depression. Health Serv Res. Aug. 1999;34(3):669-89. [pmid: 10445897].
74 Newcomer R, Miller R, Clay T, et al. Effects of the Medicare Alzheimer's Disease Demonstration on Medicare expenditures. Health Care Financ Rev. 1999;20(4):45-65. [pmid: 11482124].
75 Newcomer R, Spitalny M, Fox P, et al. Effects of the Medicare Alzheimer's Disease Demonstration on the use of community-based services. Health Serv Res. Aug. 1999;34(3):645-67. [pmid: 10445896].
76 Miller R, Newcomer R, Fox P. Effects of the Medicare Alzheimer's Disease Demonstration on nursing home entry. Health Serv Res. Aug. 1999;34(3):691-714. [pmid: 10445898].
77 Shelton P, Schraeder C, Dworak D, et al. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc. Dec. 2001;49(12):1600-5. [pmid: 11843991].
78 Newcomer R, Maravilla V, Faculjak P, et al. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. Dec. 2004;27(4):323-48. [pmid: 15492046].
79 Nickel JT, Salsberry PJ, Caswell RJ, et al. Quality of life in nurse case management of persons with AIDS receiving home care. Res Nurs Health. Apr. 1996;19(2):91-9. [pmid: 8606987].
80 Nyamathi AM, Christiani A, Nahid P, et al. A randomized controlled trial of two treatment programs for homeless adults with latent tuberculosis infection. Int J Tuberc Lung Dis. Jul. 2006;10(7):775-82. [pmid: 16848340].
81 Nyamathi A, Stein JA, Schumann A, et al. Latent variable assessment of outcomes in a nurse-managed intervention to increase latent tuberculosis treatment completion in homeless adults. Health Psychol. Jan. 2007;26(1):68-76. [pmid: 17209699].
82 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries. JAMA. February. 11. 2009. 2009;301(6):603-18. [pmid: 19211468].
83 Oliva NL. A closer look at nurse case management of community-dwelling older adults: observations from a longitudinal study of care coordination in the chronically ill. Prof Case Manag. Mar-Apr. 2010;15(2):90-100. [pmid: 20234292].
84 Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. [pmid: 20478035].
85 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. MEDSURG Nursing. 2001;10(2):71-8.
86 Rice KL, Dewan N, Bloomfield HE, et al. Disease management program for chronic obstructive pulmonary disease: a randomized controlled trial. Am J Respir Crit Care Med. Oct. 1. 2010;182(7):890-6. [pmid: 20075385].
87 Dewan NA, Rice KL, Caldwell M, et al. Economic evaluation of a disease management program for chronic obstructive pulmonary disease. COPD. Jun. 2011;8(3):153-9. [pmid: 21513435].
88 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. [pmid: 8289096].
89 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. [pmid: 7565975].
90 Riegel B, Carlson B, Glaser D, et al. Standardized telephonic case management in a Hispanic heart failure population: an effective intervention. Dis Manage Health Out. 2002;10(4):241.
91 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. [pmid: 16624687].
92 Ritz LJ, Nissen MJ, Swenson KK, et al. Effects of advanced nursing care on quality of life and cost outcomes of women diagnosed with breast cancer. Oncol Nurs Forum. Jul. 2000;27(6):923-32. [pmid: 10920832].
93 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. [pmid: 17302651].
94 Sadowski LS, Kee RA, VanderWeele TJ, et al. Effect of a housing and case management program on emergency department visits and hospitalizations among chronically ill homeless adults: a randomized trial. JAMA. May. 6. 2009;301(17):1771-8. [pmid: 19417194].
95 Schore JL, Brown RS, Cheh VA. Case management for high-cost Medicare beneficiaries. Health Care Financ Rev. Summer. 1999;20(4):87-101. [pmid: 11482127].
96 Schore J, Brown R, Cheh V, et al. Costs and Consequences of Case Management for Medicare Beneficiaries. Report prepared for the Health Care Financing Administration. Princeton (NJ). Mathematica Policy Research, Inc. 1997.
97 Schore J, Peikes D, Peterson G, et al. Fourth Report to Congress on the Evaluation of the Medicare Coordinated Care Demonstration. Mathematica Reference Number: 6555-440. (Prepared by Mathematica Policy Research, Inc. under contract number HHSM-500-2005-00025I (0012)). Baltimore, MD. Centers for Medicare & Medicaid Services. March. 2011.
98 Shea S, Starren J, Weinstock RS, et al. Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) Project: rationale and design. J Am Med Inform Assoc. Jan-Feb. 2002;9(1):49-62. [pmid: 11751803].
99 Shea S, IDEATel Consortium. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
100 Shea S, Weinstock RS, Teresi JA, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus: 5 year results of the IDEATel study. J Am Med Inform Assoc. Jul-Aug. 2009;16(4):446-56. [pmid: 19390093].
101 Palmas W, Shea S, Starren J, et al. Medicare payments, healthcare service use, and telemedicine implementation costs in a randomized trial comparing telemedicine case management with usual care in medically underserved participants with diabetes mellitus (IDEATel). J Am Med Inform Assoc. Mar-Apr. 2010;17(2):196-202. [pmid: 20190064].
102 Trief PM, Morin PC, Izquierdo R, et al. Depression and glycemic control in elderly ethnically diverse patients with diabetes: the IDEATel project. Diabetes Care. Apr. 2006;29(4):830-5. [pmid: 16567823].
103 Trief PM, Teresi JA, Izquierdo R, et al. Psychosocial outcomes of telemedicine case management for elderly patients with diabetes: the randomized IDEATel trial. Diabetes Care. May. 2007;30(5):1266-8. [pmid: 17325261].
104 Izquierdo R, Meyer S, Starren J, et al. Detection and remediation of medically urgent situations using telemedicine case management for older patients with diabetes mellitus. Ther Clin Risk Manag. Jun. 2007;3(3):485-9. [pmid: 18488079].
105 Sisk JE, Hebert PL, Horowitz CR, et al. Improving patient care. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. 2006;145(4):273. [pmid: 16908918].
106 Sorensen JL, Dilley J, London J, et al. Case management for substance abusers with HIV/AIDS: a randomized clinical trial. Am J Drug Alcohol Abuse. 2003;29(1):133-50. [pmid: 12731685].
107 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care. Ann Intern Med. November. 21. 2006. 2006;145(10):713-26. [pmid: 17116916].
108 Duru OK, Ettner SL, Vassar SD, et al. Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. 2009;15(8):521-8. [pmid: 19670955].
109 Wohl AR, Garland WH, Valencia R, et al. A randomized trial of directly administered antiretroviral therapy and adherence case management intervention. Clin Infect Dis. Jun. 2006;42(11):1619-27. [pmid: 16652320].
110 Sansom SL, Anthony MN, Garland WH, et al. The costs of HIV antiretroviral therapy adherence programs and impact on health care utilization. AIDS Patient Care STDs. 2008;22(2):131-8. [pmid: 18260804].
111 Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27(7):1570-6. [pmid: 15220230].
112 Wolf AM, Siadaty M, Yaeger B, et al. Effects of lifestyle intervention on health care costs: Improving Control with Activity and Nutrition (ICAN). J Am Diet Assoc. Aug. 2007;107(8):1365-73. [pmid: 17659904].
113 Andersen M, Hockman E, Smereck G, et al. Retaining women in HIV medical care. J Assoc Nurses AIDS Care. May-Jun. 2007;18(3):33-41. [pmid: 17570298].
114 Bird SR, Kurowski W, Dickman GK, et al. Integrated care facilitation for older patients with complex health care needs reduces hospital demand. Aust Health Rev. Aug. 2007;31(3):451-61. discussion 49-50. [pmid: 17669069].
115 Bird S, Noronha M, Sinnott H. An integrated care facilitation model improves quality of life and reduces use of hospital resources by patients with chronic obstructive pulmonary disease and chronic heart failure. Aust J Prim Health. 2010;16(4):326-33. [pmid: 21138701].
116 Bouey PD, Druan BE. The Ahalaya case-management program for HIV-infected American Indians, Alaska Natives, and Native Hawaiians: quantitative and qualitative evaluation of impacts. Am Indian Alsk Native Ment Health Res. 2000;9(2):36-52. [pmid: 11279557].
117 Challis D, von Abendorff R, Brown P, et al. Care management, dementia care and specialist mental health services: an evaluation. Int J Geriatr Psychiatry. Apr. 2002;17(4):315-25. [pmid: 11994884].
118 Chi YC, Chuang KY, Wu SC, et al. The assessment of a hospital-based care management model for long-term care services. J Nurs Res. Dec. 2004;12(4):317-26. [pmid: 15619182].
119 Creason H. Congestive heart failure telemanagement clinic. Lippincotts Case Manag. Jul-Aug. 2001;6(4):146-56. [pmid: 16398064].
120 Curtis J, Lipke S, Effland S, et al. Effectiveness and safety of medication adjustments by nurse case managers to control hyperglycemia. Diabetes Educ. Sep-Oct. 2009;35(5):851-6. [pmid: 19713556].
121 Dorr DA, Wilcox A, Donnelly SM, et al. Impact of generalist care managers on patients with diabetes. Health Serv Res. Oct. 2005;40(5 Pt 1):1400-21. [pmid: 16174140].
122 Dorr DA, Wilcox A, Jones S, et al. Care management dosage. J Gen Intern Med. Jun. 2007;22(6):736-41. [pmid: 17415620].
123 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. Dec. 2008;56(12):2195-202. [pmid: 19093919].
124 Duke C. The frail elderly community-based case management project. Geriatric Nursing. Mar-Apr. 2005;26(2):122-7. [pmid: 15824728].
125 Fleishman JA, Mor V, Piette J. AIDS case management: the client's perspective. Health Serv Res. Oct. 1991;26(4):447-70. [pmid: 1917501].
126 Fletcher K, Mant J. A before and after study of the impact of Specialist Workers for Older People. J Eval Clin Pract. Apr. 2009;15(2):335-40. [pmid: 19335494].
127 Gravelle H, Dusheiko M, Sheaff R, et al. Impact of case management (Evercare) on frail elderly patients: controlled before and after analysis of quantitative outcome data. BMJ. Jan. 6. 2007;334(7583):31. [pmid: 17107984].
128 Hammer BJ. Community-based case management for positive outcomes. Geriatr Nurs. Sep-Oct. 2001;22(5):271-5. [pmid: 11606909].
129 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. Aug. 2003;49:992-7. [pmid: 12943358].
130 Huws DW, Cashmore D, Newcombe RG, et al. Impact of case management by advanced practice nurses in primary care on unplanned hospital admissions: a controlled intervention study. BMC Health Serv Res. 2008;8:115. [pmid: 18510730].
131 Jowers J, Corsello P, Shafer A, et al. Partnering specialist care with nurse case management: a pilot project for asthma. J Clin Outcomes Manage. 2000;7(5):17-22.
132 Keating P, Sealy A, Dempsey L, et al. Reducing unplanned hospital admissions and hospital bed days in the over 65 age group: results from a pilot study. Journal of Integrated Care. 2008;16(1):3-8.
133 Kruse RL, Zweig SC, Nikodim B, et al. Nurse care coordination of older patients in an academic family medicine clinic: 5-year outcomes. Journal of Clinical Outcomes Management. 2010;17(5):209-15.
134 Kushel MB, Colfax G, Ragland K, et al. Case management is associated with improved antiretroviral adherence and CD4+ cell counts in homeless and marginally housed individuals with HIV infection. Clin Infect Dis. Jul. 15. 2006;43(2):234-42. [pmid: 16779752].
135 Lehrman SE, Gentry D, Yurchak BB, et al. Outcomes of HIV/AIDS case management in New York. AIDS Care. Aug. 2001;13(4):481-92. [pmid: 11454269].
136 Lin RL, Lin FJ, Wu CL, et al. Effect of a hospital-based case management approach on treatment outcome of patients with tuberculosis. J Formos Med Assoc. Aug. 2006;105(8):636-44. [pmid: 16935764].
137 Lu KY, Lin PL, Tzeng LC, et al. Effectiveness of case management for community elderly with hypertension, diabetes mellitus, and hypercholesterolemia in Taiwan: a record review. Int J Nurs Stud. Nov. 2006;43(8):1001-10. [pmid: 16384558].
138 Luzinski CH, Stockbridge E, Craighead J, et al. The community case management program: for 12 years, caring at its best. Geriatr Nurs. May-Jun. 2008;29(3):207-15. [pmid: 18555162].
139 Mangura B, Napolitano E, Passannante M, et al. Directly observed therapy (DOT) is not the entire answer: an operational cohort analysis. Int J Tuberc Lung Dis. Aug. 2002;6(8):654-61. [pmid: 12150475].
140 Morales-Asencio JM, Gonzalo-Jimenez E, Martin-Santos FJ, et al. Effectiveness of a nurse-led case management home care model in Primary Health Care. A quasi-experimental, controlled, multi-centre study. BMC Health Serv Res. 2008;8:193. [pmid: 18811927].
141 Moran G, Coleman V, Heaney S, et al. An alternative model for case management in Flintshire. Br J Community Nurs. May. 2008;13(5):227-31. [pmid: 18771186].
142 Okin RL, Boccellari A, Azocar F, et al. The effects of clinical case management on hospital service use among ED frequent users. Am J Emerg Med. Sep. 2000;18(5):603-8. [pmid: 10999578].
143 Onder G, Liperoti R, Soldato M, et al. Case management and risk of nursing home admission for older adults in home care: results of the AgeD in HOme Care Study. J Am Geriatr Soc. Mar. 2007;55(3):439-44. [pmid: 17341249].
144 Onder G, Liperoti R, Bernabei R, et al. Case management, preventive strategies, and caregiver attitudes among older adults in home care: results of the ADHOC study. J Am Med Dir Assoc. Jun. 2008;9(5):337-41. [pmid: 18519115].
145 Picariello G, Hanson C, Futterman R, et al. Impact of a geriatric case management program on health plan costs. Popul Health Manag. Aug. 2008;11(4):209-15. [pmid: 18942926].
146 Pugh GL. Exploring HIV/AIDS case management and client quality of life. Journal of HIV/AIDS and Social Services. 2009;8(2):202-18.
147 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. Spring. 2000;24(3):12-20. [pmid: 10986928].
148 Schifalacqua MM, Ulch PO, Schmidt M. How to make a difference in the health care of a population. One person at a time. Nurs Adm Q. Jan-Mar. 2004;28(1):29-35. [pmid: 14986505].
149 Schraeder C, Fraser C, Clark I, et al. Evaluation of a primary care nurse case management intervention for chronically ill community dwelling older people. Journal of Nursing and Healthcare of Chronic Illnesses. 2008;17:407-17.
150 Shah R, Chen C, O'Rourke S, et al. Evaluation of care management for the uninsured. Med Care. Feb. 2011;49(2):166-71. [pmid: 21206292].
151 Specht J, Bossen A, Hall GR, et al. The effects of a dementia nurse care manager on improving caregiver outcomes outcomes. Am J Alzheimers Dis Other Demen. Jun-Jul. 2009;24(3):193-207. [pmid: 19246574].
152 Tatum WO, Al-Saadi S, Orth TL. Outpatient case management in low-income epilepsy patients. Epilepsy Res. Dec. 2008;82(2-3):156-61. [pmid: 18801643].
153 Wetta-Hall R. Impact of a collaborative community case management program on a low-income uninsured population in Sedgwick County, KS. App Nurs Res. 2007;20(4):188-94. [pmid: 17996805].
154 Wilson C, Curtis J, Lipke S, et al. Nurse case manager effectiveness and case load in a large clinical practice: implications for workforce development. Diabet Med. Aug. 2005;22(8):1116-20. [pmid: 16026383].
155 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. [pmid: 11911726].
156 Latour CH, Bosmans JE, van Tulder MW, et al. Cost-effectiveness of a nurse-led case management intervention in general medical outpatients compared with usual care: an economic evaluation alongside a randomized controlled trial. J Psychosom Res. Mar. 2007;62(3):363-70. [pmid: 17324688].
157 Long MJ, Marshall BS. Case management and the cost of care in the last month of life: evidence from one managed care setting. Health Care Management Review. 1999;24(4):45-53. [pmid: 10572788].
158 Shea S, Weinstock RS, Starren J, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc. Jan-Feb. 2006;13(1):40-51. [pmid: 16221935].
159 Poole PJ, Chase B, Frankel A, et al. Case management may reduce length of hospital stay in patients with recurrent admissions for chronic obstructive pulmonary disease. Respirology. Mar. 2001;6(1):37-42. [pmid: 11264761].