# Evidence Tables

Evidence Table 1 Trials of Case Management for Older Adults with One or More Chronic Diseases

Evidence Table 2 Observational Studies of Case Management for Older Adults with Multiple Chronic Diseases

Evidence Table 3 Trials of Case Management for the Frail Elderly

Evidence Table 4 Observational Studies of Case Management for the Frail Elderly

Evidence Table 5 Trials of Case Management for Dementia

Evidence Table 6 Observational Studies of Case Management for Dementia

Evidence Table 7 Trials of Case Management for Congestive Heart Failure

Evidence Table 8 Observational Studies of Case Management for Congestive Heart Failure

Evidence Table 9 Trials of Case Management for Diabetes Mellitus

Evidence Table 10 Observational Studies of Case Management for Diabetes Mellitus

Evidence Table 11 Trials of Case Management for Cancer

Evidence Table 12 Trials of Case Management for Serious Chronic Infections

Evidence Table 13 Observational Studies of Case Management for Serious Chronic Infections

Evidence Table 14 Trials of Case Management for Other Clinical Conditions

Evidence Table 15 Observational Studies of Case Management for Other Clinical Conditions