# Strength of Evidence

Table H-1 Strength of evidence for key outcomes in case management for older adults with one or more chronic diseases

Table H-2 Strength of evidence for key outcomes in case management for the frail elderly

Table H-3 Strength of evidence for key outcomes in case management for patients with dementia

Table H-4 Strength of evidence for key outcomes in case management for patients with congestive heart failure

Table H-5 Strength of evidence for key outcomes in case management for patients with diabetes mellitus

Table H-6 Strength of evidence for key outcomes in case management for patients with cancer

Table H-7 Strength of evidence for key outcomes in case management for patients with serious chronic infections

Table H-8 Strength of evidence for key outcomes in case management for patients with other medical problems