# Quality Assessment of Randomized Trials and Observational Studies

Table G-1 Quality Assessment of Randomized Trials

Table G-2 Quality Assessment of Observational Studies