# Included and Excluded Studies

## Included Studies

1 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. [pmid: 17903862].
2 Andersen M, Hockman E, Smereck G, et al. Retaining women in HIV medical care. J Assoc Nurses AIDS Care. May-Jun. 2007;18(3):33-41. [pmid: 17570298].
3 Applebaum R, Straker J, Mehdizadeh S, et al. Using high-intensity care management to integrate acute and long-term care services: substitute for large scale system reform?. Care Manag J. Spring. 2002;3(3):113-9. [pmid: 12632877].
4 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. Feb. 2009;36(1):113-26. [pmid: 19188371].
5 Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. May. 1998;316(7141):1348-51. [pmid: 9563983].
6 Berra K, Ma J, Klieman L, et al. Implementing cardiac risk-factor case management: lessons learned in a county health system. Crit Pathw Cardiol. Dec. 2007;6(4):173-9. [pmid: 18091408].
7 Bird SR, Kurowski W, Dickman GK, et al. Integrated care facilitation for older patients with complex health care needs reduces hospital demand. Aust Health Rev. Aug. 2007;31(3):451-61. discussion 49-50. [pmid: 17669069].
8 Bird S, Noronha M, Sinnott H. An integrated care facilitation model improves quality of life and reduces use of hospital resources by patients with chronic obstructive pulmonary disease and chronic heart failure. Aust J Prim Health. 2010;16(4):326-33. [pmid: 21138701].
9 Bouey PD, Druan BE. The Ahalaya case-management program for HIV-infected American Indians, Alaska Natives, and Native Hawaiians: quantitative and qualitative evaluation of impacts. Am Indian Alsk Native Ment Health Res. 2000;9(2):36-52. [pmid: 11279557].
10 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. Mar. 2008;63(3):321-7. [pmid: 18375882].
11 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. Mar. 14. 2011;171(5):460-6. [pmid: 21403043].
12 Bourbeau J, Collet JP, Schwartzman K, et al. Economic benefits of self-management education in COPD. Chest. Dec. 2006;130(6):1704-11. [pmid: 17166985].
13 Bourbeau J, Julien M, Maltais F, et al. Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention. Arch Intern Med. Mar. 10. 2003;163(5):585-91. [pmid: 12622605].
14 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. Mar. 2010;25(3):235-42. [pmid: 20033622].
15 Brodaty H, Mittelman M, Gibson L, et al. The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. Sep. 2009;17(9):734-43. [pmid: 19705519].
16 Brown SA, Garcia AA, Winter M, et al. Integrating education, group support, and case management for diabetic Hispanics. Ethn Dis. 2011;21(1):20-6. [pmid: 21462725].
17 California Medi-Cal Type 2 Diabetes Study Group. Closing the gap: effect of diabetes case management on glycemic control among low-income ethnic minority populations: the California Medi-Cal type 2 diabetes study. Diabetes Care. Jan. 2004;27(1):95-103. [pmid: 14693973].
18 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May. 10. 2006. 2006;295(18):2148-57. [pmid: 16684985].
19 Challis D, von Abendorff R, Brown P, et al. Care management, dementia care and specialist mental health services: an evaluation. Int J Geriatr Psychiatry. Apr. 2002;17(4):315-25. [pmid: 11994884].
20 Chi YC, Chuang KY, Wu SC, et al. The assessment of a hospital-based care management model for long-term care services. J Nurs Res. Dec. 2004;12(4):317-26. [pmid: 15619182].
21 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. 2008;59(4). [pmid: 18378844].
22 Chow SKY, Wong FK. Health-related quality of life in patients undergoing peritoneal dialysis: effects of a nurse-led case management programme. J Adv Nurs. 2010;66(8):1780-92. [pmid: 20557392].
23 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early stage Alzheimer's patients and their families. Am J Alzheimers Dis. 2000;15(5):284-90.
24 Claiborne N. Efficiency of a care coordination model: a randomized study with stroke patients. Res Social Work Prac. 2006;16(1):57-66. [pmid: 16776026].
25 Clark P, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging Ment Health. 2004;8(1):40-51. [pmid: 14690867].
26 Creason H. Congestive heart failure telemanagement clinic. Lippincotts Case Manag. Jul-Aug. 2001;6(4):146-56. [pmid: 16398064].
27 Curtis J, Lipke S, Effland S, et al. Effectiveness and safety of medication adjustments by nurse case managers to control hyperglycemia. Diabetes Educ. Sep-Oct. 2009;35(5):851-6. [pmid: 19713556].
28 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2004 Oct 19;141(8):I58; PMID:15492334]. Ann Intern Med. Oct. 19. 2004;141(8):606-13. [pmid: 15492340].
29 Dewan NA, Rice KL, Caldwell M, et al. Economic evaluation of a disease management program for chronic obstructive pulmonary disease. COPD. Jun. 2011;8(3):153-9. [pmid: 21513435].
30 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. Dec. 2008;56(12):2195-202. [pmid: 19093919].
31 Dorr DA, Wilcox A, Donnelly SM, et al. Impact of generalist care managers on patients with diabetes. Health Serv Res. Oct. 2005;40(5 Pt 1):1400-21. [pmid: 16174140].
32 Dorr DA, Wilcox A, Jones S, et al. Care management dosage. J Gen Intern Med. Jun. 2007;22(6):736-41. [pmid: 17415620].
33 Duke C. The frail elderly community-based case management project. Geriatric Nursing. Mar-Apr. 2005;26(2):122-7. [pmid: 15824728].
34 Duru OK, Ettner SL, Vassar SD, et al. Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. 2009;15(8):521-8. [pmid: 19670955].
35 Eggert GM, Zimmer JG, Hall WJ, et al. Case management: a randomized controlled study comparing a neighborhood team and a centralized individual model. Health Serv Res. Oct. 1991;26(4):471-507. [pmid: 1917502].
36 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: A randomized trial. J Am Geriatr Soc. 2001;49(10):1282-7. [pmid: 11890485].
37 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen M, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200-8. [pmid: 20121986].
38 Engelhardt JB, McClive-Reed KP, Toseland RW, et al. Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care. Feb. 2006;12(2):93-100. [pmid: 16464138].
39 Fan VS, Gaziano JM, Lew R, et al. A comprehensive care management program to prevent chronic obstructive pulmonary disease hospitalizations: a randomized, controlled trial. Ann Intern Med. May. 15. 2012;156(10):673-83. [pmid: 22586006].
40 Fitzgerald JF, Smith DM, Martin DK, et al. A case manager intervention to reduce readmissions. Arch Intern Med. Aug. 8. 1994;154(15):1721-9. [pmid: 8042889].
41 Fleishman JA, Mor V, Piette J. AIDS case management: the client's perspective. Health Serv Res. Oct. 1991;26(4):447-70. [pmid: 1917501].
42 Fletcher K, Mant J. A before and after study of the impact of Specialist Workers for Older People. J Eval Clin Pract. Apr. 2009;15(2):335-40. [pmid: 19335494].
43 Gagnon AJ, Schein C, McVey L, et al. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. Sep. 1999;47(9):1118-24. [pmid: 10484257].
44 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educ. 2005;31(6):880-9. [pmid: 16288095].
45 Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med. Jul. 2003;37(1):23-32. [pmid: 12799126].
46 Gary TL, Batts-Turner M, Bone LR, et al. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Feb. 2004;25(1):53-66. [pmid: 14980748].
47 Gary TL, Batts-Turner M, Yeh HC, et al. The effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. Oct. 2009;169(19):1788-94. [pmid: 19858437].
48 Goodwin JS, Satish S, Anderson ET, et al. Effect of nurse case management on the treatment of older women with breast cancer. J Am Geriatr Soc. Sep. 2003;51(9):1252-9. [pmid: 12919237].
49 Gravelle H, Dusheiko M, Sheaff R, et al. Impact of case management (Evercare) on frail elderly patients: controlled before and after analysis of quantitative outcome data. BMJ. Jan. 6. 2007;334(7583):31. [pmid: 17107984].
50 Hammer BJ. Community-based case management for positive outcomes. Geriatr Nurs. Sep-Oct. 2001;22(5):271-5. [pmid: 11606909].
51 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. Aug. 2003;49:992-7. [pmid: 12943358].
52 Hsieh CJ, Lin LC, Kuo BI, et al. Exploring the efficacy of a case management model using DOTS in the adherence of patients with pulmonary tuberculosis. J Clin Nurs. Apr. 2008;17(7):869-75. [pmid: 17850292].
53 Husbands W, Browne G, Caswell J, et al. Case management community care for people living with HIV/AIDS (PLHAs). AIDS Care. Sep. 2007;19(8):1065-72. [pmid: 17852006].
54 Huws DW, Cashmore D, Newcombe RG, et al. Impact of case management by advanced practice nurses in primary care on unplanned hospital admissions: a controlled intervention study. BMC Health Serv Res. 2008;8:115. [pmid: 18510730].
55 Ishani A, Greer N, Taylor BC, et al. Effect of nurse case management compared with usual care on controlling cardiovascular risk factors in patients with diabetes: a randomized controlled trial. Diabetes Care. Aug. 2011;34(8):1689-94. [pmid: 21636796].
56 Izquierdo R, Meyer S, Starren J, et al. Detection and remediation of medically urgent situations using telemedicine case management for older patients with diabetes mellitus. Ther Clin Risk Manag. Jun. 2007;3(3):485-9. [pmid: 18488079].
57 Jaarsma T, van der Wal MH, Lesman-Leegte I, et al. Effect of moderate or intensive disease management program on outcome in patients with heart failure: Coordinating Study Evaluating Outcomes of Advising and Counseling in Heart Failure (COACH). Arch Intern Med. Feb. 11. 2008;168(3):316-24. [pmid: 18268174].
58 Jansen AP, van Hout HP, van Marwijk HW, et al. (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. [pmid: 16343336].
59 Jansen A, van Hout H, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. 2011;48(8):933-43. [pmid: 21356537].
60 Jennings-Sanders A, Anderson ET. Older women with breast cancer: perceptions of the effectiveness of nurse case managers. Nurs Outlook. May-Jun. 2003;51(3):108-14. [pmid: 12830102].
61 Jennings-Sanders A, Kuo YF, Anderson ET, et al. How do nurse case managers care for older women with breast cancer?. Oncol Nurs Forum. May. 2005;32(3):625-32. [pmid: 15897937].
62 Jowers J, Corsello P, Shafer A, et al. Partnering specialist care with nurse case management: a pilot project for asthma. J Clin Outcomes Manage. 2000;7(5):17-22.
63 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. [pmid: 11823086].
64 Keating P, Sealy A, Dempsey L, et al. Reducing unplanned hospital admissions and hospital bed days in the over 65 age group: results from a pilot study. Journal of Integrated Care. 2008;16(1):3-8.
65 Krein SL, Klamerus ML, Vijan S, et al. Case management for patients with poorly controlled diabetes: a randomized trial. Am J Med. Jun. 1. 2004;116(11):732-9. [pmid: 15144909].
66 Kristensson J, Ekwall AK, Jakobsson U, et al. Case managers for frail older people: a randomised controlled pilot study. Scand J Caring Sci. Dec. 2010;24(4):755-63. [pmid: 20409057].
67 Kruse RL, Zweig SC, Nikodim B, et al. Nurse care coordination of older patients in an academic family medicine clinic: 5-year outcomes. Journal of Clinical Outcomes Management. 2010;17(5):209-15.
68 Kushel MB, Colfax G, Ragland K, et al. Case management is associated with improved antiretroviral adherence and CD4+ cell counts in homeless and marginally housed individuals with HIV infection. Clin Infect Dis. Jul. 15. 2006;43(2):234-42. [pmid: 16779752].
69 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. Apr. 2010;25(4):395-402. [pmid: 19606455].
70 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 2003;163(7):809-17. [pmid: 12695272].
71 Latour CH, de Vos R, Huyse FJ, et al. Effectiveness of post-discharge case management in general-medical outpatients: a randomized, controlled trial. Psychosomatics. Sep-Oct. 2006;47(5):421-9. [pmid: 16959931].
72 Latour CH, Bosmans JE, van Tulder MW, et al. Cost-effectiveness of a nurse-led case management intervention in general medical outpatients compared with usual care: an economic evaluation alongside a randomized controlled trial. J Psychosom Res. Mar. 2007;62(3):363-70. [pmid: 17324688].
73 Lehrman SE, Gentry D, Yurchak BB, et al. Outcomes of HIV/AIDS case management in New York. AIDS Care. Aug. 2001;13(4):481-92. [pmid: 11454269].
74 Leung AC, Yau DC, Liu CP, et al. Reducing utilisation of hospital services by case management: a randomised controlled trial. Aust Health Rev. 2004;28(1):79-86. [pmid: 15525254].
75 Leung AT, Liu CP, Chow NS, et al. Cost-benefit analysis of a case management project for the community-dwelling frail elderly in Hong Kong. J Appl Gerontol. 2004;23(1):70-85.
76 Lin RL, Lin FJ, Wu CL, et al. Effect of a hospital-based case management approach on treatment outcome of patients with tuberculosis. J Formos Med Assoc. Aug. 2006;105(8):636-44. [pmid: 16935764].
77 Long MJ. Case management model or case manager type? That is the question. Health Care Manager. Jun. 2002;20(4):53-65. [pmid: 12083179].
78 Long MJ, Marshall BS. What price an additional day of life? A cost-effectiveness study of case management. Am J Manag Care. Aug. 2000;6(8):881-6. [pmid: 11186500].
79 Lu KY, Lin PL, Tzeng LC, et al. Effectiveness of case management for community elderly with hypertension, diabetes mellitus, and hypercholesterolemia in Taiwan: a record review. Int J Nurs Stud. Nov. 2006;43(8):1001-10. [pmid: 16384558].
80 Luzinski CH, Stockbridge E, Craighead J, et al. The community case management program: for 12 years, caring at its best. Geriatr Nurs. May-Jun. 2008;29(3):207-15. [pmid: 18555162].
81 Ma J, Berra K, Haskell WL, et al. Case management to reduce risk of cardiovascular disease in a county health care system. Arch Intern Med. Nov. 2009;169(21):1988-95. [pmid: 19933961].
82 Ma J, Lee KV, Berra K, et al. Implementation of case management to reduce cardiovascular disease risk in the Stanford and San Mateo Heart to Heart randomized controlled trial: study protocol and baseline characteristics. Implement Sci. 2006;1:21. [pmid: 17005050].
83 Mangura B, Napolitano E, Passannante M, et al. Directly observed therapy (DOT) is not the entire answer: an operational cohort analysis. Int J Tuberc Lung Dis. Aug. 2002;6(8):654-61. [pmid: 12150475].
84 Marshall BS, Long MJ, Voss J, et al. Case management of the elderly in a health maintenance organization: the implications for program administration under managed care. J Healthc Manag. Nov-Dec. 1999;44(6):477-91. discussion 92-3. [pmid: 10662433].
85 Martin DC, Berger ML, Anstatt DT, et al. A randomized controlled open trial of population-based disease and case management in a Medicare Plus Choice health maintenance organization. Prev Chronic Dis. Oct. 2004;1(4):A05. [pmid: 15670436].
86 Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient's personal physician on the outcome of stroke. Age and ageing. Jan. 2008;37(1):32-8. [pmid: 18006510].
87 McCorkle R, Benoliel JQ, Donaldson G, et al. A randomized clinical trial of home nursing care for lung cancer patients. Cancer. Sep. 15. 1989;64(6):1375-82. [pmid: 2670188].
88 McCoy HV, Dodds S, Rivers JE, et al. Case management services for HIV-seropositive IDUs. NIDA Res Monogr. 1992;127:181-207. [pmid: 1435995].
89 Miller R, Newcomer R, Fox P. Effects of the Medicare Alzheimer's Disease Demonstration on nursing home entry. Health Serv Res. Aug. 1999;34(3):691-714. [pmid: 10445898].
90 Mittelman M, Roth D, Haley W, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems inpatients with Alzheimer's Disease: Results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. 2004;59(1):27-34. [pmid: 14722336].
91 Mittelman M, Roth D, Coon D, et al. Sustained benefit of supportive intervention for depressive symptoms in Alzheimer's caregivers. Am J Psychiatry. 2004;161:850-6. [pmid: 15121650].
92 Mittelman MS, Brodaty H, Wallen AS, et al. A Three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: Effects on caregiver depression. Am J Geriatr Psychiatry. 2008;16(11):893-904. [pmid: 18978250].
93 Mittelman MS, Haley WE, Clay OJ, et al. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. 2006;67(9):1592-9. [pmid: 17101889].
94 Moore S, Corner J, Haviland J, et al. Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. BMJ. Nov. 16. 2002;325(7373):1145. [pmid: 12433764].
95 Mor V, Wool M, Guadagnoli E, et al. The impact of short term case management on cancer patients' concrete needs and quality of life. Advances in Medical Sociology. 1995;6:269-94.
96 Morales-Asencio JM, Gonzalo-Jimenez E, Martin-Santos FJ, et al. Effectiveness of a nurse-led case management home care model in Primary Health Care. A quasi-experimental, controlled, multi-centre study. BMC Health Serv Res. 2008;8:193. [pmid: 18811927].
97 Moran G, Coleman V, Heaney S, et al. An alternative model for case management in Flintshire. Br J Community Nurs. May. 2008;13(5):227-31. [pmid: 18771186].
98 Newcomer R, Yordi C, DuNah R, et al. Effects of the Medicare Alzheimer's Disease Demonstration on caregiver burden and depression. Health Serv Res. Aug. 1999;34(3):669-89. [pmid: 10445897].
99 Newcomer R, Spitalny M, Fox P, et al. Effects of the Medicare Alzheimer's Disease Demonstration on the use of community-based services. Health Serv Res. Aug. 1999;34(3):645-67. [pmid: 10445896].
100 Newcomer R, Miller R, Clay T, et al. Effects of the Medicare Alzheimer's Disease Demonstration on Medicare expenditures. Health Care Financ Rev. 1999;20(4):45-65. [pmid: 11482124].
101 Newcomer R, Maravilla V, Faculjak P, et al. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. Dec. 2004;27(4):323-48. [pmid: 15492046].
102 Nickel JT, Salsberry PJ, Caswell RJ, et al. Quality of life in nurse case management of persons with AIDS receiving home care. Res Nurs Health. Apr. 1996;19(2):91-9. [pmid: 8606987].
103 Nyamathi AM, Christiani A, Nahid P, et al. A randomized controlled trial of two treatment programs for homeless adults with latent tuberculosis infection. Int J Tuberc Lung Dis. Jul. 2006;10(7):775-82. [pmid: 16848340].
104 Nyamathi A, Stein JA, Schumann A, et al. Latent variable assessment of outcomes in a nurse-managed intervention to increase latent tuberculosis treatment completion in homeless adults. Health Psychol. Jan. 2007;26(1):68-76. [pmid: 17209699].
105 Okin RL, Boccellari A, Azocar F, et al. The effects of clinical case management on hospital service use among ED frequent users. Am J Emerg Med. Sep. 2000;18(5):603-8. [pmid: 10999578].
106 Oliva NL. A closer look at nurse case management of community-dwelling older adults: observations from a longitudinal study of care coordination in the chronically ill. Prof Case Manag. Mar-Apr. 2010;15(2):90-100. [pmid: 20234292].
107 Onder G, Liperoti R, Soldato M, et al. Case management and risk of nursing home admission for older adults in home care: results of the AgeD in HOme Care Study. J Am Geriatr Soc. Mar. 2007;55(3):439-44. [pmid: 17341249].
108 Onder G, Liperoti R, Bernabei R, et al. Case management, preventive strategies, and caregiver attitudes among older adults in home care: results of the ADHOC study. J Am Med Dir Assoc. Jun. 2008;9(5):337-41. [pmid: 18519115].
109 Palmas W, Shea S, Starren J, et al. Medicare payments, healthcare service use, and telemedicine implementation costs in a randomized trial comparing telemedicine case management with usual care in medically underserved participants with diabetes mellitus (IDEATel). J Am Med Inform Assoc. Mar-Apr. 2010;17(2):196-202. [pmid: 20190064].
110 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries. JAMA. February. 11. 2009. 2009;301(6):603-18. [pmid: 19211468].
111 Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. [pmid: 20478035].
112 Pettitt DJ, Okada Wollitzer A, Jovanovic L, et al. Decreasing the risk of diabetic retinopathy in a study of case management: the California Medi-Cal Type 2 Diabetes Study. Diabetes Care. Dec. 2005;28(12):2819-22. [pmid: 16306539].
113 Picariello G, Hanson C, Futterman R, et al. Impact of a geriatric case management program on health plan costs. Population Health Management. Aug. 2008;11(4):209-15. [pmid: 18942926].
114 Poole PJ, Chase B, Frankel A, et al. Case management may reduce length of hospital stay in patients with recurrent admissions for chronic obstructive pulmonary disease. Respirology. Mar. 2001;6(1):37-42. [pmid: 11264761].
115 Pugh GL. Exploring HIV/AIDS case management and client quality of life. Journal of HIV/AIDS and Social Services. 2009;8(2):202-18.
116 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. MEDSURG Nursing. 2001;10(2):71-8.
117 Rice KL, Dewan N, Bloomfield HE, et al. Disease management program for chronic obstructive pulmonary disease: a randomized controlled trial. Am J Respir Crit Care Med. Oct. 1. 2010;182(7):890-6. [pmid: 20075385].
118 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. [pmid: 8289096].
119 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. [pmid: 7565975].
120 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. [pmid: 11911726].
121 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. [pmid: 16624687].
122 Ritz LJ, Nissen MJ, Swenson KK, et al. Effects of advanced nursing care on quality of life and cost outcomes of women diagnosed with breast cancer. Oncol Nurs Forum. Jul. 2000;27(6):923-32. [pmid: 10920832].
123 Roth DL, Mittelman MS, Clay OJ, et al. Changes in social support as mediators of the impact of a psychosocial intervention for spouse caregivers of persons with Alzheimer's disease. Psychol Aging. Dec. 2005;20(4):634-44. [pmid: 16420138].
124 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. [pmid: 17302651].
125 Sadowski LS, Kee RA, VanderWeele TJ, et al. Effect of a housing and case management program on emergency department visits and hospitalizations among chronically ill homeless adults: a randomized trial. JAMA. May. 6. 2009;301(17):1771-8. [pmid: 19417194].
126 Sansom SL, Anthony MN, Garland WH, et al. The costs of HIV antiretroviral therapy adherence programs and impact on health care utilization. AIDS Patient Care STDs. 2008;22(2):131-8. [pmid: 18260804].
127 Schein C, Gagnon AJ, Chan L, et al. The association between specific nurse case management interventions and elder health. J Am Geriatr Soc. Apr. 2005;53(4):597-602. [pmid: 15817004].
128 Schifalacqua MM, Ulch PO, Schmidt M. How to make a difference in the health care of a population. One person at a time. Nurs Adm Q. Jan-Mar. 2004;28(1):29-35. [pmid: 14986505].
129 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. Spring. 2000;24(3):12-20. [pmid: 10986928].
130 Schore J, Brown R, Cheh V, et al. Costs and Consequences of Case Management for Medicare Beneficiaries. Report prepared for the Health Care Financing Administration. Princeton (NJ). Mathematica Policy Research, Inc. 1997.
131 Schore JL, Brown RS, Cheh VA. Case management for high-cost Medicare beneficiaries. Health Care Financ Rev. Summer. 1999;20(4):87-101. [pmid: 11482127].
132 Schore J, Peikes D, Peterson G, et al. Fourth Report to Congress on the Evaluation of the Medicare Coordinated Care Demonstration. Mathematica Reference Number: 6555-440. (Prepared by Mathematica Policy Research, Inc. under contract number HHSM-500-2005-00025I (0012)). Baltimore, MD. Centers for Medicare & Medicaid Services. March. 2011.
133 Schraeder C, Fraser C, Clark I, et al. Evaluation of a primary care nurse case management intervention for chronically ill community dwelling older people. Journal of Nursing and Healthcare of Chronic Illnesses. 2008;17:407-17.
134 Shah R, Chen C, O'Rourke S, et al. Evaluation of care management for the uninsured. Med Care. Feb. 2011;49(2):166-71. [pmid: 21206292].
135 Shea S, IDEATel Consortium. The Informatics for Diabetes and Education Telemedicine (IDEATel) project. Trans Am Clin Climatol Assoc. 2007;118:289-304. [pmid: 18528511].
136 Shea S, Starren J, Weinstock RS, et al. Columbia University 's Informatics for Diabetes Education and Telemedicine (IDEATel) Project: rationale and design. J Am Med Inform Assoc. Jan-Feb. 2002;9(1):49-62. [pmid: 11751803].
137 Shea S, Weinstock RS, Starren J, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc. Jan-Feb. 2006;13(1):40-51. [pmid: 16221935].
138 Shea S, Weinstock RS, Teresi JA, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus: 5 year results of the IDEATel study. J Am Med Inform Assoc. Jul-Aug. 2009;16(4):446-56. [pmid: 19390093].
139 Shelton P, Schraeder C, Dworak D, et al. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc. Dec. 2001;49(12):1600-5. [pmid: 11843991].
140 Sisk JE, Hebert PL, Horowitz CR, et al. Improving patient care. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. 2006;145(4):273. [pmid: 16908918].
141 Sorensen JL, Dilley J, London J, et al. Case management for substance abusers with HIV/AIDS: a randomized clinical trial. Am J Drug Alcohol Abuse. 2003;29(1):133-50. [pmid: 12731685].
142 Specht J, Bossen A, Hall GR, et al. The effects of a dementia nurse care manager on improving caregiver outcomes outcomes. Am J Alzheimers Dis Other Demen. Jun-Jul. 2009;24(3):193-207. [pmid: 19246574].
143 Tatum WO, Al-Saadi S, Orth TL. Outpatient case management in low-income epilepsy patients. Epilepsy Res. Dec. 2008;82(2-3):156-61. [pmid: 18801643].
144 Trief PM, Teresi JA, Izquierdo R, et al. Psychosocial outcomes of telemedicine case management for elderly patients with diabetes: the randomized IDEATel trial. Diabetes Care. May. 2007;30(5):1266-8. [pmid: 17325261].
145 Trief PM, Morin PC, Izquierdo R, et al. Depression and glycemic control in elderly ethnically diverse patients with diabetes: the IDEATel project. Diabetes Care. Apr. 2006;29(4):830-5. [pmid: 16567823].
146 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care. Ann Intern Med. November. 21. 2006. 2006;145(10):713-26. [pmid: 17116916].
147 Wetta-Hall R. Impact of a collaborative community case management program on a low-income uninsured population in Sedgwick County, KS. App Nurs Res. 2007;20(4):188-94. [pmid: 17996805].
148 Wilson C, Curtis J, Lipke S, et al. Nurse case manager effectiveness and case load in a large clinical practice: implications for workforce development. Diabet Med. Aug. 2005;22(8):1116-20. [pmid: 16026383].
149 Wohl AR, Garland WH, Valencia R, et al. A randomized trial of directly administered antiretroviral therapy and adherence case management intervention. Clin Infect Dis. Jun. 2006;42(11):1619-27. [pmid: 16652320].
150 Wolf AM, Conaway MR, Crowther JQ, et al. Translating lifestyle intervention to practice in obese patients with type 2 diabetes: Improving Control with Activity and Nutrition (ICAN) study. Diabetes Care. 2004;27(7):1570-6. [pmid: 15220230].
151 Wolf AM, Siadaty M, Yaeger B, et al. Effects of lifestyle intervention on health care costs: Improving Control with Activity and Nutrition (ICAN). J Am Diet Assoc. Aug. 2007;107(8):1365-73. [pmid: 17659904].
152 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of guided care on family caregivers. Gerontologist. Aug. 2010;50(4):459-70. [pmid: 19710354].
153 Zimmer JG, Eggert GM, Chiverton P. Individual versus team case management in optimizing community care for chronically ill patients with dementia. J Aging Health. Aug. 1990;2(3):357-72. [pmid: 10170566].

## Excluded Studies

1 Care coordination decreases hospitalizations: program combines face-to-face, telephonic CM. Hospital Home Health. Jan. 2010;27(1):6-8. Exclusion reason: Background.
2 Care management position statement. American Geriatrics Society. Journal of the American Geriatrics Society. Oct. 2000;48(10):1338-9. Exclusion reason: No original data. [pmid: 11037025].
3 Case managers are still fighting to prove their value. Hospital Case Management. Nov. 2004;12(11):1-4. Exclusion reason: No original data. [pmid: 15540617].
4 Case managers reorganize to challenge claims denials. Hospital Case Management. Aug. 1999;7(8):133-6. Exclusion reason: Wrong intervention. [pmid: 10557727].
5 Chronic illness subject of successful program. Hospital Case Management. Oct. 2000;8(10):148-9. Exclusion reason: No original data. [pmid: 11143161].
6 CM in the home reduces ED, inpatient visits: hospital focuses on frail elderly patients. Hospital Case Management. 2011;19(1):12-5. Exclusion reason: Wrong intervention. [pmid: 21265382].
7 CM redesign promotes care coordination. Hospital Case Management. 2010;18(11):166-72. Exclusion reason: Wrong setting. [pmid: 21053695].
8 CMS programs tackle chronic care costs: home health agencies use CM experience. Case Management Advisor. 2005;16(4):41-3. Exclusion reason: Background.
9 ‘Down and dirty’ medical information system identifies high-risk patients. Data Strategies & Benchmarks. Dec. 1998;2(12):186-7. Exclusion reason: Wrong intervention. [pmid: 10538489].
10 Hospital group saves money with data on nurse case management. Healthcare Benchmarks. Sep. 2000;7(9):97-100. Exclusion reason: Wrong intervention. [pmid: 11187284].
11 LitScan for case managers. Care Management. 2010;16(6):18-21. Exclusion reason: Unable to locate.
12 Multi-pronged plan helps members with chronic illness: interventions depend on the severity of disease. Case Management Advisor. 2007;18(8):77-9. Exclusion reason: No original data.
13 Proactive case management pays off for insurer in outcomes, cost savings: program achieves a minimum 4.5-to-1 return on investment. Case Management Advisor. 2003;14(11):121-3. Exclusion reason: Wrong intervention.
14 Proactive interventions cut hospitalization rate dramatically: program targets at-risk members. Case Management Advisor. 2003;14(12):133-5. Exclusion reason: Wrong intervention.
15 Program provides case management for ill, frail elderly who don't qualify for home care. Senior Care Management. 2004;7(11):124-27. Exclusion reason: Unable to locate.
16 Providers reap big savings with case management. Public Sector Contracting Report. Oct. 1997;3(10):145-51. Exclusion reason: Unable to locate. [pmid: 10177096].
17 Reduce costs, improve outcomes with community case management. Hospital Case Management. Mar. 2001;9(3):33-6. Exclusion reason: No original data. [pmid: 11236278].
18 Summaries for patients. Effect of case managers on the care of patients with HIV infection. Annals of Internal Medicine. Oct. 16. 2001;135(8 Pt 1):S-46. Exclusion reason: No original data. [pmid: 11680416].
19 Summaries for patients. Nurse care management for low-risk patients with heart failure. [Original report in Ann Intern Med. 2004 Oct 19;141 (8):606-13; PMID:15492340]. Annals of Internal Medicine. Oct. 19. 2004;141(8):I58. Exclusion reason: No original data. [pmid: 15492334].
20 Aadalen SP. Methodological challenges to prospective study of an innovation: interregional nursing care management of cardiovascular patients. Journal of Evaluation in Clinical Practice. Aug. 1998;4(3):197-223. Exclusion reason: Wrong intervention. [pmid: 9744709].
21 Abell J, Hughes J, Reilly S, et al. Case management for long-term conditions: developing targeting processes. Care Management Journals. 2010;11(1):11-8. Exclusion reason: Wrong outcome. [pmid: 20426316].
22 Abissi CJ, Sepe E, Patlak C, et al. Cerebral infarction: comparison of a care plan with case-management to traditional care. Neurology. 1995:45. Exclusion reason: Wrong setting. [pmid: 7824133].
23 Adam R. Delivering unique care: care co-ordination in practice. Journal of Integrated Care. Apr. 2006;14(2):37-47. Exclusion reason: No original data.
24 Ahmed OI, Rak DJ. Hospital readmission among participants in a transitional case management program. American Journal of Managed Care. Oct. 2010;16(10):778-83. Exclusion reason: Wrong intervention. [pmid: 20964474].
25 Aiken LS, Butner J, Lockhart CA, et al. Outcome evaluation of a randomized trial of the PhoenixCare intervention: program of case management and coordinated care for the seriously chronically ill. Journal of Palliative Medicine. Feb. 2006;9(1):111-26. Exclusion reason: Wrong population. [pmid: 16430351].
26 Alexopoulos GS. Personalizing the care of geriatric depression. American Journal of Psychiatry. Jul. 2008;165(7):790-2. Exclusion reason: Wrong population. [pmid: 18593780].
27 Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in depressed geriatric primary care patients: a report from the PROSPECT study. American Journal of Psychiatry. Apr. 2005;162(4):718-24. Exclusion reason: Wrong intervention. [pmid: 15800144].
28 Aliotta S. Patient adherence outcome indicators: the Council for Case Management Accountability's first state of the science paper. first of a three-part series. Case Manager. 2002;13(3):57-61. Exclusion reason: No original data. [pmid: 12011839].
29 Aliotta SL. Focus on case management: linking outcomes and accountability. Topics in Health Information Management. 2000;20(3):11-6. Exclusion reason: No original data. [pmid: 10747430].
30 Aliotta SL, Boling J, Commander C, et al. The impact of CMSA's case management adherence guidelines and guidelines training on case manager-reported behavior change. Professional Case Management. 2007;12(5):288-95. Exclusion reason: Wrong outcome. [pmid: 17885636].
31 Aliotta SL, Grieve K, Giddens JF, et al. Guided care: a new frontier for adults with chronic conditions. Professional Case Management. May-Jun. 2008;13(3):151-8. quiz 9-60. Exclusion reason: Wrong outcome. [pmid: 18562909].
32 Aliotta SL, Vlasnik JJ, Delor B. Enhancing adherence to long-term medical therapy: a new approach to assessing and treating patients. Advances in Therapy. Jul-Aug. 2004;21(4):214-31. Exclusion reason: Wrong intervention. [pmid: 15605616].
33 Alkema GE, Reyes JY, Wilber KH. Characteristics associated with home- and community-based service utilization for Medicare managed care consumers. Gerontologist. Apr. 2006;46(2):173-82. Exclusion reason: Wrong intervention. [pmid: 16581881].
34 Allen JK, Blumenthal RS, Margolis S, et al. Nurse case management of hypercholesterolemia in patients with coronary heart disease: results of a randomized clinical trial. American heart journal. Oct. 2002;144(4):678-86. Exclusion reason: Wrong intervention. [pmid: 12360165].
35 Allen NE, Meduna E. Development and implementation of a case management model for long-term care. Journal of Gerontological Nursing. Aug. 1999;25(8):42-9. Exclusion reason: Wrong setting. [pmid: 10711105].
36 Allen SA. Description and outcomes of a Medicare case management program by nurses. Home Health Care Services Quarterly. 1999;18(2):43-68. Exclusion reason: Wrong intervention. [pmid: 11066728].
37 Andersen MD, Smereck GA, Hockman EM, et al. Nurses decrease barriers to health care by “hyperlinking” multiple-diagnosed women living with HIV/AIDS into care. Journal of the Association of Nurses in AIDS Care. Mar-Apr. 1999;10(2):55-65. Exclusion reason: Wrong population. [pmid: 10065410].
38 Anderson JH. The impact of using nursing presence in a community heart failure program. Journal of Cardiovascular Nursing. Mar-Apr. 2007;22(2):89-94. quiz 5-6; discussion 7-8. Exclusion reason: No original data. [pmid: 17318031].
39 Anderson MA, Helms LB, Kelly NR. Realigning the communication paradigm in nursing case management. Care Management Journals. 2004;5(2):67-72. Exclusion reason: Wrong setting. [pmid: 16047911].
40 Anderson MA, Tredway CA. Communication: an outcome of case management. Nursing Case Management. 1999;4(3):104-11. Exclusion reason: Wrong outcome. [pmid: 10476180].
41 Anderson MC, Skillen DL, Knight CL. Continuing care nurses' perceptions of need for physical assessment skills. Journal of Gerontological Nursing. Jul. 2001;27(7):23-9. Exclusion reason: Wrong outcome. [pmid: 11817457].
42 Anderson-Loftin W. In search of a nursing case management model for rural hospitals. NursingConnections. 1995;8(4):31-42. Exclusion reason: Wrong intervention. [pmid: 8709999].
43 Anderson-Loftin W. Activities and perceived outcomes of nurse case managers: building a case management model for rural hospitals [PH.D.]. MEDICAL COLLEGE OF GEORGIA. 1996. Exclusion reason: Wrong population.
44 Anderson-Loftin W. A nursing case management model for rural hospitals. NursingConnections. 1997;10(2):27-38. Exclusion reason: Background. [pmid: 9335891].
45 Anderson-Loftin W. Nurse case managers in rural hospitals. Journal of Nursing Administration. Feb. 1999;29(2):42-9. Exclusion reason: Background. [pmid: 10029801].
46 Anderson-Loftin W, Stiles AS. Developing and testing a case manager impact profile. Nursing Connections. 1999;12(4):5-25. Exclusion reason: Wrong setting. [pmid: 12016641].
47 Applebaum R, Christianson J. Using case management to monitor community-based long term care. QRB. July. Quality Review Bulletin. 1988;14(7):227-31. Exclusion reason: Wrong outcome. [pmid: 3140167].
48 Applebaum R, Mayberry P. Long-term care case management: a look at alternative models. Gerontologist. Oct. 1996;36(5):701-5. Exclusion reason: No original data. [pmid: 8942115].
49 Applebaum RA, Wilson NL. Prescreening at-risk elders for entry into a community-based long-term care program. Home Health Care Services Quarterly. 1987;8(1):75-86. Exclusion reason: Wrong intervention. [pmid: 10312069].
50 Applebaum RA, Wilson NL. Training needs for providing case management for the long-term care client: lessons from the National Channeling Demonstration. Gerontologist. Apr. 1988;28(2):172-6. Exclusion reason: No original data. [pmid: 3129342].
51 Arean PA, Gum A, McCulloch CE, et al. Treatment of depression in low-income older adults. Psychology & Aging. Dec. 2005;20(4):601-9. Exclusion reason: Wrong population. [pmid: 16420135].
52 Armour J. Early perceptions of the role of community matrons. Nursing Times. 2007;103(2):32-3. Exclusion reason: Wrong outcome.
53 Armstrong M, Norby R, Kerwick K, et al. On the scene: Department of Veterans Affairs Medical Center, San Diego, California. Nursing Administration Quarterly. 1995;19(3):45-73. Exclusion reason: No original data. [pmid: 7731585].
54 Arnsberger P. Best practices in care management for Asian American elders: the case of Alzheimer's disease. Care Management Journals. 2005;6(4):171-7. Exclusion reason: No original data. [pmid: 16739769].
55 Aronson J, Sinding C. Home care users' experiences of fiscal constraints. Challenges and opportunities for case management. Care Management Journals. 2000;2(4):220-5. Exclusion reason: Wrong intervention. [pmid: 11680905].
56 Ashman JJ, Conviser R, Pounds MB. Associations between HIV-positive individuals' receipt of ancillary services and medical care receipt and retention. AIDS Care. Aug. Suppl 1. 2002;14:S109-18. Exclusion reason: Wrong intervention. [pmid: 12204145].
57 Ashman JJ, Perez-Jimenez D, Marconi K. Health and support service utilization patterns of American Indians and Alaska Natives diagnosed with HIV/AIDS. AIDS Education & Prevention. Jun. 2004;16(3):238-49. Exclusion reason: Wrong outcome. [pmid: 15237053].
58 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Annals of Internal Medicine. Oct. 15. 1998;129(8):605-12. Exclusion reason: Wrong intervention. [pmid: 9786807].
59 Aubin M, Giguere A, Verreault R, et al. Interventions to improve continuity of care in the follow-up of patients with cancer. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: No original data.
60 Austin CD, McClelland RW. Case management in the human services. Reflections of public policy. Journal of Case Management. 1997;6(3):119-26. Exclusion reason: Wrong population. [pmid: 9573971].
61 Austin CD, McClelland RW, Gursansky D. Linking case management and community development. Care Management Journals. 2006;7(4):162-8. Exclusion reason: Wrong intervention. [pmid: 17194052].
62 Back AL, Li YF, Sales AE. Impact of palliative care case management on resource use by patients dying of cancer at a Veterans Affairs medical center. Journal of Palliative Medicine. Feb. 2005;8(1):26-35. Exclusion reason: Wrong setting. [pmid: 15662171].
63 Bailey JE, Coombs DW. Effectiveness of an Indonesian model for rapid training of Guatemalan health workers in diarrhea case management. Journal of Community Health. Aug. 1996;21(4):269-76. Exclusion reason: Wrong population. [pmid: 8842889].
64 Baker CM, Miller I, Sitterding M, et al. Acute stroke patients comparing outcomes with and without case management. Nursing Case Management. Sep-Oct. 1998;3(5):196-203. Exclusion reason: Wrong intervention. [pmid: 9832763].
65 Baker DI, Gottschalk M, Eng C, et al. The design and implementation of a restorative care model for home care. Gerontologist. Apr. 2001;41(2):257-63. Exclusion reason: Wrong outcome. [pmid: 11327492].
66 Baldwin LM, Larson EH, Connell FA, et al. The effect of expanding Medicaid prenatal services on birth outcomes. American Journal of Public Health. Nov. 1998;88(11):1623-9. Exclusion reason: Wrong population. [pmid: 9807527].
67 Bane SD. Rural mental health and aging: implication for case management. Journal of Case Management. 1997;6(4):158-61. Exclusion reason: No original data. [pmid: 9644406].
68 Banja JD. Three perspectives on suffering. Case Manager. Nov-Dec. 2006;17(6):21-3. Exclusion reason: No original data. [pmid: 17116535].
69 Banning M. Evaluating practice-based learning specific to the community matron role. British Journal of Community Nursing. 2009;14(2):76-80. Exclusion reason: Wrong outcome. [pmid: 19223814].
70 Banwat EB, Egah DZ, Peter J, et al. Integrating syndromic case management of sexually transmitted diseases into primary healthcare services in Nigeria. Nigerian Journal of Medicine: Journal of the National Association of Resident Doctors of Nigeria. Apr-Jun. 2009;18(2):215-8. Exclusion reason: Wrong population. [pmid: 19630334].
71 Barcelo A, Cafiero E, de Boer M, et al. Using collaborative learning to improve diabetes care and outcomes: the VIDA project. Primary care diabetes. Oct. 2010;4(3):145-53. Exclusion reason: Wrong intervention. [pmid: 20478753].
72 Barefield F. Working case managers' view of the profession. Case Manager. Nov-Dec. 2003;14(6):69-71. Exclusion reason: No original data. [pmid: 14618154].
73 Barger SE. Making the case for a college-run case management practice. Journal of Professional Nursing. Jul-Aug. 2000;16(4):187. Exclusion reason: No original data. [pmid: 10932989].
74 Barker NN, Himchak MV. Environmental issues affecting elder abuse victims in their reception of community based services. Journal of Gerontological Social Work. 2006;48(1-2):233-55. Exclusion reason: Wrong population. [pmid: 17200082].
75 Barney DD, Rosenthal CC, Speier T. Components of successful HIV/AIDS case management in Alaska Native villages. AIDS Education & Prevention. Jun. 2004;16(3):202-17. Exclusion reason: Wrong intervention. [pmid: 15237051].
76 Barrett DL, Secic M, Borowske D. The Gatekeeper Program: proactive identification and case management of at-risk older adults prevents nursing home placement, saving healthcare dollars program evaluation. Home Healthcare Nurse. Mar. 2010;28(3):191-7. Exclusion reason: Wrong intervention. [pmid: 20308813].
77 Barry J, McQuade C, Livingstone T. Using nurse case management to promote self-efficacy in individuals with rheumatoid arthritis. Rehabilitation Nursing. Nov-Dec. 1998;23(6):300-4. Exclusion reason: Wrong outcome. [pmid: 10223032].
78 Bartolozzi PR, Levin J. Strategies in a managed care system: one agency's experience. Journal of Case Management. 1997;6(3):114-8. Exclusion reason: Wrong outcome. [pmid: 9573970].
79 Barton V. When a psychiatric disorder interferes with TB treatment. Journal of the New York State Nurses Association. Mar. 1. 1999;30(1):16-9. Exclusion reason: Wrong population.
80 Bartsch DA, Rodgers VK. Senior Reach outcomes in comparison with the Spokane Gatekeeper program. Care Management Journals. 2009;10(3):82-8. Exclusion reason: Wrong population. [pmid: 19772205].
81 Battersby MW. Health reform through coordinated care: SA HealthPlus. BMJ: British Medical Journal. 2005;330(7492):662-5. Exclusion reason: Wrong intervention. [pmid: 15775001].
82 Bausewein C, Booth S, Gysels M, et al. Non-pharmacological interventions for breathlessness in advanced stages of malignant and non-malignant diseases. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention. [pmid: 18425927].
83 Beaulieu JE, Hickman M. Rural case management: a pilot study. Home Health Care Services Quarterly. 1994;14(4):69-85. Exclusion reason: Wrong outcome. [pmid: 10134031].
84 Bebout RR. The link between inpatient care and case management services. New Directions for Mental Health Services. 1988;(40):53-6. Exclusion reason: Wrong population. [pmid: 3237188].
85 Becker C, Bjornson DC, Kuhle JW. Pharmacist care plans and documentation of follow-up before the Iowa Pharmaceutical Case Management program. Journal of the American Pharmacists Association: JAPhA. May-Jun. 2004;44(3):350-7. Exclusion reason: Wrong intervention. [pmid: 15191245].
86 Bellucci M, Tonges MC, Kopelman R. Doing well by doing good. The case for objective feedback in case management. Journal of Case Management. 1998;7(4):161-6. Exclusion reason: Wrong outcome. [pmid: 10703383].
87 Bender NL. An analysis of the processes and outcomes of coordination of care: A home care organization initiated case management intervention in a Medicare population. 2003:296. Exclusion reason: Wrong intervention.
88 Berdes C. Driving the system: long-term-care coordination in Manitoba, Canada. Journal of Case Management. 1996;5(4):168-72. Exclusion reason: No original data. [pmid: 9110701].
89 Berendt M, Schaefer B, Heglund MJ, et al. Telehealth for effective disease state management. Home Care Provider. Apr. 2001;6(2):67-72. Exclusion reason: Wrong intervention. [pmid: 11295686].
90 Bergen A. Care management revisited: a follow-up study. British Journal of Community Nursing. 2003;8(1):16-23. Exclusion reason: Wrong outcome. [pmid: 12574730].
91 Berger BA. Assessing and interviewing patients for meaningful behavioral change: Part 2. Case Manager. Nov-Dec. 2004;15(6):58-62. quiz 3. Exclusion reason: No original data. [pmid: 15557995].
92 Bergman H, Beland F. Evaluating innovation in the care of Canada's frail elderly population. CMAJ Canadian Medical Association Journal. Feb. 22. 2000;162(4):511-2. Exclusion reason: No original data. [pmid: 10701385].
93 Berg-Weger M, Tebb SS. Caregiver well-being: a strengths-based case management approach. Journal of Case Management. 1998;7(2):67-73. Exclusion reason: No original data. [pmid: 10703370].
94 Berkowitz R, Blank LJ, Powell SK. Strategies to reduce hospitalization in the management of heart failure. Lippincott 's Case Management. Nov-Dec. 2005;10(6 Suppl):S1-15. quiz S6-7. Exclusion reason: Wrong intervention. [pmid: 16314728].
95 Bernabei R, Onder G, Landi F. Comprehensive care for older adults: case management approach. Journal of the American Geriatrics Society. Jun. 2010;58(6):1202-3. Exclusion reason: No original data. [pmid: 20722858].
96 Bernstein RH. New arrows in the quiver for targeting care management: high-risk versus high-opportunity case identification. Journal of Ambulatory Care Management. Jan-Mar. 2007;30(1):39-51. Exclusion reason: Wrong intervention. [pmid: 17170637].
97 Berube D. Case management in the Canadian Forces. Lippincott's Case Management. May-Jun. 2004;9(3):141-6. Exclusion reason: No original data. [pmid: 15252365].
98 Betts G. Primary care. Home truths. Health Service Journal. Jan. 9. 2003;113(5837):26-7. Exclusion reason: No original data. [pmid: 12536902].
99 Bierlein C, Hadjistavropoulos H, Bourgault-Fagnou M, et al. A six-month profile of community case coordinated older adults. Canadian Journal of Nursing Research. Sep. 2006;38(3):32-50. Exclusion reason: Wrong intervention. [pmid: 17037112].
100 Binkin NJ, Vernon AA, Simone PM, et al. Tuberculosis prevention and control activities in the United States: an overview of the organization of tuberculosis services. International Journal of Tuberculosis & Lung Disease. Aug. 1999;3(8):663-74. Exclusion reason: No original data. [pmid: 10460098].
101 Bird D, Morris T. NT clinical. Using community matrons to target long-term conditions. Nursing Times. 2006;102(23):19-20. Exclusion reason: No original data. [pmid: 16784043].
102 Bird M, Llewellyn-Jones RH, Korten A. An evaluation of the effectiveness of a case-specific approach to challenging behaviour associated with dementia. Aging & Mental Health. Jan. 2009;13(1):73-83. Exclusion reason: Wrong intervention. [pmid: 19197692].
103 Birmingham J. Growth hormone therapy in adults: what case managers need to know. Case Manager. Mar-Apr. 2001;12(2):57-63. Exclusion reason: No original data. [pmid: 11244404].
104 Birmingham J. Blending case management components into disease management. Inside Case Management. Aug. 3. 2001;8(5):1-7. Exclusion reason: Wrong outcome.
105 Birmingham J. Discharge planning: a collaboration between provider and payer case managers using Medicare's conditions of participation. Lippincott's Case Management. 2004;9(3):147-51. Exclusion reason: Wrong intervention. [pmid: 15252366].
106 Birmingham J. Patient choice in the discharge planning process. Professional Case Management. 2009;14(6):296-311. Exclusion reason: Wrong intervention. [pmid: 19935347].
107 Birmingham J, Anctil B. Managing the dynamics of collaboration. Case Manager. May-Jun. 2002;13(3):73-7. Exclusion reason: No original data. [pmid: 12011842].
108 Bischof RO, Loh E, Smith RL. Managed care clinical corner: a case of congestive heart failure--the managed care perspective. American Journal of Managed Care. Feb. 1997;3(2):303-6. Exclusion reason: No original data. [pmid: 10169265].
109 Black DA. Case management for elderly people in the community. BMJ. Jan. 6. 2007;334(7583):3-4. Exclusion reason: No original data. [pmid: 17107985].
110 Black K, Fauske J. Exploring influences on community-based case managers' advance care planning practices: facilitators or barriers?. Home Health Care Services Quarterly. 2007;26(2):41-58. Exclusion reason: No original data. [pmid: 17537710].
111 Black K, Fauske J. Measuring case managers' advance care planning practice: translating focus group findings to survey development. Care Management Journals. 2008;9(4):166-76. Exclusion reason: Wrong outcome. [pmid: 19177974].
112 Black K, Osman H. Concerned about client decision-making capacity? Considerations for practice. Care Management Journals. 2005;6(2):50-5. Exclusion reason: No original data. [pmid: 16544865].
113 Black RE. Priority setting in case management based on need and risk. Journal of Case Management. 1995;4(3):79-84. Exclusion reason: Wrong outcome. [pmid: 7580953].
114 Blaha C, Robinson JM, Pugh LC, et al. Longitudinal nursing case management for elderly heart failure patients: notes from the field. Nursing Case Management. Jan-Feb. 2000;5(1):32-6. Exclusion reason: No original data. [pmid: 10855156].
115 Blase NJ, Kaufman JM. Case management in a vertically integrated health care system. HMO Practice. Sep. 1994;8(3):110-4. Exclusion reason: No original data. [pmid: 10157226].
116 Blecher M. Beyond managed care. Hospitals & Health Networks. Sep. 2001;75(9):50-3. Exclusion reason: No original data. [pmid: 11579767].
117 Bocchi EA, Cruz F, Guimaraes G, et al. Long-term prospective, randomized, controlled study using repetitive education at six-month intervals and monitoring for adherence in heart failure outpatients: the REMADHE trial. Circulation. Jul. Heart failure. 2008;1(2):115-24. Exclusion reason: Wrong intervention. [pmid: 19808281].
118 Bodenheimer T. Interventions to improve chronic illness care: evaluating their effectiveness. Disease Management. 2003;6(2):63-71. Exclusion reason: Wrong intervention. [pmid: 14577900].
119 Bodenheimer TB, Berry-Millett R. Care Management of Patients with Complex Health Care Needs The Synthesis Project. December. 2009;19:1-36. [pmid: 22052205]. Exclusion reason: No original data.
120 Boguslawski CA. Patient-focused practice results in early return to work. Professional Case Management. May-Jun. 2008;13(3):181-3. Exclusion reason: No original data. [pmid: 18562917].
121 Boltz M, Harrington C, Kluger M. Nurses Improving Care for Health System Elders (NICHE). American Journal of Nursing. May. 2005;105(5):101-2. Exclusion reason: No original data. [pmid: 15867549].
122 Bonvissuto CA, Kastens JM, Atwell SR. Preparing health care organizations for successful case management programs. Journal of Case Management. 1997;6(2):51-5. Exclusion reason: Wrong outcome. [pmid: 9335724].
123 Boobier S. Community matrons. Nursing Older People. Dec. 2009;21(10):16. Exclusion reason: No original data. [pmid: 20067074].
124 Borgenicht K, Carty E, Feigenbaum LZ. Community resources for frail older patients. Western Journal of Medicine. Oct. 1997;167(4):291-4. Exclusion reason: No original data. [pmid: 9348762].
125 Borglund ST. Case management quality-of-life outcomes for adults with a disability. Rehabilitation Nursing. Nov-Dec. 2008;33(6):260-7. Exclusion reason: Wrong intervention. [pmid: 19024241].
126 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Education & Counseling. Apr. 2005;57(1):5-14. Exclusion reason: Wrong population. [pmid: 15797147].
127 Bott DM, Kapp MC, Johnson LB, et al. Disease management for chronically ill beneficiaries in traditional Medicare. Health Affairs. Jan-Feb. 2009;28(1):86-98. Exclusion reason: Wrong intervention. [pmid: 19124858].
128 Boult C, Green AF, Boult LB, et al. Successful models of comprehensive care for older adults with chronic conditions: evidence for theinstitute of medicine's “Retooling for an aging America” report. Journal of the American Geriatrics Society. 2009;57(12):2328-37. Exclusion reason: No original data. [pmid: 20121991].
129 Boult C, Kane RL, Pacala JT, et al. Innovative healthcare for chronically ill older persons: results of a national survey. American Journal of Managed Care. 1999;5(9):1162-72. Exclusion reason: No original data. [pmid: 10621082].
130 Boult C, Rassen J, Rassen A, et al. The effect of case management on the costs of health care for enrollees in Medicare Plus Choice plans: a randomized trial. Journal of the American Geriatrics Society. Aug. 2000;48(8):996-1001. Exclusion reason: Wrong intervention. [pmid: 10968308].
131 Bound J, Gardiner P. Hospital readmissions. Return to sender. Health Service Journal. Mar. 28. 2002;112(5798):26-7. Exclusion reason: No original data. [pmid: 11963313].
132 Bourbeau J. The role of collaborative self-management in pulmonary rehabilitation. Semin Respir Crit Care Med. Dec. 2009;30(6):700-7. Exclusion reason: No original data. [pmid: 19941227].
133 Bourbonniere M, Kagan SH. Nursing intervention and older adults who have cancer: specific science and evidence based practice. Nursing Clinics of North America. Sep. 2004;39(3):529-43. Exclusion reason: No original data. [pmid: 15331300].
134 Bourdeaux L, Matthews L, Richards NL, et al. Comparative study of case management program for patients with syncope. Journal of Nursing Care Quality. Apr-Jun. 2005;20(2):140-4. Exclusion reason: Wrong setting. [pmid: 15839293].
135 Bowers B, Esmond S, Canales M. Approaches to case management supervision. Administration in Social Work. 1999;23(2):29-49. Exclusion reason: Wrong outcome.
136 Boyd ML, Fisher B, Davidson AW, et al. Community-based case management for chronically ill older adults. Nursing Management. Nov. 1996;27(11):31-2. Exclusion reason: Wrong population. [pmid: 8954445].
137 Bozzo J, Carlson B, Diers D. Using hospital data systems to find target populations: new tools for clinical nurse specialists. Clinical Nurse Specialist. Mar. 1998;12(2):86-91. Exclusion reason: Wrong intervention. [pmid: 9708115].
138 Bradley EH, Bogardus ST Jr., van Doorn C, et al. Goals in geriatric assessment: are we measuring the right outcomes?. Gerontologist. Apr. 2000;40(2):191-6. Exclusion reason: Wrong outcome. [pmid: 10820921].
139 Bradley PM, Lindsay B. Care delivery and self-management strategies for adults with epilepsy. Cochrane Database of Systematic Reviews. 2011;(1). Exclusion reason: Wrong intervention.
140 Branch LG, Coulam RF, Zimmerman YA. The PACE evaluation: initial findings. Gerontologist. Jun. 1995;35(3):349-59. Exclusion reason: Wrong outcome. [pmid: 7622088].
141 Brandis M, Stacom R. Long-term care in the home for people with multiple sclerosis. Care Management Journals. 2009;10(3):128-37. Exclusion reason: Wrong intervention. [pmid: 19772211].
142 Braxton BA. The impact of managed care on elders. Case Manager. Nov-Dec. 2002;13(6):68-71. Exclusion reason: No original data. [pmid: 12439468].
143 Bray P, Thompson D, Wynn JD, et al. Confronting disparities in diabetes care: the clinical effectiveness of redesigning care management for minority patients in rural primary care practices. Journal of Rural Health. 2005;21(4):317-21. Exclusion reason: Wrong intervention. [pmid: 16294654].
144 Bremer A. A description of community health nursing practice with the community-based elderly. Journal of Community Health Nursing. 1989;6(3):173-84. Exclusion reason: Wrong outcome. [pmid: 2778477].
145 Briones J, Carlino M. A case study in interdisciplinary care of the critically ill. AACN Clinical Issues. Aug. 1998;9(3):409-15. Exclusion reason: No original data. [pmid: 9855879].
146 Brockopp DY, Porter M, Kinnaird S, et al. Fiscal and clinical evaluation of patient care. A case management model for the future. Journal of Nursing Administration. Sep. 1992;22(9):23-7. Exclusion reason: Wrong setting. [pmid: 1432238].
147 Browdie R. Pennsylvania's experience: Area Agencies on Aging and home health agencies. Caring. Mar. 1992;11(3):70-2. Exclusion reason: No original data. [pmid: 10117087].
148 Brown JA, Von Roenn JH. Symptom management in the older adult. Clinics in Geriatric Medicine. Nov. 2004;20(4):621-40. Exclusion reason: Wrong intervention. [pmid: 15541616].
149 Brown K, Stainer K, Stewart J, et al. Older people with complex long-term health conditions. Their views on the community matron service: a qualitative study. Quality in Primary Care. 2008;16(6):409-17. Exclusion reason: Wrong outcome. [pmid: 19094416].
150 Brown RS, Dale SB. The research design and methodological issues for the Cash and Counseling Evaluation. Health Services Research. Feb. 2007;42(1 Pt 2):414-45. Exclusion reason: Wrong intervention. [pmid: 17244291].
151 Browne R, Biancolillo K. Fusing roles--the ambulatory care nurse as case manager. Nursing Management. Sep. 1997;28(9):30-1. Exclusion reason: No original data. [pmid: 9335836].
152 Buckley B, Byrne M, Smith S. Service organisation for the secondary prevention of ischaemic heart disease in primary care. Cochrane Database of Systematic Reviews. Mar. 2010;17(3):CD006772. Exclusion reason: Wrong intervention. [pmid: 20238349].
153 Bull MJ. Discharge planning for older people: a review of current research. British Journal of Community Nursing. Feb. 2000;5(2):70-4. Exclusion reason: Wrong intervention. [pmid: 11125455].
154 Bunch D. The road to wellness: RT case managers at Kaiser facilities provide “TLC” to chronic disease patients. AARC Times. 2002;26(11):28. Exclusion reason: No original data.
155 Bunch D. The fabric of success: weaving outcomes measurement into the case management programs shows their worth. AARC Times. 2004;28(2):32-5. Exclusion reason: No original data.
156 Bunch D. VA researchers use respiratory therapists for COPD disease management study. AARC Times. 2010;34(2):160-3. Exclusion reason: No original data.
157 Burgess MJ. New York State Plan on Aging. Care Management Journals. 2009;10(1):21-7. Exclusion reason: No original data. [pmid: 19353984].
158 Burke SM. The case manager's view. Journal of Clinical Ethics. 2006;17(1):83-4. Exclusion reason: Wrong setting. [pmid: 16689119].
159 Burns LR, Lamb GS, Wholey DR. Impact of integrated community nursing services on hospital utilization and costs in a Medicare risk plan. Inquiry. 1996;33(1):30-41. Exclusion reason: Wrong intervention. [pmid: 8774372].
160 Campagna V. Coordinating important message notifications. Hospital Case Management. Nov. 2007;15(11):164-6. Exclusion reason: No original data. [pmid: 17982831].
161 Campbell C, Craig J, Eggert J, et al. Implementing and measuring the impact of patient navigation at a comprehensive community cancer center. Oncology Nursing Forum. Jan. 2010;37(1):61-8. Exclusion reason: Wrong intervention. [pmid: 20044340].
162 Campbell J, Kaitfors S. Evaluation of an intensive case management program for short-term nursing home residents. Journal of Case Management. Fall. 1993;2(3):91-5. Exclusion reason: Wrong setting. [pmid: 8130751].
163 Cantor M, Rehr H, Trotz V, Workshop II. Case management and family involvement. Mount Sinai Journal of Medicine. Nov-Dec. 1981;48(6):566-8. Exclusion reason: No original data. [pmid: 6977716].
164 Capitman J. Effective coordination of medical and supportive services. Journal of Aging & Health. 2003;15(1):124-64. Exclusion reason: No original data. [pmid: 12611412].
165 Capitman JA. Verve not ERVs for care planners. Gerontologist. Dec. 2003;43(6):806-7. discussion 7. Exclusion reason: No original data. [pmid: 14704378].
166 Capitman JA, Haskins B, Bernstein J. Case management approaches in coordinated community-oriented long-term care demonstrations. Gerontologist. Aug. 1986;26(4):398-404. Exclusion reason: Background. [pmid: 3089878].
167 Caro FG, Gottlieb AS, Safran-Norton C. Performance-based home care for the elderly: the quality of circumstance protocol. Home Health Care Services Quarterly. 2000;18(4):1-48. Exclusion reason: No original data. [pmid: 11216437].
168 Carr DD. Protocols in practice Case management as a triad in long-term care: a collaborative approach. Lippincott's Case Management. 2003;8(5):224-7. Exclusion reason: No original data. [pmid: 14517502].
169 Carr DD. Implications for case management: ensuring access and delivery of quality health care to undocumented immigrant populations. Lippincott 's Case Management. Jul-Aug. 2006;11(4):195-204. quiz 5-6. Exclusion reason: No original data. [pmid: 16926691].
170 Carr DD. Case managers optimize patient safety by facilitating effective care transitions. Professional Case Management. Mar-Apr. 2007;12(2):70-80. quiz 1-2. Exclusion reason: No original data. [pmid: 17413671].
171 Carver T. www.alternativecasemanagement.now. Nursing Management. Aug. 2001;32(8):33-5. [pmid: 15129527]. Exclusion reason: No original data.
172 Casalino L, Gillies RR, Shortell SM, et al. External incentives, information technology, and organized processes to improve health care quality for patients with chronic diseases. JAMA: Journal of the American Medical Association. 2003;289(4):434-41. Exclusion reason: Wrong intervention. [pmid: 12533122].
173 Casuto D. The influence of special needs trusts on case management practice. Case Manager. Jul-Aug. 2000;11(4):64-6. Exclusion reason: Wrong population. [pmid: 11935615].
174 Centre for Reviews and Dissemination. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission (Structured abstract). Database. (3). Exclusion reason: Wrong setting.
175 Centre for Reviews and Dissemination. A systematic review of randomized trials of disease management programs in heart failure (Structured abstract). Database. (3). Exclusion reason: No original data.
176 Centre for Reviews and Dissemination. Case management for patients with congestive heart failure under ambulatory care: a critical review (Provisional abstract). Database. (3). Exclusion reason: Wrong intervention.
177 Centre for Reviews and Dissemination. Case management programs in primary care (Structured abstract). Database. (3). Exclusion reason: No original data.
178 Centre for Reviews and Dissemination. Case management: a critical review of the outcome literature (Structured abstract). Database. (3). Exclusion reason: Wrong population.
179 Centre for Reviews and Dissemination. Comprehensive multidisciplinary programs for the management of patients with congestive heart failure (Structured abstract). Database. (3). Exclusion reason: No original data.
180 Centre for Reviews and Dissemination. Do geriatric interventions reduce emergency department visits: a systematic review (Structured abstract). Database. (3). Exclusion reason: No original data.
181 Centre for Reviews and Dissemination. Do innovative models of health care delivery improve quality of care for selected vulnerable populations: a systematic review (Structured abstract). Database. (3). Exclusion reason: Wrong population.
182 Centre for Reviews and Dissemination. Effectiveness of innovations in nurse led chronic disease management for patients with chronic obstructive pulmonary disease: systematic review of evidence (Structured abstract). Database. (3). Exclusion reason: No original data.
183 Centre for Reviews and Dissemination. Effects of case management for frail older people or those with chronic illness: a systematic review (Structured abstract). Database. (3). Exclusion reason: No original data.
184 Centre for Reviews and Dissemination. Impact of home care on hospital days: a meta analysis (Structured abstract). Database. (3). Exclusion reason: Wrong intervention.
185 Centre for Reviews and Dissemination. Interventions to improve access to health and social care after discharge from hospital: a systematic review (Provisional abstract). Database. (3). Exclusion reason: Wrong intervention.
186 Centre for Reviews and Dissemination. Review of effectiveness and outcomes: home care (Structured abstract). Database. (3). Exclusion reason: Wrong intervention.
187 Centre for Reviews and Dissemination. Review of nurse home visiting interventions for community-dwelling older persons with existing disability (Structured abstract). Database. (3). Exclusion reason: No original data.
188 Centre for Reviews and Dissemination. Interventions to improve the health of the homeless: a systematic review (Structured abstract). Database. (3). Exclusion reason: No original data.
189 Centre for Reviews and Dissemination. A literature review of cardiovascular disease management programs in managed care populations (Structured abstract). Database. (3). Exclusion reason: Background.
190 Centre for Reviews and Dissemination. Directly observed therapy for treatment completion of pulmonary tuberculosis: consensus statement of the Public Health Tuberculosis Guidelines Panel (Structured abstract). Database. (3). Exclusion reason: Background.
191 Centre for Reviews and Dissemination. International experiments in integrated care for the elderly: a synthesis of the evidence (Structured abstract). Database. (3). Exclusion reason: Background.
192 Centre for Reviews and Dissemination. Outcome effectiveness of community health workers: an integrative literature review (Structured abstract). Database. (3). Exclusion reason: Background.
193 Centre for Reviews and Dissemination. Systematic review of the effects of chronic disease management on quality-of-life in people with chronic obstructive pulmonary disease (Structured abstract). Database. (3). Exclusion reason: Background.
194 Centre for Reviews and Dissemination. The effectiveness and efficiency of home-based nursing health promotion for older people: a review of the literature (Structured abstract). Database. (3). Exclusion reason: Background.
195 Centre for Reviews and Dissemination. The effectiveness of home visiting as a delivery strategy for public health nursing interventions: a systematic overview (Structured abstract). Database. (3). Exclusion reason: Background.
196 Centre for Reviews and Dissemination. A systematic review of integrated use of disease-management interventions in asthma and COPD (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(3). Exclusion reason: No original data.
197 Centre for Reviews and Dissemination. Supporting the dementia family caregiver: the effect of home care intervention on general well-being (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(3). Exclusion reason: No original data.
198 Centre for Reviews and Dissemination. Interventions to prevent disability in frail community-dwelling older persons: an overview (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(3). Exclusion reason: No original data.
199 Centre for Reviews and Dissemination. An integrative review and meta-synthesis of the scope and impact of intensive care liaison and outreach services (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(3). Exclusion reason: No original data.
200 Centre for Reviews and Dissemination. Implementation of integrated care for patients with cancer: a systematic review of interventions and effects (Structured abstract). Database of Abstracts of Reviews of Effects. 2011;(3). Exclusion reason: No original data.
201 Challis D, Darton R, Hughes J, et al. Emerging models of care management for older people and those with mental health problems in the United Kingdom. Journal of Case Management. 1998;7(4):153-60. Exclusion reason: Wrong outcome. [pmid: 10703382].
202 Challis D, Darton R, Johnson L, et al. An evaluation of an alternative to long-stay hospital care for frail elderly patients: I. The model of care. Age & Ageing. Jul. 1991;20(4):236-44. Exclusion reason: Wrong outcome. [pmid: 1656717].
203 Chan D, Absher D, Sabatier S. Recipients in need of ancillary services and their receipt of HIV medical care in California. AIDS Care. Aug. Suppl 1. 2002;14:S73-83. Exclusion reason: Wrong outcome. [pmid: 12204143].
204 Chapko MK, Manheim LM, Guihan M, et al. Assisted living pilot program: utilization and cost findings. Journal of Aging & Health. Feb. 2009;21(1):208-25. Exclusion reason: Wrong intervention. [pmid: 19144975].
205 Chatman VS, Turner-Friley S. Providing long term health care to the minority aging poor: a case management approach. Pride Institute Journal of Long Term Home Health Care. 1988;7(4):10-3. Exclusion reason: Wrong outcome. [pmid: 10312779].
206 Chavannes NH, Grijsen M, van den Akker M, et al. Integrated disease management improves one-year quality of life in primary care COPD patients: a controlled clinical trial. Primary Care Respiratory Journal. Sep. 2009;18(3):171-6. Exclusion reason: Wrong intervention. [pmid: 19142557].
207 Chen LK, Chen YM, Hwang SJ, et al. Effectiveness of community hospital-based post-acute care on functional recovery and 12-month mortality in older patients: a prospective cohort study. Annals of Medicine. Dec. 2010;42(8):630-6. Exclusion reason: Wrong intervention. [pmid: 20883138].
208 Cherin DA. The transprofessional model of terminal care: reforming end-stage care in HIV/AIDS. 1996:319. Exclusion reason: No original data.
209 Cherin DA, Simmons WJ, Hillary K. The transprofessional model: blending intents in terminal care of AIDS. Home Health Care Services Quarterly. 1998;17(1):31-54. Exclusion reason: Wrong outcome. [pmid: 10338807].
210 Chernesky RH, Grube B. HIV/AIDS case management: views from the frontline. Care Management Journals. Winter. 1999;1(1):19-28. Exclusion reason: Wrong outcome. [pmid: 10835793].
211 Chin JJ, Kang E, Kim JH, et al. Serving Asians and Pacific Islanders with HIV/AIDS: challenges and lessons learned. Journal of Health Care for the Poor & Underserved. Nov. 2006;17(4):910-27. Exclusion reason: Wrong intervention. [pmid: 17242538].
212 Chin SM. “Acute care case management and linkage with community services for continuity of care” -- the Tan Tock Seng Hospital (TTSH) experience. 5th Asia & Pacific Nurses Convention (ASPAN), 14-17 Nov 2001, the Mandarin Singapore. Exploring the Web of nursing: integrating touch & tech. 2001:66. Exclusion reason: Unable to locate.
213 Chiu WK, Newcomer R. A systematic review of nurse-assisted case management to improve hospital discharge transition outcomes for the elderly. Professional Case Management. Nov-Dec. 2007;12(6):330-6. quiz 7-8. Exclusion reason: Wrong intervention. [pmid: 18030153].
214 Choe HM, Mitrovich S, Dubay D, et al. Proactive case management of high-risk patients with type 2 diabetes mellitus by a clinical pharmacist: a randomized controlled trial. American Journal of Managed Care. Apr. 2005;11(4):253-60. Exclusion reason: Wrong population. [pmid: 15839185].
215 Chow SKY. The effects of a nurse-led case management programme on patients undergoing peritoneal dialysis: a randomized controlled trial. Journal of Advanced Nursing. 2006. Aug. Exclusion reason: Wrong intervention. [pmid: 20557392].
216 Chow SKY, Wong FKY, Chan TMF, et al. Community nursing services for postdischarge chronically ill patients. Journal of Clinical Nursing. Apr. 2008;17(7B):260-71. Exclusion reason: Wrong intervention. [pmid: 18578802].
217 Chrischilles E. Evaluation of the Iowa Medicaid pharmaceutical case management program. Journal of the American Pharmacists Association: JAPhA. May-Jun. 2004;44(3):337-49. Exclusion reason: Wrong intervention. [pmid: 15191244].
218 Christenson D, Moore I. Intensive case management in Alzheimer's disease home care: an interim report on the Cincinnati (Ohio) Medicare Alzheimer's Project. Journal of Long Term Home Health Care. 1994;13(4):43-52. Exclusion reason: No original data. [pmid: 10172192].
219 Christianson JB, Applebaum R, Carcagno G, et al. Organizing and delivering case management services: lessons from the National Long Term Care Channeling Demonstration. Home Health Care Services Quarterly. 1988;9(1):7-27. Exclusion reason: No original data. [pmid: 10312879].
220 Christianson JB, Pietz L, Taylor R, et al. Implementing programs for chronic illness management: the case of hypertension services. Joint Commission Journal on Quality Improvement. 1997;23(11):593-601. Exclusion reason: Wrong intervention. [pmid: 9407263].
221 Claiborne N, Vandenburgh H. Social workers' role in disease management. Health & Social Work. 2001;26(4):217-25. Exclusion reason: No original data. [pmid: 11758863].
222 Cohen CA. The SMARTT (Sunnybrook Memory Assessment Research Treatment and Training) Program: planning for dementia care. Healthcare Management Forum. 1997;10(3):49-51. Exclusion reason: Wrong outcome. [pmid: 10173498].
223 Coleman EA, Parry C, Chalmers S, et al. The Care Transitions Intervention: Results of a Randomized Controlled Trial. Archives of Internal Medicine. Sep. 25. 2006;166(17):1822-8. Exclusion reason: Wrong intervention. [pmid: 17000937].
224 Coleman J. Social health maintenance organizations, Part II. Case Manager. Mar-Apr. 2001;12(2):42-7. Exclusion reason: No original data. [pmid: 11244401].
225 Coleman JR. Aging and disability demand extended model of case management in SHMOs, PACEs, and HMOs. Case Manager. Jan-Feb. 2002;13(1):28-30. Exclusion reason: Wrong intervention. [pmid: 11818905].
226 Coleman JR. MCO trends. Case management imbedded into disease management: the formula for effective disease management in HMOs and IDSs… integrated delivery systems. Case Manager. Nov-Dec. 2005;16(6):40-2. Exclusion reason: No original data. [pmid: 16326322].
227 Commission MPA. A Data Book: Healthcare Spending and the Medicare Program. 2009. Exclusion reason: Wrong intervention.
228 Corazzini K. How state-funded home care programs respond to changes in Medicare home health care: resource allocation decisions on the front line. Health Services Research. Oct. 2003;38(5):1263-81. Exclusion reason: Wrong intervention. [pmid: 14596390].
229 Corbett HM, Lim WK, Davis SJ, et al. Care coordination in the Emergency Department: improving outcomes for older patients. Australian Health Review. Feb. 2005;29(1):43-50. Exclusion reason: Wrong setting. [pmid: 15683355].
230 Couch C, Sheffield P, Gerthoffer T, et al. Clinical outcomes in patients with type 2 diabetes managed by a diabetes resource nurse in a primary care practice. Baylor University Medical Center Proceedings. Jul. 2003;16(3):336-40. Exclusion reason: Wrong intervention. [pmid: 16278705].
231 Courtney L, Gordon M, Romer L. A clinical path for adult diabetes. Diabetes Educator. Nov-Dec. 1997;23(6):664-71. Exclusion reason: Wrong intervention. [pmid: 9416030].
232 Craw JA, Gardner LI, Marks G, et al. Brief strengths-based case management promotes entry into HIV medical care: results of the antiretroviral treatment access study-II. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Apr. 15. 2008;47(5):597-606. Exclusion reason: Wrong intervention. [pmid: 18285714].
233 Crawley WD. Case management: improving outcomes of care for ischemic stroke patients. MEDSURG Nursing. Aug. 1996;5(4):239-44. Exclusion reason: Wrong setting. [pmid: 8852193].
234 Crosby M, Gambrill L, Trembly L, et al. The challenges of providing case management in a Medicaid environment. Case Manager. May-Jun. 2000;11(3):69-72. Exclusion reason: No original data. [pmid: 11935644].
235 Crotty M, Rowett D, Spurling L, et al. Does the addition of a pharmacist transition coordinator improve evidence-based medication management and health outcomes in older adults moving from the hospital to a long-term care facility? Results of a randomized, controlled trial. American Journal of Geriatric Pharmacotherapy. Dec. 2004;2(4):257-64. Exclusion reason: Wrong intervention. [pmid: 15903284].
236 Cunningham CO, Sanchez JP, Li X, et al. Medical and support service utilization in a medical program targeting marginalized HIV-infected individuals. Journal of Health Care for the Poor & Underserved. Aug. 2008;19(3):981-90. Exclusion reason: Wrong intervention. [pmid: 18677084].
237 Cunningham WE, Wong M, Hays RD. Case management and health-related quality of life outcomes in a national sample of persons with HIV/AIDS. Journal of the National Medical Association. Jul. 2008;100(7):840-7. Exclusion reason: Wrong intervention. [pmid: 18672562].
238 Curiale V, Cella A, Luzzani M, et al. Home-based palliative care for adults with cancer. Cochrane Database of Systematic Reviews. 2011;(1). Exclusion reason: Wrong intervention.
239 Dahl Bh DR. In view of health technology assessment: what is the effect of case management for patients with severe COPD? [Abstract]. American Thoracic Society International Conference. May. 2009. Exclusion reason: No original data.
240 Dale SB, Brown RS. How does Cash and Counseling affect costs?. Health Services Research. Feb. 2007;42(1 Pt 2):488-509. Exclusion reason: Wrong intervention. [pmid: 17244294].
241 Daly GM, Mitchell RD. Case management in the community setting. Nursing Clinics of North America. Sep. 1996;31(3):527-34. Exclusion reason: No original data. [pmid: 8751786].
242 Dammann M, Patel S. Enhancing the case manager's role through early identification of at-risk members. Care Management Journals. 1999;1(2):98-104. Exclusion reason: No original data. [pmid: 10644293].
243 Dang S, Dimmick S, Kelkar G. Evaluating the evidence base for the use of home telehealth remote monitoring in elderly with heart failure. Telemedicine Journal & E-Health. Oct. 2009;15(8):783-96. Exclusion reason: Wrong intervention. [pmid: 19831704].
244 Daniels S. Introducing HCM v3 0: a standard model for hospital case management practice. Professional Case Management. May-Jun. 2011;16(3):109-27. Exclusion reason: Wrong intervention. [pmid: 21475053].
245 Dant T, Gearing B. Keyworkers for elderly people in the community: case managers and care coordinators. Journal of Social Policy. Jul. 1990;19(3):331-60. Exclusion reason: No original data. [pmid: 10106906].
246 Davidson G, Moscovice I, McCaffrey D. Allocative efficiency of case managers for the elderly. Health Services Research. Oct. 1989;24(4):539-54. Exclusion reason: Wrong intervention. [pmid: 2681082].
247 Davis C, Darby K, Likes W, et al. Social workers as patient navigators for breast cancer survivors: what do African-American medically underserved women think of this idea?. Social Work in Health Care. Aug-Sep. 2009;48(6):561-78. Exclusion reason: Wrong outcome. [pmid: 19860292].
248 DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Annals of internal medicine. May. 1994;120(9):721-9. Exclusion reason: Wrong population. [pmid: 8147544].
249 Dedhia P, Kravet S, Bulger J, et al. A quality improvement intervention to facilitate the transition of older adults from three hospitals back to their homes. Journal of the American Geriatrics Society. Sep. 2009;57(9):1540-6. Exclusion reason: Wrong intervention. [pmid: 19694865].
250 Degenholtz H, Kane RA, Kivnick HQ. Care-related preferences and values of elderly community-based LTC consumers: can case managers learn what's important to clients?. Gerontologist. Dec. 1997;37(6):767-76. Exclusion reason: Wrong outcome. [pmid: 9432993].
251 Del Sindaco D, Pulignano G, Minardi G, et al. Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. Journal of Cardiovascular Medicine. May. 2007;8(5):324-9. Exclusion reason: Wrong intervention. [pmid: 17443097].
252 Delaronde S. Using case management to increase anti-inflammatory medication use among a managed care population with asthma. Journal of Asthma. Feb. 2002;39(1):55-63. Exclusion reason: Wrong intervention. [pmid: 11883740].
253 Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. American Journal of Managed Care. Jun. 2005;11(6):361-8. Exclusion reason: Wrong intervention. [pmid: 15974555].
254 Dick J, Clarke M, van Zyl H, et al. Primary health care nurses implement and evaluate a community outreach approach to health care in the South African agricultural sector. International nursing review. Dec. 2007;54(4):383-90. Exclusion reason: Wrong intervention. [pmid: 17958668].
255 Dinelli DL, Higgins JC. Case management of asthma for family practice patients: a pilot study. Military Medicine. Mar. 2002;167(3):231-4. Exclusion reason: Wrong population. [pmid: 11901573].
256 Dissemination. A new approach to disease management for seniors. Hospital Case Management. Aug. 1997;5(8):136-9. Exclusion reason: No original data. [pmid: 10169509].
257 Dissemination. Essential components of geriatric care provided through health maintenance organizations. The HMO Workgroup on Care Management. Journal of the American Geriatrics Society. Mar. 1998;46(3):303-8. Exclusion reason: Wrong intervention. [pmid: 9514376].
258 Dissemination. Placing facilitator in ED cuts avoidable hospital stays. Clinical Resource Management. Feb. 2001;2(2):17-20. Exclusion reason: No original data. [pmid: 11246804].
259 Ditusa L, Luzier AB, Brady PG, et al. A pharmacy-based approach to cholesterol management. American Journal of Managed Care. Oct. 2001;7(10):973-9. Exclusion reason: Wrong intervention. [pmid: 11669361].
260 Diwan S. Allocation of case management resources in long-term care: predicting high use of case management time. Gerontologist. Oct. 1999;39(5):580-90. Exclusion reason: Wrong outcome. [pmid: 10568082].
261 Diwan S, Hougham GW, Sachs GA. Strain experienced by caregivers of dementia patients receiving palliative care: findings from the Palliative Excellence in Alzheimer Care Efforts (PEACE) Program. Journal of Palliative Medicine. Dec. 2004;7(6):797-807. Exclusion reason: Wrong intervention. [pmid: 15684847].
262 Diwan S, Ivy C, Merino D, et al. Assessing need for intensive case management in long-term care. Gerontologist. Oct. 2001;41(5):680-6. Exclusion reason: Wrong outcome. [pmid: 11574713].
263 Diwan S, Phillips VL. Agitation and dementia-related problem behaviors and case management in long-term care. International Psychogeriatrics. Mar. 2001;13(1):5-21. Exclusion reason: Wrong outcome. [pmid: 11352334].
264 Dolen L. Models of case management in long term home health care. The evolution of for-profit geriatric care management. Journal of Long Term Home Health Care. 1995;14(2):17-24. Exclusion reason: Wrong intervention. [pmid: 10142951].
265 Dollard VM. Postacute care organizations: a solution for Medicare risk. HMOs Managed Care Quarterly. 1999;7(1):52-8. Exclusion reason: No original data. [pmid: 10350797].
266 Donie JF. The relationship between diabetes and depression: improving the effectiveness of case management interventions. Lippincott 's Case Management. Jul-Aug. 2004;9(4):177-83. Exclusion reason: Wrong population. [pmid: 15273603].
267 Dorr DA, Wilcox A, Burns L, et al. Implementing a multidisease chronic care model in primary care using people and technology. Disease Management. Feb. 2006;9(1):1-15. Exclusion reason: No original data. [pmid: 16466338].
268 Dorr DA, Wilcox A, McConnell KJ, et al. Productivity enhancement for primary care providers using multicondition care management. American Journal of Managed Care. Jan. 2007;13(1):22-8. Exclusion reason: Wrong outcome. [pmid: 17227200].
269 Dorsinville MS. Case management of tuberculosis in New York City. International Journal of Tuberculosis & Lung Disease. Sep. 1998;2(9 Suppl 1):S46-52. Exclusion reason: Wrong intervention. [pmid: 9755965].
270 Douglas SL, Daly BJ, Kelley CG, et al. Chronically critically ill patients: health-related quality of life and resource use after a disease management intervention. American Journal of Critical Care. 2007;16(5):447-57. Exclusion reason: Wrong setting. [pmid: 17724242].
271 Drennan V, Goodman C. Nurse-led case management for older people with long-term conditions. British Journal of Community Nursing. Dec. 2004;9(12):527-33. Exclusion reason: No original data. [pmid: 15655487].
272 Drennan V, Iliffe S, Tai SS, et al. Can primary care identify an ‘at risk’ group in the older population. British Journal of Community Nursing. Apr. 2007;12(4):142-8. Exclusion reason: Wrong intervention. [pmid: 17505328].
273 Duke SAS, Colagiuri S, Colagiuri R. Individual patient education for people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. Jan. 2009;21(1):CD005268. Exclusion reason: Wrong intervention. [pmid: 19160249].
274 Dunagan WC, Littenberg B, Ewald GA, et al. Randomized trial of a nurse-administered, telephone-based disease management program for patients with heart failure. Journal of Cardiac Failure. Jun. 2005;11(5):358-65. Exclusion reason: Wrong intervention. [pmid: 15948086].
275 Dwan J. The value of RCP asthma/COPD case managers, a randomised control trial. Respiratory Care. 2001;46(10):1137. Exclusion reason: No original data.
276 Dyeson TB, Murphy J, Stryker K. Demographic and psychosocial characteristics of cognitively-intact chronically Ill elders receiving home health services. Home Health Care Services Quarterly. 1999;18(2):1-25. Exclusion reason: Wrong intervention. [pmid: 11066726].
277 Eaton MK. Nurse and client perceptions of home health wound care effectiveness after a change in Medicare reimbursement. Policy, Politics & Nursing Practice. 2005;6(4):285-95. Exclusion reason: Wrong outcome. [pmid: 16443983].
278 Ebener MK, Baugh K, Formella NM. Proving that less is more: linking resources to outcomes. Journal of nursing care quality. Jan. 1996;10(2):1-9. Exclusion reason: Wrong setting. [pmid: 8562983].
279 Edwards CS. Design and implementation of a comprehensive heart failure management program. Journal of Healthcare Management. Nov-Dec. 2005;50(6):411-6. Exclusion reason: No original data. [pmid: 16370127].
280 Edwards DF, Baum CM, Meisel M, et al. Home-based multidisciplinary diagnosis and treatment of inner-city elders with dementia. Gerontologist. Aug. 1999;39(4):483-8. Exclusion reason: Wrong intervention. [pmid: 10495587].
281 Effing T, Monninkhof EEM, van der Valk PPDLPM, et al. Self-management education for patients with chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention.
282 Egan E, Clavarino A, Burridge L, et al. A randomized control trial of nursing-based case management for patients with chronic obstructive pulmonary disease. Lippincott 's Case Management. Sep-Oct. 2002;7(5):170-9. Exclusion reason: Wrong setting. [pmid: 12394555].
283 Einstadter D, Cebul RD, Franta PR. Effect of a nurse case manager on postdischarge follow-up. Journal of General Internal Medicine. Nov. 1996;11(11):684-8. Exclusion reason: Wrong setting. [pmid: 9120655].
284 Eklund K, Wilhelmson K. Outcomes of coordinated and integrated interventions targeting frail elderly people: a systematic review of randomised controlled trials. Health & Social Care in the Community. Sep. 2009;17(5):447-58. Exclusion reason: No original data. [pmid: 19245421].
285 Elwyn G, Williams M, Roberts C, et al. Case management by nurses in primary care: analysis of 73 ‘success stories’. Quality in Primary Care. 2008;16(2):75-82. Exclusion reason: No original data. [pmid: 18700083].
286 Emlet CA, Gusz SS. Service use patterns in HIV/AIDS case management: a five-year study. Journal of Case Management. 1998;7(1):3-9. Exclusion reason: Wrong outcome. [pmid: 9764020].
287 Endicott L, Corsello P, Prinzi M, et al. Operating a sustainable disease management program for chronic obstructive pulmonary disease. Lippincott 's Case Management. Nov-Dec. 2003;8(6):252-62. quiz 63-4. Exclusion reason: Wrong outcome. [pmid: 14646783].
288 Enguidanos S. Integrating behavior change theory into geriatric case management practice. Home Health Care Services Quarterly. 2001;20(1):67-83. Exclusion reason: No original data. [pmid: 11878076].
289 Enguidanos SM, Gibbs NE, Simmons WJ, et al. Kaiser Permanente community partners project: improving geriatric care management practices. Journal of the American Geriatrics Society. May. 2003;51(5):710-4. Exclusion reason: No original data. [pmid: 12752849].
290 Esposito D, Taylor EF, Gold M. Using qualitative and quantitative methods to evaluate small-scale disease management pilot programs. Population Health Management. Feb. 2009;12(1):3-15. Exclusion reason: Wrong intervention. [pmid: 19216674].
291 Esposito L. Home health case management: rural caregiving. Home Healthcare Nurse. May-Jun. 1994;12(3):38-43. Exclusion reason: No original data. [pmid: 8056606].
292 Essex EL, Biegel DE. Older case management clients with younger family members in need of care: interdependencies and well-being. Care Management Journals. 2007;8(4):162-70. Exclusion reason: Wrong intervention. [pmid: 18236955].
293 Farris KB, Cote I, Feeny D, et al. Enhancing primary care for complex patients. Demonstration project using multidisciplinary teams. Canadian Family Physician. Jul. 2004;50:998-1003. Exclusion reason: Wrong intervention. [pmid: 15317232].
294 Fazzi R, Agoglia R, Mazza G, et al. Final report: the Briggs National Quality Improvement/Hospitalization Reduction Study. Caring. 2006;25(2):70-5. Exclusion reason: No original data. [pmid: 16579288].
295 Feldman C, Olberding L, Shortridge L, et al. Decision making in case management of home healthcare clients. Journal of Nursing Administration. Jan. 1993;23(1):33-8. Exclusion reason: Wrong intervention. [pmid: 8433170].
296 Feliciano MS. Determining requirements for case management in long-term health care. Journal of Long Term Home Health Care. 1995;14(2):44-51. Exclusion reason: No original data. [pmid: 10142955].
297 Feltes M, Wetle T, Clemens E, et al. Case managers and physicians: communication and perceived problems. Journal of the American Geriatrics Society. Jan. 1994;42(1):5-10. Exclusion reason: Wrong intervention. [pmid: 8277115].
298 Ferry JL, Abramson JS. Toward understanding the clinical aspects of geriatric case management. Social Work in Health Care. 2005;42(1):35-56. Exclusion reason: Wrong outcome. [pmid: 16236648].
299 Ferry JL, O'Toole R. Geriatric care managers: a collaborative resource to the physician practice. Journal of Medical Practice Management. Nov-Dec. 2002;18(3):129-32. Exclusion reason: No original data. [pmid: 12534253].
300 Fetterolf D, Holt AI, Tucker T, et al. Estimating clinical and economic impact in case management programs. Population Health Management. Apr. 2010;13(2):73-82. Exclusion reason: No original data. [pmid: 20102274].
301 Fillit HM, Hill J, Picariello G, et al. How the principles of geriatric assessment are shaping managed care. Geriatrics. Apr. 1998;53(4):76-8. Exclusion reason: Wrong intervention. [pmid: 9559029].
302 Fishbane S, Niederman MS, Daly C, et al. The impact of standardized order sets and intensive clinical case management on outcomes in community-acquired pneumonia. Archives of Internal Medicine. Aug. 13-27. 2007;167(15):1664-9. Exclusion reason: Wrong setting. [pmid: 17698690].
303 Fisk MJ. Telemedicine, new technologies and care management. International Journal of Geriatric Psychiatry. Nov. 1997;12(11):1057-9. Exclusion reason: Wrong intervention. [pmid: 9427089].
304 Fleming DT, Zambrowski A, Fong F, et al. Surveillance programs for chronic viral hepatitis in three health departments. Public Health Reports. Jan-Feb. 2006;121(1):23-35. Exclusion reason: Wrong outcome. [pmid: 16416695].
305 Flynn MB, McKeever JL, Spada T, et al. Active client participation: an examination of self-empowerment in HIV/AIDS case management with women. Journal of the Association of Nurses in AIDS Care. May-Jun. 2000;11(3):59-68. Exclusion reason: No original data. [pmid: 10826304].
306 Forbes DA. Goal Attainment Scaling. A responsive measure of client outcomes. Journal of Gerontological Nursing. Dec. 1998;24(12):34-40. Exclusion reason: Wrong intervention. [pmid: 10025309].
307 Ford ME, Havstad S, Vernon SW, et al. Enhancing adherence among older African American men enrolled in a longitudinal cancer screening trial. Gerontologist. Aug. 2006;46(4):545-50. Exclusion reason: Wrong population. [pmid: 16921009].
308 Ford ME, Randolph V, Hopkins-Johnson L, et al. Design of a case management approach to enhance cancer screening trial retention among older African American men. Journal of Aging & Health. Nov. 2004;16(5 Suppl):39S-57S. Exclusion reason: Wrong population. [pmid: 15448286].
309 Fordyce M, Bardole D, Romer L, et al. Senior Team Assessment and Referral Program--STAR. Journal of the American Board of Family Practice. Nov-Dec. 1997;10(6):398-406. Exclusion reason: Wrong intervention. [pmid: 9407480].
310 Forer S. Outcomes and case management. The keys to survival under managed care capitation. Rehab Management. Apr-May. 1998;11(3):92-5. Exclusion reason: Wrong outcome. [pmid: 10179223].
311 Fox P, Newcomer R, Yordi C, et al. Lessons learned from the Medicare Alzheimer Disease Demonstration. Alzheimer Disease & Associated Disorders. Apr-Jun. 2000;14(2):87-93. Exclusion reason: No original data. [pmid: 10850747].
312 Fralic J, Griffin C. Nutrition and the elderly: a case manager's guide. Lippincott 's Case Management. Jul-Aug. 2001;6(4):177-82. Exclusion reason: Wrong intervention. [pmid: 16398067].
313 Freedman JA, Cook CA, Robison T, et al. Collaborative QI in community-based long term care. Joint Commission Journal on Quality Improvement. Dec. 1995;21(12):701-10. Exclusion reason: Wrong intervention. [pmid: 8688926].
314 Fuhlbrigge AL, Adams WG, Kelley H, et al. TLC-asthma: extending the reach of case management in persistent asthma [Abstract]. Proceedings of the American Thoracic Society. A54 [Poster 705]. 2006. Exclusion reason: Wrong population.
315 Gabbay RA, Lendel I, Saleem TM, et al. Nurse case management improves blood pressure, emotional distress and diabetes complication screening. Diabetes Research & Clinical Practice. Jan. 2006;71(1):28-35. Exclusion reason: Wrong intervention. [pmid: 16019102].
316 Gallagher E, Alcock D, Diem E, et al. Ethical dilemmas in home care case management. Journal of Healthcare Management. Mar-Apr. 2002;47(2):85-96. discussion -7. Exclusion reason: Wrong outcome. [pmid: 11933604].
317 Gallagher LP, Truglio-Londrigan M, Levin R. Partnership for healthy living: an action research project. Nurse Researcher. 2009;16(2):7-29. Exclusion reason: No original data. [pmid: 19241904].
318 Ganz PA, Casillas J, Hahn EE. Ensuring quality care for cancer survivors: implementing the survivorship care plan. Seminars in Oncology Nursing. Aug. 2008;24(3):208-17. Exclusion reason: Wrong population. [pmid: 18687267].
319 Gardner LI, Metsch LR, Anderson-Mahoney P, et al. Efficacy of a brief case management intervention to link recently diagnosed HIV-infected persons to care. AIDS. Mar. 4. 2005;19(4):423-31. Exclusion reason: Wrong intervention. [pmid: 15750396].
320 Garrett B, Davidoff AJ, Yemane A. Effects of Medicaid managed care programs on health services access and use. Health Services Research. Apr. 2003;38(2):575-94. Exclusion reason: Wrong intervention. [pmid: 12785562].
321 Garrett M. Medicare chronic care improvement program puts the spotlight on case management. Case Manager. Jul-Aug. 2005;16(4):56-8. Exclusion reason: No original data. [pmid: 16061160].
322 Gasiorowicz M, Llanas MR, DiFranceisco W, et al. Reductions in transmission risk behaviors in HIV-positive clients receiving prevention case management services: findings from a community demonstration project. AIDS Education & Prevention. Feb. 2005;17(1 Suppl A):40-52. Exclusion reason: Wrong intervention. [pmid: 15843116].
323 Gask L, Ludman E, Schaefer J. Qualitative study of an intervention for depression among patients with diabetes: how can we optimize patient-professional interaction?. Chronic illness. Sep. 2006;2(3):231-42. Exclusion reason: Wrong population. [pmid: 17007699].
324 Genke J. HIV/AIDS and older adults. The invisible ten percent. Care Management Journals. 2000;2(3):196-205. Exclusion reason: Wrong intervention. [pmid: 11398576].
325 Genovese MC, Davis JSt. Current management of rheumatoid arthritis. Hospital practice (1995) Hospital practice. Feb. 15. 2001;36(2):21-6. Exclusion reason: Wrong intervention. [pmid: 11220358].
326 Gerber L. Ethics and caring: cornerstones of nursing geriatric case management. Journal of Gerontological Nursing. Dec. 1995;21(12):15-9. Exclusion reason: Wrong intervention. [pmid: 8537615].
327 Gerin W, Tobin JN, Schwartz JE, et al. The medication Adherence and Blood Pressure Control (ABC) trial: a multi-site randomized controlled trial in a hypertensive, multi-cultural, economically disadvantaged population. Contemporary Clinical Trials. Jul. 2007;28(4):459-71. Exclusion reason: Wrong intervention. [pmid: 17287150].
328 Gibson SJ, Martin SM, Johnson MB, et al. CNS-directed case management. Cost and quality in harmony. Journal of Nursing Administration. Jun. 1994;24(6):45-51. Exclusion reason: No original data. [pmid: 8006704].
329 Gilmer TP, Roze S, Valentine WJ, et al. Cost-effectiveness of diabetes case management for low-income populations. Health Services Research. Oct. 2007;42(5):1943-59. Exclusion reason: No original data. [pmid: 17850527].
330 Gimbel R, Ziac V, Tackley L, et al. A continuum-based outcome approach to measuring performance in HIV/AIDS case management. AIDS Care. Jul. 2007;19(6):767-74. Exclusion reason: No original data. [pmid: 17573597].
331 Gimpel N, Marcee A, Kennedy K, et al. Patient perceptions of a community-based care coordination system. Health Promotion Practice. Mar. 2010;11(2):173-81. Exclusion reason: No original data. [pmid: 19131540].
332 Glettler E, Leen MG. The advanced practice nurse as case manager. Journal of Case Management. 1996;5(3):121-6. Exclusion reason: No original data. [pmid: 9257627].
333 Gohler A, Januzzi JL, Worrell SS, et al. A systematic meta-analysis of the efficacy and heterogeneity of disease management programs in congestive heart failure. Journal of Cardiac Failure. Sep. 2006;12(7):554-67. Exclusion reason: No original data. [pmid: 16952790].
334 Gomez-Soto FM, Puerto JL, Andrey JL, et al. Consultation between specialists in Internal Medicine and Family Medicine improves management and prognosis of heart failure. European Journal of Internal Medicine. Nov. 2008;19(7):548-54. Exclusion reason: Wrong intervention. [pmid: 19013386].
335 Gonen JS. Neither prevention nor cure: managed care for women with chronic conditions. Women's Health Issues. Mar-Apr. 1999;9(2 Suppl):68S-78S. Exclusion reason: Wrong intervention. [pmid: 10189829].
336 Goode CJ. Impact of a CareMap and case management on patient satisfaction and staff satisfaction, collaboration, and autonomy. Nursing economic$. Nov-Dec. 1995;13(6):337-48. Exclusion reason: Wrong setting. [pmid: 8538807].
337 Goodman D. Application of the critical pathway and integrated case teaching method to nursing orientation. Journal of Continuing Education in Nursing. Sep-Oct. 1997;28(5):205-10. Exclusion reason: Wrong intervention. [pmid: 9348832].
338 Goodwin DR. Nursing case management activities. How they differ between employment settings. Journal of Nursing Administration. Feb. 1994;24(2):29-34. Exclusion reason: Wrong intervention. [pmid: 8301392].
339 Gotham CF, Bayliss D, Luzinski CH, et al. A cost-effective model of community case management. Case Manager. May-Jun. 2000;11(3):75-9. Exclusion reason: Wrong outcome. [pmid: 11935645].
340 Gow P, Berg S, Smith D, et al. Care co-ordination improves quality-of-care at South Auckland Health. Journal of quality in clinical practice. Jun. 1999;19(2):107-10. Exclusion reason: Wrong setting. [pmid: 10408752].
341 Graham C, Anderson L, Newcomer R. Nursing home transition: providing assistance to caregivers in transition program. Lippincott 's Case Management. Mar-Apr. 2005;10(2):93-101. Exclusion reason: Wrong intervention. [pmid: 15815225].
342 Grana J, Preston S, McDermott PD, et al. The use of administrative data to risk-stratify asthmatic patients. American Journal of Medical Quality. 1997;12(2):113-9. Exclusion reason: Wrong intervention. [pmid: 9161058].
343 Granieri EC, Turner GH, Organist L. Geriatric assessment, coordinated case management, and information systems: an integrated model for delivery of services to nursing home residents. Topics in Health Information Management. Aug. 1997;18(1):38-46. Exclusion reason: No original data. [pmid: 10173752].
344 Graves MT, Slater MA, Maravilla V, et al. Implementing an early intervention case management program in three medical groups. Case Manager. Sep-Oct. 2003;14(5):48-52. Exclusion reason: Wrong outcome. [pmid: 14593346].
345 Gray L, Sims N, Farish S, et al. A randomised trial of two forms of case management in the community: outcomes at two yea follow-up. [abstract]. Australian & New Zealand Journal of Medicine. 1994;24(424). Exclusion reason: Wrong intervention.
346 Graybeal K, Moccia-Sattler J. Protocols in practice Heart failure management in a community hospital system. Lippincott 's Case Management. May-Jun. 2001;6(3):112-18. Exclusion reason: No original data. [pmid: 16397996].
347 Greenawalt S. The integration of case management and disease management. Remington Report. Jul-Aug. 2008;16(4):37. Exclusion reason: No original data.
348 Greene SB, Reiter KL, Kilpatrick KE, et al. Searching for a business case for quality in Medicaid managed care. Health Care Management Review. Oct-Dec. 2008;33(4):350-60. Exclusion reason: Wrong outcome. [pmid: 18815500].
349 Greenwood RJ, McMillan TM, Brooks DN, et al. Effects of case management after severe head injury. BMJ (Clinical research ed.). May. 1994;308(6938):1199-205. Exclusion reason: Wrong intervention. [pmid: 8180536].
350 Grissom N. Model for consideration: retaining the experienced aging workforce in home care. Home Healthcare Nurse. Jan. 2009;27(1):60-3. Exclusion reason: No original data. [pmid: 19114789].
351 Griswold KS, Servoss TJ, Leonard KE, et al. Connections to primary medical care after psychiatric crisis. Journal of the American Board of Family Practice. May-Jun. 2005;18(3):166-72. Exclusion reason: Wrong population. [pmid: 15879563].
352 Grover CA, Close RJH, Villarreal K, et al. Emergency department frequent user: pilot study of intensive case management to reduce visits and computed tomography. Western Journal of Emergency Medicine. Sep. 2010;11(4):336-43. Exclusion reason: Wrong intervention. [pmid: 21079705].
353 Grower R, Hillegass B, Nelson F. Case management: meeting the needs of chronically ill patients in an HMO. Managed Care Quarterly. 1996;4(2):46-57. Exclusion reason: No original data. [pmid: 10157261].
354 Gruffydd-Jones K, Richman J, Jones RC, et al. A pilot study of identification and case management of high-risk COPD patients in a general practice. Family Practice. 2010;27(5):494-8. Exclusion reason: Wrong intervention. [pmid: 20631057].
355 Guleserian B. A cognitive-behavioral approach improves case management outcomes. Professional Case Management. Jan-Feb. 2007;12(1):55-9. Exclusion reason: Wrong population. [pmid: 17387293].
356 Habib OS, Ebrahim SM. Acute respiratory infections: a study on case management in Basrah health centres. Health Policy & Planning. Jun. 1994;9(2):213-7. Exclusion reason: Wrong population. [pmid: 15726783].
357 Hackstaff L, Davis C, Katz L. The case for integrating behavior change, client-centered practice and other evidence-based models into geriatric care management. Social Work in Health Care. 2004;38(3):1-19. Exclusion reason: Wrong intervention. [pmid: 15149909].
358 Hadjistavropoulos H, Bierlein C, Neville S, et al. Utility of The Regina Risk Indicator Tool among case managed elderly clients. Healthcare Management Forum. 2005;18(2):22-6. Exclusion reason: Wrong intervention. [pmid: 16119383].
359 Hadjistavropoulos HD, Sagan M, Bierlein C, et al. Development of a case management quality questionnaire. Care Management Journals. 2003;4(1):8-17. Exclusion reason: Wrong outcome. [pmid: 14502873].
360 Haley JE. Experience shown to affect communication skills of nurse case managers. Care Management Journals. 2007;8(2):50-7. Exclusion reason: Wrong outcomes. [pmid: 17595922].
361 Hallberg IR. Clinical group supervision and supervised implementation of planned individualized care of severely demented people: effects on nurses, provision of the care, and patients. Journal of Psychiatric & Mental Health Nursing. 1995;2(2):113-4. Exclusion reason: Wrong setting. [pmid: 7655909].
362 Hallberg IR, Kristensson J. Preventive home care of frail older people: a review of recent case management studies. Journal of Clinical Nursing. Sep. 2004;13(6B):112-20. Exclusion reason: No original data. [pmid: 15724826].
363 Hallberg IR, Norberg A. Strain among nurses and their emotional reactions during 1 year of systematic clinical supervision combined with the implementation of individualized care in dementia nursing. Journal of Advanced Nursing. Dec. 1993;18(12):1860-75. Exclusion reason: Wrong outcome. [pmid: 8132916].
364 Ham C. Chronic care in the English National Health Service: progress and challenges [corrected]. [published erratum appears in HEALTH AFF 2009 Mar-Apr;28(2):607]. Health Affairs. Jan-Feb. 2009;28(1):190-201. Exclusion reason: Wrong intervention. [pmid: 19124870].
365 Hammond FM, Gassaway J, Abeyta N, et al. The SCIRehab project: social work and case management. Social work and case management treatment time during inpatient spinal cord injury rehabilitation. Journal of Spinal Cord Medicine. Mar. 2011;34(2):216-26. Exclusion reason: Wrong setting. [pmid: 21675360].
366 Handford C, Tynan AM, Rackal JM, et al. Setting and organization of care for persons living with HIV/AIDS. Cochrane Database of Systematic Reviews. 2010;(2). Exclusion reason: No original data.
367 Hanson S, Engvall J, Sunkutu RM, et al. Case management and patient reactions: a study of STD care in a province in Zambia. International Journal of STD & AIDS. May. 1997;8(5):320-8. Exclusion reason: Wrong intervention. [pmid: 9175655].
368 Harari D, Martin FC, Buttery A, et al. The older persons' assessment and liaison team ‘OPAL’: evaluation of comprehensive geriatric assessment in acute medical inpatients. Age & Ageing. Nov. 2007;36(6):670-5. Exclusion reason: Wrong setting. [pmid: 17656421].
369 Harries CS, Botha J, McFadyen ML, et al. STI case management at a South African teaching hospital. Sexually Transmitted Infections. Dec. 2003;79(6):498-9. Exclusion reason: Wrong population. [pmid: 14663132].
370 Harris LE, Luft FC, Rudy DW, et al. Effects of multidisciplinary case management in patients with chronic renal insufficiency. American Journal of Medicine. Dec. 1998;105(6):464-71. Exclusion reason: Wrong intervention. [pmid: 9870830].
371 Harris M. New directions for clinical case management. New Directions for Mental Health Services. 1988;(40):87-96. Exclusion reason: No original data. [pmid: 3237193].
372 Harris SK, Samples CL, Keenan PM, et al. Outreach, mental health, and case management services: can they help to retain HIV-positive and at-risk youth and young adults in care?. Maternal & Child Health Journal. Dec. 2003;7(4):205-18. Exclusion reason: Wrong outcome. [pmid: 14682498].
373 Harrison JP, Nolin J, Suero E. The effect of case management on U.S. hospitals. Nursing Economic$. Mar-Apr. 2004;22(2):64-70. Exclusion reason: Wrong setting. [pmid: 15108474].
374 Harrison PL, Hara PA, Pope JE, et al. The impact of postdischarge telephonic follow-up on hospital readmissions. Population Health Management. Feb. 2011;14(1):27-32. Exclusion reason: Wrong intervention. [pmid: 21090991].
375 Hartigan M, Cesta TG, Mapes D, et al. AMDP: the Anemia Management Demonstration Project: development, implementation and testing of a multidisciplinary action plan (MAP) for hemodialysis patients in the community. Care Management. 2003;9(2):19. Exclusion reason: Wrong intervention.
376 Hauber RP, Jones ML. Telerehabilitation support for families at home caring for individuals in prolonged states of reduced consciousness. Journal of Head Trauma Rehabilitation. Dec. 2002;17(6):535-41. Exclusion reason: Wrong intervention. [pmid: 12802244].
377 Hauser SP. Case management of the kidney transplant recipient. Anna Journal. Aug. 1995;22(4):369-74. Exclusion reason: Wrong setting. [pmid: 7654083].
378 Haussler B, Keck M. Improvement in occupational rehabilitation of myocardial infarct patients--results of a model study in Rhineland-Pfalz. Die Rehabilitation. May. 1997;36(2):106-10. Exclusion reason: Wrong setting. [pmid: 9324707].
379 Havens PL, Cuene BE, Hand JR, et al. Effectiveness of intensive nurse case management in decreasing vertical transmission of human immunodeficiency virus infection in Wisconsin. Pediatric Infectious Disease Journal. Sep. 1997;16(9):871-5. Exclusion reason: Wrong population. [pmid: 9306482].
380 Hayes E. Nurse practitioners and managed care: patient satisfaction and intention to adhere to nurse practitioner plan of care. Journal of the American Academy of Nurse Practitioners. Aug. 2007;19(8):418-26. Exclusion reason: Wrong intervention. [pmid: 17655571].
381 Head BA, Cantrell M, Pfeifer M. Mark's journey: a study in medicaid palliative care case management. Professional Case Management. Jan-Feb. 2009;14(1):39-45. Exclusion reason: No original data. [pmid: 19092600].
382 Headley CM, Wall B. Advanced practice nurses: roles in the hemodialysis unit. Nephrology Nursing Journal: Journal of the American Nephrology Nurses' Association. Apr. 2000;27(2):177-84. quiz 85-6. Exclusion reason: Wrong intervention. [pmid: 11111544].
383 Heaney C, Lim K, Lydall-Smith S, et al. Unassigned Geriatric Evaluation and Management program: preventing sub-acute hospital admissions. Australian Health Review. 2002;25(6):164-70. Exclusion reason: Wrong intervention. [pmid: 12536876].
384 Heinemann AW, Corrigan JD, Moore D. Case management for traumatic brain injury survivors with alcohol problems. Rehabilitation Psychology. 2004;4(2):156-66. Exclusion reason: Wrong population.
385 Hellwig SD, Yam M, DiGiulio M. Nurse case managers' perceptions of advocacy: a phenomenological inquiry. Lippincott's Case Management. Mar-Apr. 2003;8(2):53-63. quiz 4-5. Exclusion reason: Wrong intervention. [pmid: 12668923].
386 Henry RA, Stanton MP. Case management process improvement protocol: transcribing an initial summary for the oncology geriatric patient in a rural satellite office. Lippincott's Case Management. Sep-Oct. 2005;10(5):234-9. Exclusion reason: Wrong intervention. [pmid: 16205205].
387 Hereford RW. Private-pay case management. Let the seller beware. Caring. Aug. 1990;9(8):8-12. Exclusion reason: Wrong intervention. [pmid: 10113331].
388 Herrin J, Cangialose CB, Nicewander D, et al. Cost and effects of performance feedback and nurse case management for Medicare beneficiaries with diabetes: a randomized controlled trial. Disease management : DM. Dec. 2007;10(6):328-36. Exclusion reason: Wrong intervention. [pmid: 18163861].
389 Hey M. Nursing's renaissance An innovative continuum of care takes nurses back to their roots. Health Progress. Oct. 1993;74(8):26-32. Exclusion reason: Wrong outcome. [pmid: 10129199].
390 Hickey ML, Cook EF, Rossi LP, et al. Effect of case managers with a general medical patient population. Journal of Evaluation in Clinical Practice. Feb. 2000;6(1):23-9. Exclusion reason: Wrong intervention. [pmid: 10807021].
391 Higgins J, Cole-Poklewski T. Case management reform: an illustrative study of one hospital's experience. Professional Case Management. Mar-Apr. 2010;15(2):79-89. Exclusion reason: No original data. [pmid: 20234291].
392 Hilgendorf PM. Profile of the successful home health nurse case manager. Nursing Management. Oct. 1996;27(10):32Q-R. Exclusion reason: No original data. [pmid: 8632867].
393 Hillestad R, Bigelow J, Bower A, et al. Can electronic medical record systems transform health care? Potential health benefits, savings, and costs. Health Affairs. Sep-Oct. 2005;24(5):1103-17. Exclusion reason: Wrong intervention. [pmid: 16162551].
394 Hirshberg AJ, Holliman CJ, Wuerz RC, et al. Case management by physician assistants and primary care physicians vs. emergency physicians. Academic Emergency Medicine. Nov. 1997;4(11):1046-52. Exclusion reason: Wrong intervention. [pmid: 9383490].
395 Hodgen RK, Ferguson D, Davis C, et al. Congestive heart failure: examining the influence of nurse case management on health care outcomes. Care Management. 2002;8(4):16. Exclusion reason: Wrong setting.
396 Hodgkinson B, Haesler EJ, Nay R, et al. Effectiveness of staffing models in residential, subacute, extended aged care settings on patient and staff outcomes. Cochrane Database of Systematic Reviews. 2011;(4). Exclusion reason: Wrong population. [pmid: 21678358].
397 Hodgkinson J, Townsend J, McKinnon M, et al. Evaluation of nurse-led case management of the elderly [abstract]. Age and Ageing. Sep. 2000;29(Suppl 2):38. Exclusion reason: Wrong outcome.
398 Hogan TD. Case management in a wound care program. Nursing Case Management. Jan-Feb. 1997;2(1):2-13. quiz 4-5. Exclusion reason: No original data. [pmid: 9205322].
399 Hokenstad MC, Johansson L. Eldercare in Sweden: issues in service provision and case management. Journal of Case Management. 1996;5(4):137-41. Exclusion reason: Wrong outcome. [pmid: 9110695].
400 Holloway F, Carson J. Intensive case management: does it work?. Proceedings of the 8th Congress of the Association of European Psychiatrists. 1996. Exclusion reason: Wrong population.
401 Holloway M. Traversing the network: a user-led Care Pathway approach to the management of Parkinson's disease in the community. Health & Social Care in the Community. Jan. 2006;14(1):63-73. Exclusion reason: Wrong intervention. [pmid: 16324188].
402 Holzemer WL, Henry SB, Portillo CJ, et al. The Client Adherence Profiling-Intervention Tailoring (CAP-IT) intervention for enhancing adherence to HIV/AIDS medications: a pilot study. Journal of the Association of Nurses in AIDS Care. Jan-Feb. 2000;11(1):36-44. Exclusion reason: Wrong intervention. [pmid: 10670005].
403 Hopey KC. Role perceptions of hospital based nurse case managers. 2008:148. Exclusion reason: Wrong outcome.
404 Horton S, Johnson RJ. Improving access to health care for uninsured elderly patients. Public Health Nursing. Jul. 2010;27(4):362-70. Exclusion reason: Wrong intervention. [pmid: 20626837].
405 Horvath KJ, Secatore JA, Alpert HB, et al. Uncovering the knowledge embedded in clinical nurse manager practice. Journal of Nursing Administration. Jul-Aug. 1994;24(7-8):39-44. Exclusion reason: Wrong intervention. [pmid: 8057172].
406 Horwitz SM, Busch SH, Balestracci KM, et al. Intensive intervention improves primary care follow-up for uninsured emergency department patients. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2005;12(7):647-52. Exclusion reason: Wrong intervention. [pmid: 15995098].
407 Hoskins LM, Thiel L, Walton-Moss B, et al. Clinical pathway versus a usual plan of care for patients with congestive heart failure: what's the difference?.. part 1 of a two-part series. Home Healthcare Nurse. Mar. 2001;19(3):142-50. Exclusion reason: Wrong intervention. [pmid: 11985241].
408 Howe R, Greenberg L. Performance measurement for case management: principles and objectives for developing standard measures. Case Manager. Sep-Oct. 2005;16(5):52-6. Exclusion reason: No original data. [pmid: 16243662].
409 Howell DM, Sussman J, Wiernikowski J, et al. A mixed-method evaluation of nurse-led community-based supportive cancer care. Supportive Care in Cancer. Dec. 2008;16(12):1343-52. Exclusion reason: Wrong outcome. [pmid: 18335260].
410 Hromco JG, Lyons JS, Nikkel RE. Styles of case management: the philosophy and practice of case managers. Community Mental Health Journal. Oct. 1997;33(5):415-28. Exclusion reason: Wrong population. [pmid: 9413668].
411 Hsu LC, Chen M, Kali J, et al. Assessing receipt of medical care and disparity among persons with HIV/AIDS in San Francisco, 2006-2007. AIDS Care. Mar. 2011;23(3):383-92. Exclusion reason: Wrong intervention. [pmid: 21347902].
412 Huber DL, Sarrazin MV, Vaughn T, et al. Evaluating the impact of case management dosage. Nursing Research. Sep-Oct. 2003;52(5):276-88. Exclusion reason: Wrong population. [pmid: 14501542].
413 Huber L. Pilot admits patients from ED directly to post-acute care. Hospital Case Management. Sep. 2008;16(9):135-6. Exclusion reason: No original data.
414 Hudson AJ, Moore LJ. A new way of caring for older people in the community. [Erratum appears in Nurs Stand. 2006 Sep 20-26;21(2):31]. Nursing Standard. Jul. 26. Aug. 1. 2006;20(46):41-7. Exclusion reason: No original data. [pmid: 16898196].
415 Hudson B. Sea change or quick fix? Policy on long-term conditions in England. Health & Social Care in the Community. Jul. 2005;13(4):378-85. Exclusion reason: No original data. [pmid: 15969709].
416 Huggins D, Lehman K. Reducing costs through case management. Nursing Management. Dec. 1997;28(12):34-7. Exclusion reason: No original data. [pmid: 9423451].
417 Hughes CB, Trofino J, O'Brien BL, et al. Primary care parish nursing: outcomes and implications. Nursing Administration Quarterly. Fall. 2001;26(1):45-59. Exclusion reason: Wrong intervention.
418 Hughes SL, Finkel S, Harter K, et al. Evaluation of the Managed Community Care Demonstration Project. Journal of Aging & Health. Feb. 2003;15(1):246-68. Exclusion reason: Wrong intervention. [pmid: 12613470].
419 Hunt AM, da Silva A, Lurie S, et al. Community treatment orders in Toronto: the emerging data. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Oct. 2007;52(10):647-56. Exclusion reason: Wrong population. [pmid: 18020112].
420 Hytoff RA. Meeting the needs of the chronically ill. Tampa General implements a care management model for the chronically ill. Healthcare Executive. Jan-Feb. 2003;18(1):66-7. Exclusion reason: No original data. [pmid: 12555692].
421 Igarashi A, Ikegami N, Yamada Y, et al. Effect of the Japanese preventive-care version of the Minimum Data Set - Home Care on the health-related behaviors of community-dwelling, frail older adults and skills of preventive-care managers: a quasi-experimental study conducted in Japan. Geriatrics & Gerontology International. Sep. 2009;9(3):310-9. Exclusion reason: Wrong intervention. [pmid: 19702943].
422 Inciardi JA, Isenberg H, Lockwood D, et al. Assertive community treatment with a parolee population: an extension of case management. NIDA Research Monograph. 1992;127:350-67. Exclusion reason: Wrong intervention. [pmid: 1436003].
423 Ingersoll S, Valente SM, Roper J. Using the best evidence to change practice. Nurse care coordination for diabetes: a literature review and synthesis. Journal of Nursing Care Quality. Jul-Sep. 2005;20(3):208-14. Exclusion reason: Background. [pmid: 15965384].
424 Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database of Systematic Reviews. 2011;(4). Exclusion reason: Wrong intervention.
425 Inglis SC, Pearson S, Treen S, et al. Extending the Horizon in Chronic Heart Failure. Circulation. Dec. 5. 2006;114(23):2466-73. Exclusion reason: Wrong intervention. [pmid: 17116767].
426 Intagliata J. Improving the quality of community care for the chronically mentally disabled: the role of case management. Schizophr Bull. 1982;8:655-74. Exclusion reason: Wrong population. [pmid: 7178854].
427 Ireland S, MacKenzie G, Gould L, et al. Nurse case management to improve risk reduction outcomes in a stroke prevention clinic. Canadian Journal of Neuroscience Nursing. 2010;32(4):7-13. Exclusion reason: Wrong intervention. [pmid: 21268488].
428 Ison A. Nursing case management: an innovative approach to care in the emergency department. Topics in Emergency Medicine. Sep. 1991;13(3):35-46. Exclusion reason: Wrong setting.
429 Issel LM, Anderson RA. Intensity of case managers' participation in organizational decision making. Research in Nursing & Health. Oct. 2001;24(5):361-72. Exclusion reason: Wrong population. [pmid: 11746066].
430 Jaana M, Paré G. Home telemonitoring of patients with diabetes: a systematic assessment of observed effects. J Eval Clin Pract. 2007;13(2):242-53. Exclusion reason: No original data. [pmid: 17378871].
431 Jackson CT, Covell NH, Drake RE, et al. Relationship between diabetes and mortality among persons with co-occurring psychotic and substance use disorders. Psychiatric Services. Feb. 2007;58(2):270-2. Exclusion reason: Wrong population. [pmid: 17287387].
432 Jacobs B. Reducing heart failure hospital readmissions from skilled nursing facilities. Professional Case Management. Jan-Feb. 2011;16(1):18-26. Exclusion reason: Wrong intervention. [pmid: 21164330].
433 Jacobs S, Challis D. Assessing the impact of care management in the community: associations between key organisational components and service outcomes. Age & Ageing. May. 2007;36(3):336-9. Exclusion reason: No original data. [pmid: 17387122].
434 Jacobs S, Hughes J, Challis D, et al. From care management to case management: what can the NHS learn from the social care experience?. Journal of Integrated Care. Jun. 2006;14(3):22-31. Exclusion reason: Wrong outcome.
435 Jacobs S, Hughes J, Challis D, et al. Care managers' time use: differences between community mental health and older people's services in the United Kingdom. Care Management Journals. 2006;7(4):169-78. Exclusion reason: No original data. [pmid: 17194053].
436 Jansen DEMC, Krol B, Groothoff JW, et al. Evaluation of a transmural care model for multiple sclerosis patients. Journal of Neuroscience Nursing. Oct. 2006;38(5):384-9. Exclusion reason: Wrong intervention. [pmid: 17069269].
437 Jensen S, Bowman J. Community assessment for the case manager. Case Manager. Nov-Dec. 2002;13(6):59-62. Exclusion reason: No original data. [pmid: 12439466].
438 Jensen S, Carlson T. Vocational rehabilitation: what the medical case manager needs to know. Lippincott's Case Management. Mar-Apr. 2005;10(2):110-2. Exclusion reason: No original data. [pmid: 15815228].
439 Jia H, Chuang H, Wu SS, et al. Long-term effect of home telehealth services on preventable hospitalization use. Journal of Rehabilitation Research & Development. 2009;46(5):557-66. Exclusion reason: Wrong intervention. [pmid: 19882490].
440 John EJ, Vavra T, Farris K, et al. Workplace-based cardiovascular risk management by community pharmacists: impact on blood pressure, lipid levels, and weight. Pharmacotherapy. Oct. 2006;26(10):1511-7. Exclusion reason: Wrong population. [pmid: 16999661].
441 Johnson CE, Lemak CH, Hall AG, et al. Outsourcing administrative functions: service organization demonstrations and Florida Medicaid PCCM program costs. Journal of Health Care Finance. 2010;37(1):1-12. Exclusion reason: Wrong intervention. [pmid: 20973369].
442 Johnson D, Polansky M, Matosky M, et al. Psychosocial factors associated with successful transition into HIV case management for those without primary care in an urban area. AIDS & Behavior. Apr. 2010;14(2):459-68. Exclusion reason: Wrong outcome. [pmid: 19921420].
443 Johnson P, Rubin A. Case management in mental health: a social work domain?. Social Work. Jan-Feb. 1983;28(1):49-55. Exclusion reason: No original data. [pmid: 10314015].
444 Johnston S, Salkeld G, Sanderson K, et al. Intensive case management: a cost-effectiveness analysis. Australian & New Zealand Journal of Psychiatry. Aug. 1998;32(4):551-9. Exclusion reason: Wrong population. [pmid: 9711370].
445 Jones C, Roderick P, Harris S, et al. An evaluation of a shared primary and secondary care nephrology service for managing patients with moderate to advanced CKD. American Journal of Kidney Diseases. Jan. 2006;47(1):103-14. Exclusion reason: Wrong intervention. [pmid: 16377391].
446 Jones S, Farrar P, Poland M, et al. Comparison of participants and refusers invited to enroll in a case management study for patients with moderate to severe chronic obstructive pulmonary disease [Abstract]. Thorax. Dec. 2005;60(Suppl 2):ii70. Exclusion reason: Wrong outcome.
447 Jones SM, Albert P, Warburton CJ, et al. Effect of a case management study on primary care use and prescribing for AECOPD [Abstract]. Thorax. Dec. 2009;64(Suppl IV):A119. [P05]. Exclusion reason: No original data.
448 June KJ, Lee JY, Yoon JL. Effects of case management using Resident Assessment Instrument-Home Care (RAI-HC) in home health services for older people. Journal of Korean Academy of Nursing. Jun. 2009;39(3):366-75. Exclusion reason: Wrong population. [pmid: 19571633].
449 Kahler D, Salber P, Wilson T. An epidemiologic perspective on a case management program. Professional Case Management. Nov. 2010;15(6):314-22. quiz 23-4. Exclusion reason: Wrong outcome. [pmid: 21057296].
450 Kahn LS, Fox CH, Carrington J, et al. Telephonic nurse case management for patients with diabetes and mental illnesses: a qualitative perspective. Chronic Illness. Dec. 2009;5(4):257-67. Exclusion reason: Wrong outcome. [pmid: 20156943].
451 Kaiser KL, Hays BJ, Cho WJ, et al. Examining health problems and intensity of need for care in family-focused community and public health nursing. Journal of Community Health Nursing. 2002;19(1):17-32. Exclusion reason: Wrong outcome. [pmid: 11985209].
452 Kaiser KL, Miller LL, Hays BJ, et al. Patterns of health resource utilization, costs, and intensity of need for primary care clients receiving public health nursing case management. Nursing Case Management. Mar-Apr. 1999;4(2):53-62. quiz 3-6. Exclusion reason: Wrong intervention. [pmid: 10418455].
453 Kalichman SC, Klein SJ, Kalichman MO, et al. HIV/AIDS case managers and client HIV status disclosure: perceived client needs, practices, and services. Health & Social Work. Nov. 2007;32(4):259-67. Exclusion reason: Wrong outcome. [pmid: 18038727].
454 Kane RA, Degenholtz H. Case management as a force for quality assurance and quality improvement in home care. Journal of Aging & Social Policy. 1997;9(4):5-28. Exclusion reason: Wrong outcome. [pmid: 10186891].
455 Kane RA, Degenholtz HB, Kane RL. Adding values: an experiment in systematic attention to values and preferences of community long-term care clients. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Mar. 1999;54(2):S109-19. Exclusion reason: Wrong outcome. [pmid: 10097781].
456 Kane RA, Penrod JD, Kivnick HQ. Case managers discuss ethics: dilemmas of an emerging occupation in long-term care in the United States. Journal of Case Management. Spring. 1994;3(1):3-12. Exclusion reason: Wrong outcome. [pmid: 8000320].
457 Kane RL. What Can Improve Chronic Disease Care?. Journal of the American Geriatrics Society. Dec. 2009;57(12):2338-45. Exclusion reason: No original data. [pmid: 20121992].
458 Kane RL. Finding the right level of posthospital care: “We didn't realize there was any other option for him”. JAMA. Jan. 19. 2011;305(3):284-93. Exclusion reason: No original data. [pmid: 21245184].
459 Kane RL, Homyak P, Bershadsky B, et al. Consumer responses to the Wisconsin Partnership Program for Elderly Persons: a variation on the PACE Model. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Apr. 2002;57(4):M250-8. Exclusion reason: Wrong intervention. [pmid: 11909892].
460 Kane RL, Kane RA. Assessment in long-term care. Annual Review of Public Health. 2000;21:659-86. Exclusion reason: Wrong intervention. [pmid: 10884969].
461 Kanter PM, Otwell JA. Diabetes case management: exploring staff practice patterns. Diabetes Educator. Jul-Aug. 1996;22(4):333. Exclusion reason: No original data. [pmid: 8846740].
462 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Archives of general psychiatry. Oct. 2004;61(10):1042-9. Exclusion reason: Wrong population. [pmid: 15466678].
463 Katz MH, Cunningham WE, Fleishman JA, et al. Effect of case management on unmet needs and utilization of medical care and medications among HIV-infected persons. Annals of Internal Medicine. Oct. 16. 2001;135(8 Pt 1):557-65. Exclusion reason: Wrong intervention. [pmid: 11601927].
464 Katz MH, Cunningham WE, Mor V, et al. Prevalence and predictors of unmet need for supportive services among HIV-infected persons: impact of case management. Medical Care. Jan. 2000;38(1):58-69. Exclusion reason: Wrong intervention. [pmid: 10630720].
465 Kaul P, Armstrong PW, Chang WC, et al. Long-term mortality of patients with acute myocardial infarction in the United States and Canada: comparison of patients enrolled in Global Utilization of Streptokinase and t-PA for Occluded Coronary Arteries (GUSTO)-I. Circulation. Sep. 2004;110(13):1754-60. Exclusion reason: Wrong intervention. [pmid: 15381645].
466 Kay D, Blue A, Pye P, et al. Heart failure: improving the continuum of care [corrected]. [published erratum appears in CARE MANAGE J 2006 winter;7(4):161]. Care Management Journals. Summer. 2006;7(2):58-63. Exclusion reason: Wrong setting. [pmid: 17214237].
467 Keefe B, Geron SM, Enguidanos S. Integrating social workers into primary care: physician and nurse perceptions of roles, benefits, and challenges. Social Work in Health Care. 2009;48(6):579-96. Exclusion reason: Wrong outcome. [pmid: 19860293].
468 Keith PM. Health care hassles of caregivers to the chronically ill. International Journal of Aging & Human Development. 2009;69(1):1-16. Exclusion reason: Wrong intervention. [pmid: 19803337].
469 Kelley ML, MacLean MJ. I want to live here for rest of my life. The challenge of case management for rural seniors. Journal of Case Management. 1997;6(4):174-82. Exclusion reason: Wrong intervention. [pmid: 9644409].
470 Kemper P, Pezzin LE. The effect of public provision of home care on living and care arrangements: evidence from the channeling experiment. Developments in Health Economics & Public Policy. 1996;5:125-46. Exclusion reason: Wrong intervention. [pmid: 10164416].
471 Kempshall N. The care of patients with complex long-term conditions. British Journal of Community Nursing. Apr. 2010;15(4):181-7. Exclusion reason: No original data. [pmid: 20559165].
472 Kerekes J, Thornton O. Incorporating nutritional risk screening with case management initiatives. Nutrition in Clinical Practice. Jun. 1996;11(3):95-7. Exclusion reason: No original data. [pmid: 8807926].
473 Kersbergen AL. Case management: A rich history of coordinating care to control costs. Nursing Outlook. Jul-Aug. 1996;44(4):169-72. Exclusion reason: No original data. [pmid: 8871998].
474 Khan NA, Hemmelgarn B, Herman RJ, et al. The 2009 Canadian Hypertension Education Program recommendations for the management of hypertension: Part 2--therapy. Canadian Journal of Cardiology. May. 2009;25(5):287-98. Exclusion reason: Wrong intervention. [pmid: 19417859].
475 Kibbe DC. Physicians, care coordination, and the use of Web-based information systems to manage chronic illness across the continuum. Case Manager. Sep-Oct. 2001;12(5):56-61. Exclusion reason: Wrong outcome. [pmid: 11552096].
476 Kim YJ, Soeken KL. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission. Nursing Research. Jul-Aug. 2005;54(4):255-64. Exclusion reason: Wrong setting. [pmid: 16027568].
477 Kimball B, Cherner D, Joynt J, et al. The quest for new innovative care delivery models. Journal of Nursing Administration. Sep. 2007;37(9):392-8. Exclusion reason: No original data. [pmid: 17823572].
478 King A, Parsons M. An evaluation of two respite models for older people and their informal caregivers. New Zealand Medical Journal. May. 6. 2005;118(1214):U1440. Exclusion reason: No original data. [pmid: 15886735].
479 Kinney ED, Kennedy J, Cook CAL, et al. A randomized trial of two quality improvement strategies implemented in a statewide public community-based, long-term care program. Medical Care. Sep. 2003;41(9):1048-57. Exclusion reason: Wrong intervention. [pmid: 12972844].
480 Kirchberger I, Meisinger C, Seidl H, et al. Nurse-based case management for aged patients with myocardial infarction: study protocol of a randomized controlled trial. BMC geriatrics. May. 2010;10(29). Exclusion reason: No original data. [pmid: 20507567].
481 Klein GL, Kita K, Fish J, et al. Nutrition and health for older persons in rural America: a managed care model. Journal of the American Dietetic Association. Aug. 1997;97(8):885-8. Exclusion reason: Wrong outcome. [pmid: 9259711].
482 Knollmueller R. Case management: what's in a name?. Nurs Manage. Oct. 1989;20(10):38-42. Exclusion reason: No original data. [pmid: 2586933].
483 Knowlton AR, Hoover DR, Chung SE, et al. Access to medical care and service utilization among injection drug users with HIV/AIDS. Drug & Alcohol Dependence. Sep. 1. 2001;64(1):55-62. Exclusion reason: Wrong population. [pmid: 11470341].
484 Kodner DL, Kyriacou CK. Bringing managed care home to people with chronic, disabling conditions: prospects and challenges for policy, practice, and research. Journal of Aging & Health. Feb. 2003;15(1):189-222. Exclusion reason: No original data. [pmid: 12613468].
485 Koff TH. Case management in long term care: assessment, service coordination. Hospital Progress. Oct. 1981;62(10):54-7. Exclusion reason: No original data. [pmid: 10309461].
486 Kolbasovsky A, Reich L, Meyerkopf N. Reducing six-month inpatient psychiatric recidivism and costs through case management. Care Management Journals. 2010;11(1):2-10. Exclusion reason: Wrong population. [pmid: 20426315].
487 Kornfeld R, Rupp K. The net effects of the Project NetWork return-to-work case management experiment on participant earnings, benefit receipt, and other outcomes. Social Security Bulletin. 2000;63(1):12-33. Exclusion reason: Wrong population. [pmid: 10951687].
488 Krause C. Preemptive measures: a guide to potential pitfalls in a new telehealth program. Caring. Jul. 2004;23(7):12-5. Exclusion reason: No original data. [pmid: 15341300].
489 Kreindler SA. Lifting the burden of chronic disease: what has worked? What hasn't? What's next?. Healthcare Quarterly. 2009;12(2):30-40. Exclusion reason: No original data. [pmid: 19369809].
490 Krout JA. Barriers to providing case management to older rural persons. Journal of Case Management. 1997;6(4):142-50. Exclusion reason: Wrong outcome. [pmid: 9644404].
491 Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. Sep. 26. 2006;114(13):1432-45. Exclusion reason: No original data. [pmid: 16952985].
492 Kuo S, Burrill J. Differences in antihypertensive compliance by BCBSRI disease and case management intervention group. Medicine & Health, Rhode Island. Dec. 2007;90(12):381-4. Exclusion reason: Wrong outcome. [pmid: 18314829].
493 Lacy CR, Suh DC, Barone JA, et al. Impact of a targeted intervention on lipid-lowering therapy in patients with coronary artery disease in the hospital setting. Archives of Internal Medicine. Feb. 25. 2002;162(4):468-73. Exclusion reason: Wrong setting. [pmid: 11863482].
494 Lager KE, Wilson AD, Mistri AK, et al. Stroke services for risk reduction in the secondary prevention of stroke. Cochrane Database of Systematic Reviews. 2011;(4). Exclusion reason: No original data.
495 Lagoe RJ, Noetscher CM, Markle A, et al. Community-wide programs to support hospital discharges to nursing homes. Topics in Advanced Practice Nursing. 2010;10(2):11. Exclusion reason: Wrong population.
496 Lagoe RJ, Noetscher CM, Murphy ME. Hospital readmissions at the communitywide level: implications for case management. Journal of Nursing Care Quality. Jul. 2000;14(4):1-15. Exclusion reason: Wrong outcome. [pmid: 10881445].
497 Lagoe RJ, Noetscher CM, Murphy MP. Hospital readmission: predicting the risk. Journal of Nursing Care Quality. Jul. 2001;15(4):69-83. Exclusion reason: Wrong intervention. [pmid: 11452643].
498 Laine C, Markson LE, Fanning TR, et al. Relationship between ambulatory care accessibility and hospitalization for persons with advanced HIV disease. Journal of Health Care for the Poor & Underserved. Aug. 1999;10(3):313-27. Exclusion reason: Wrong intervention. [pmid: 10436730].
499 Lamb G. Conceptual and methodological issues in nurse case management research. Adv Nurs Sci. Dec. 1992;15(2):16-24. Exclusion reason: Wrong population. [pmid: 1444280].
500 Lamb GS, Stempel JE. Nurse case management from the client's view: growing as insider-expert. Nursing Outlook. Jan-Feb. 1994;42(1):7-13. Exclusion reason: Wrong population. [pmid: 8202398].
501 Lamb L, Pereira JX, Shir Y. Nurse case management program of chronic pain patients treated with methadone. Pain Management Nursing. Sep. 2007;8(3):130-8. Exclusion reason: Wrong population. [pmid: 17723930].
502 Lamont C, Rae H, McAuley S, et al. Integrated case management between primary and secondary care for COPD patients: perspectives from the respiratory nurse specialist. Respirology. 2002;7(Suppl):A1-68. Exclusion reason: Wrong intervention. [pmid: 12075615].
503 Landi F, Sgadari A, Cipriani L, et al. A simple program to train case managers in community elderly care. Aging-Clinical & Experimental Research. Jun. 1996;8(3):211-8. Exclusion reason: No original data. [pmid: 8862197].
504 Lantz PM, Keeton K, Romano L, et al. Case management in public health screening programs: the experience of the National Breast and Cervical Cancer Early Detection Program. Journal of Public Health Management & Practice. Nov-Dec. 2004;10(6):545-55. Exclusion reason: Wrong outcome. [pmid: 15643379].
505 Lashley M. CM and DM team up for effective management of high-cost care. Case Manager. 1995;6(3):70-6. Exclusion reason: No original data.
506 5. Lata PF, Mainhardt M, Johnson CA. Impact of nurse case manager -- pharmacist collaboration on adverse-drug-event reporting. American Journal of Health-System Pharmacy. Mar. 2004;61(5):483-87. Exclusion reason: Wrong outcome. [pmid: 15018225].
507 Latini EE. Trauma critical pathways: a care delivery system that works. Critical Care Nursing Quarterly. May. 1996;19(1):83-7. Exclusion reason: Wrong setting. [pmid: 8705703].
508 Latour CH, vdW D, de Jonge P, et al. Nurse-led case management for ambulatory complex patients in general health care: a systematic review. J Psychosom Res. Mar. 2007;62(3):385-95. Exclusion reason: Background. [pmid: 17324690].
509 Latour CHM, Huyse FJ, de Vos R, et al. A method to provide integrated care for complex medically ill patients: the INTERMED. Nursing & Health Sciences. Jun. 2007;9(2):150-7. Exclusion reason: No original data. [pmid: 17470190].
510 Lee B. Challenges facing case management in a changing social service environment. Care Management Journals. 2001;3(1):20-4. Exclusion reason: No original data. [pmid: 11974573].
511 Lee KH, Davenport L. Can case management interventions reduce the number of emergency department visits by frequent users?. Health Care Manager. Apr-Jun. 2006;25(2):155-9. Exclusion reason: Wrong population. [pmid: 16699330].
512 Leenakul R, Boontong T, Phancharoenworakul K, et al. Development of nursing case management model for patients with myocardial infarction. Thai Journal of Nursing Research. 2006;10(2):120-32. Exclusion reason: Wrong setting.
513 Lehna C, Tholcken M. Using visual inquiry to reveal differences in nursing students' perception of case management. Pediatric Nursing. Jul-Aug. 2001;27(4):403-9. Exclusion reason: Wrong population. [pmid: 12025280].
514 Lehrman S, Gimbel R, Freedman J, et al. Development and implementation of an HIV/AIDS case management outcomes assessment programme. AIDS Care. 2002;14(6):751-61. Exclusion reason: Wrong outcome. [pmid: 12515262].
515 Leininger SM. One year later: did the quality circle of geriatric hip fracture care achieve quality outcomes?. Nursing Case Management. Nov-Dec. 1999;4(6):263-7. Exclusion reason: Wrong setting. [pmid: 10855150].
516 Leininger SM, Cohen PZ. The quality circle of hip fracture care. Nursing Case Management. Sep-Oct. 1998;3(5):220-6. Exclusion reason: Wrong setting. [pmid: 9832767].
517 LeMaster JW, Kruse RL, Lin W, et al. Health care expenses for people with diabetes mellitus in the United States: does having a usual care provider make a difference?. Journal of Health Care Finance. Summer. 2006;32(4):76-87. Exclusion reason: Wrong population.
518 Lemire ET. Community-based health reform: a case management model for consumer self-determination. Journal of Care Management. Jun. 1996;2(3):9-11. Exclusion reason: No original data.
519 Leonard B. Review: existing evidence does not support nurse led interventions in chronic obstructive pulmonary disease. Evidence-Based Nursing. Apr. 2006;9(2):56. Exclusion reason: Wrong outcome. [pmid: 16622933].
520 Leonard M, McGlone S, Boardman A. Taking integrated care management to the street: can we find the road to our triple aim?. Journal of Ambulatory Care Management. Apr-Jun. 2011;34(2):192-202. Exclusion reason: Wrong outcome. [pmid: 21415617].
521 Lepage B, Robert R, Lebeau M, et al. Use of a risk analysis method to improve care management for outlying inpatients in a university hospital. Quality & Safety in Health Care. Dec. 2009;18(6):441-5. Exclusion reason: Wrong setting. [pmid: 19955454].
522 LePansee KT. Pricing specialty carve-outs and disease management programs under managed care. Managed Care Quarterly. 1997;5(2):10-9. Exclusion reason: Unable to locate. [pmid: 10166983].
523 Les I, Doval E, Flavià M, et al. Quality of life in cirrhosis is related to potentially treatable factors. European Journal of Gastroenterology & Hepatology. Feb. 2010;22(2):221-7. Exclusion reason: Wrong intervention. [pmid: 19794311].
524 Lesperance ME, Bell SE, Ervin NE. Heart failure and weight gain monitoring. Lippincott's Case Management. Nov-Dec. 2005;10(6):287-93. Exclusion reason: Wrong intervention. [pmid: 16317329].
525 Leung AC, Liu CP, Tsui LL, et al. The use of the Minimum Data Set. Home Care in a case management project in Hong Kong. Care Management Journals. 2001;3(1):8-13. Exclusion reason: No original data. [pmid: 11974577].
526 Levine C, Halper D, Peist A, et al. Bridging troubled waters: family caregivers, transitions, and long-term care. Health Affairs. Jan-Feb. 2010;29(1):116-24. Exclusion reason: Wrong intervention. [pmid: 20048369].
527 Lewis BE, Mills C. Management of SNF beds in a group model HMO. Hmo Practice. Jul-Aug. 1991;5(4):133-8. Exclusion reason: No original data. [pmid: 10112049].
528 Lewis R. Comment. Managing and improving care of chronic disease in the NHS. British Journal of Nursing (BJN). 2004;13(3):125. Exclusion reason: No original data. [pmid: 14997072].
529 Lewis-Fleming G, Laing D, Whiting DR, et al. Case management and the active duty service member. Care Management. 2001;7(1):48. Exclusion reason: No original data.
530 Li LC, Davis AM, Lineker SC, et al. Effectiveness of the primary therapist model for rheumatoid arthritis rehabilitation: a randomized controlled trial. Arthritis & Rheumatism. Feb. 15. 2006;55(1):42-52. Exclusion reason: Wrong intervention. [pmid: 16463410].
531 Lichtman JH, Roumanis SA, Radford MJ, et al. Can practice guidelines be transported effectively to different settings? Results from a multicenter interventional study. Joint Commission Journal on Quality Improvement. Jan. 2001;27(1):42-53. Exclusion reason: Wrong intervention. [pmid: 11147239].
532 Lidz V, Bux DA, Platt JJ, et al. Transitional case management: a service model for AIDS outreach projects. Progress and issues in case management. 1992:112-44. Exclusion reason: Wrong intervention. [pmid: 1435991].
533 Liebman-Cohen EH. The effects of a nursing case management model on patient length of stay and variables related to cost of care delivery within an acute care setting. 1990. Exclusion reason: Wrong population.
534 Lillibridge J, Hanna B. Using telehealth to deliver nursing case management services to HIV/AIDS clients. Online Journal of Issues in Nursing. Jan. 1. 2009;14(1):9. Exclusion reason: No original data.
535 Lilly CM, De Meo DL, Sonna LA, et al. An intensive communication intervention for the critically ill. American Journal of Medicine. Oct. 15. 2000;109(6):469-75. Exclusion reason: Wrong setting. [pmid: 11042236].
536 Lim WK, Lambert SF, Gray LC. Effectiveness of case management and post-acute services in older people after hospital discharge. Medical Journal of Australia. Mar. 17. 2003;178(6):262-6. Exclusion reason: Wrong intervention. [pmid: 12633482].
537 Limb M. Blurring boundaries. Physiotherapy Frontline. Sep. 2005:9-13. Exclusion reason: Unable to locate.
538 Lin PC, Wang JL, Chang SY, et al. Effectiveness of a discharge-planning pilot program for orthopedic patients in Taiwan. International Journal of Nursing Studies. Sep. 2005;42(7):723-31. Exclusion reason: Wrong intervention. [pmid: 16084920].
539 Liu WI, Edwards H, Courtney M. Case management educational intervention with public health nurses: cluster randomized controlled trial. Journal of Advanced Nursing. Oct. 2010;66(10):2234-44. Exclusion reason: Wrong intervention. [pmid: 20636466].
540 Livadiotakis G, Gutman G, Hollander MJ. Rationing home care resources: how discharged seniors cope. Home Health Care Services Quarterly. 2003;22(2):31-42. Exclusion reason: Wrong intervention. [pmid: 12870711].
541 Lobati F, Herndon B, Bamberger D. Osteomyelitis: etiology, diagnosis, treatment and outcome in a public versus a private institution. Infection. Dec. 2001;29(6):333-6. Exclusion reason: Wrong intervention. [pmid: 11787835].
542 Lombardi D, Mizuno LT, Thornberry A. The use of the Zung Self-Rating Depression Scale to assist in the case management of patients living with HIV/AIDS. Care Management Journals. 2010;11(4):210-6. Exclusion reason: Wrong outcome. [pmid: 21197926].
543 London AS, LeBlanc AJ, Aneshensel CS. The integration of informal care, case management and community-based services for persons with HIV/AIDS. AIDS Care. Aug. 1998;10(4):481-503. Exclusion reason: Wrong outcome. [pmid: 9828968].
544 Long MJ, Marshall BS. Case management and the cost of care in the last month of life: evidence from one managed care setting. Health Care Management Review. 1999;24(4):45-53. Exclusion reason: Wrong Setting. [pmid: 10572788].
545 Long MJ, Marshall BS, Kurowski S. The effect of case management and type of case manager on service use and costs during the last month of life: results of a randomized trial [abstract]. Abstract Book/Association for Health Services Research. 1997;14:153-4. Exclusion reason: No original data.
546 Lonnroth K, Thuong LM, Lambregts K, et al. Private tuberculosis care provision associated with poor treatment outcome: comparative study of a semi-private lung clinic and the NTP in two urban districts in Ho Chi Minh City, Vietnam. National Tuberculosis Programme. International Journal of Tuberculosis & Lung Disease. Feb. 2003;7(2):165-71. Exclusion reason: Wrong intervention. [pmid: 12588018].
547 Lowenstein A. A legislative infrastructure that fosters case management. The Israeli Long-Term Care Insurance Law. Care Management Journals. 2000;2(1):15-20. Exclusion reason: No original data. [pmid: 11000718].
548 Lowenstein A. A case management demonstration project for the frail elderly in Israel. Care Management Journals. 2000;2(1):5-14. Exclusion reason: Wrong outcome. [pmid: 11000717].
549 Lowery J, Hopp F, Subramanian U, et al. Evaluation of a Nurse Practitioner Disease Management Model for Chronic Heart Failure: A Multi-Site Implementation Study. Congestive Heart Failure. Jan-Feb. 2012;18(1):64-71. Exclusion reason: Wrong intervention. [pmid: 22277180].
550 Lowrey S. Negotiating for successful outcomes in case management practice. Case Manager. Jan-Feb. 2004;15(1):70-2. Exclusion reason: No original data. [pmid: 14961023].
551 Lu CC, Su HF, Tsay SL, et al. A pilot study of a case management program for patients with chronic obstructive pulmonary disease (COPD). The journal of nursing research : JNR. Jun. 2007;15(2):89-98. Exclusion reason: Wrong setting. [pmid: 17551890].
552 Lubben JE, Damron-Rodriguez J. An international approach to community health care for older adults. Family & Community Health. Oct-Dec. 2003;26(4):338-49. Exclusion reason: No original data. [pmid: 14528139].
553 Lucente B, Rea MR, Vorce SH, et al. Redesigning care delivery in the community hospital. Nursing Economic$. Jul-Aug. 1995;13(4):242-7. Exclusion reason: Wrong setting. [pmid: 7630445].
554 Luque JL, Pereira MJ, Brown JD. Using computer systems to enhance case management. Quality Management in Health Care. Fall. 1996;5(1):17-24. Exclusion reason: Wrong intervention. [pmid: 10163105].
555 Lynn MR, Kelley B. Effects of case management on the nursing context--perceived quality of care, work satisfaction, and control over practice. Image - the Journal of Nursing Scholarship. 1997;29(3):237-41. Exclusion reason: Wrong setting. [pmid: 9378478].
556 MacKenzie A, Lee DT, Dudley-Brown S, et al. The processes of case management: a review of the evaluation of a pilot study for elderly people in Hong Kong. Journal of Nursing Management. Sep. 1998;6(5):293-301. Exclusion reason: No original data. [pmid: 9856006].
557 Macq J. Commentary: trials should inform structures and processes needed for tailoring interventions. BMJ: British Medical Journal. Mar. 2005;330(7492):665-6. Exclusion reason: No original data. [pmid: 15775002].
558 Magnus M, Schmidt N, Kirkhart K, et al. Association between ancillary services and clinical and behavioral outcomes among HIV-infected women. AIDS Patient Care & Stds. Mar. 2001;15(3):137-45. Exclusion reason: Wrong outcome. [pmid: 11313026].
559 Mahn VA. Clinical nurse case management: a service line approach. Nursing Management. Sep. 1993;24(9):48-50. Exclusion reason: Wrong setting. [pmid: 8367118].
560 Mahony SO, Blank A, Simpson J, et al. Preliminary report of a palliative care and case management project in an emergency department for chronically ill elderly patients. Journal of Urban Health. May. 2008;85(3):443-51. Exclusion reason: Wrong intervention. [pmid: 18363108].
561 Majumdar SR, Beaupre LA, Harley CH, et al. Use of a case manager to improve osteoporosis treatment after hip fracture: results of a randomized controlled trial. Archives of Internal Medicine. Oct. 22. 2007;167(19):2110-5. Exclusion reason: Wrong intervention. [pmid: 17954806].
562 Majumdar SR, Lier DA, Beaupre LA, et al. Osteoporosis case manager for patients with hip fractures: results of a cost-effectiveness analysis conducted alongside a randomized trial. Archives of Internal Medicine. Jan. 12. 2009;169(1):25-31. Exclusion reason: Wrong population. [pmid: 19139320].
563 Malla AK, Norman RM, McLean TS, et al. An integrated medical and psychosocial treatment program for psychotic disorders: patient characteristics and outcome. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Sep. 1998;43(7):698-705. Exclusion reason: Wrong population. [pmid: 9773219].
564 MaloneBeach EE, Zarit SH, Spore DL. Caregivers' perceptions of case management and community-based services: barriers to service use. Journal of Applied Gerontology. Jun. 1992;11(2):146-59. Exclusion reason: Wrong outcome. [pmid: 10171017].
565 Mamon J, Steinwachs DM, Fahey M, et al. Impact of hospital discharge planning on meeting patient needs after returning home. Health Services Research. Jun. 1992;27(2):155-75. Exclusion reason: Wrong intervention. [pmid: 1317367].
566 Maniapoto T, Gribben B. Establishing a Maori case management clinic. New Zealand Medical Journal. Feb. 21. 2003;116(1169):U328. Exclusion reason: Wrong intervention. [pmid: 12601405].
567 Manthorpe J, Jacobs S, Rapaport J, et al. Training for change: early days of individual budgets and the implications for social work and care management practice: a qualitative study of the views of trainers. British Journal of Social Work. 2009;39(7):1291-305. Exclusion reason: Wrong outcome.
568 Maravilla V, Graves MT, Newcomer R. Development of a standardized language for case management among high-risk elderly. Lippincott's Case Management. Jan-Feb. 2005;10(1):3-13. Exclusion reason: No original data. [pmid: 15685005].
569 Marek KD, Rantz MJ. Aging in place: a new model for long-term care. Nursing Administration Quarterly. 2000;24(3):1-11. Exclusion reason: Wrong intervention. [pmid: 10986927].
570 Margalit AP, El-Ad A. Costly patients with unexplained medical symptoms: a high-risk population. Patient education and counseling. Feb. 2008;70(2):173-8. Exclusion reason: Wrong intervention. [pmid: 17983723].
571 Markle A. The economic impact of case management. Case Manager. Jul-Aug. 2004;15(4):54-8. Exclusion reason: No original data. [pmid: 15247897].
572 Markle-Reid M, Browne G, Roberts J, et al. The 2-year costs and effects of a public health nursing case management intervention on mood-disordered single parents on social assistance. Journal of Evaluation in Clinical Practice. Feb. 2002;8(1):45-59. Exclusion reason: Wrong population. [pmid: 11882101].
573 Marsh D, Hashim R, Hassany F, et al. Front-line management of pulmonary tuberculosis: an analysis of tuberculosis and treatment practices in urban Sindh, Pakistan. Tubercle & Lung Disease. Feb. 1996;77(1):86-92. Exclusion reason: Wrong intervention. [pmid: 8733421].
574 Martin EM, Coyle MK. Nursing protocol for telephonic supervision of clients. Rehabilitation Nursing. Mar-Apr. 2006;31(2):54-7. Exclusion reason: No original data. [pmid: 16526522].
575 Martin EM, French L, Janos A. Home/community monitoring using telephonic follow-up. NeuroRehabilitation. 2010;26(3):279-83. Exclusion reason: No original data. [pmid: 20448317].
576 Martin JS, Ummenhofer W, Manser T, et al. Interprofessional collaboration among nurses and physicians: making a difference in patient outcome. Swiss Medical Weekly. 2010;140:w13062. Exclusion reason: Wrong intervention. [pmid: 20458647].
577 Martinen M, Freundl M. Managing congestive heart failure in long-term care: development of an interdisciplinary protocol. Journal of Gerontological Nursing. Dec. 2004;30(12):5-12. Exclusion reason: Wrong setting. [pmid: 15624691].
578 Mason DJ. SOS reports. The state of the science: focus on chronic illness. American Journal of Nursing. 2005;105(2):27-8. Exclusion reason: No original data.
579 Massie C. Using total quality management in long-term care case management. American Journal of Medical Quality. 1993;8(2):79-86. Exclusion reason: Wrong intervention. [pmid: 8513256].
580 Mateo MA, Matzke K, Newton C. Designing measurements to access case management outcomes. Nursing Case Management. Jan-Feb. 1998;3(1):2-6. Exclusion reason: No original data. [pmid: 9526390].
581 Mateo MA, Matzke K, Newton C. Designing measurements to assess case management outcomes… epilogue. Lippincott's Case Management. Nov-Dec. 2002;7(6):261-6. Exclusion reason: No original data. [pmid: 12478228].
582 Matrone JS. The effect of a staff development program on nursing case management competencies and patient outcomes in the acute care setting [PH.D.]. BOSTON COLLEGE. 1990. Exclusion reason: Wrong outcome.
583 Matthews JH, Coe TR, Bruflat C, et al. The patient lock modelCopyright: a continuum of care. Policy, Politics, & Nursing Practice. May. 2010;11(2):132-9. Exclusion reason: No original data. [pmid: 20971932].
584 Mayaud P, Mosha F, Todd J, et al. Improved treatment services significantly reduce the prevalence of sexually transmitted diseases in rural Tanzania: results of a randomized controlled trial. AIDS. Dec. 1997;11(15):1873-80. Exclusion reason: Wrong intervention. [pmid: 9412707].
585 Maynard A, Bloor K. Managing medical practice: time for a quantitative approach?. Clinician in Management. 2003;12(1):33-8. Exclusion reason: Wrong intervention.
586 Mayo NE, Scott SC, Ahmed S. Case management poststroke did not induce response shift: the value of residuals. Journal of Clinical Epidemiology. Nov. 2009;62(11):1148-56. Exclusion reason: No original data. [pmid: 19595568].
587 McCall N, Cromwell J. Results of the Medicare Health Support Disease-Management Pilot Program. New England Journal of Medicine. 2011;365(18):1704-12. Exclusion reason: Wrong intervention. [pmid: 22047561].
588 McClaran J, Lam Z, Franco E, et al. Can case management be taught in a multidisciplinary forum?. Journal of Continuing Education in the Health Professions. Summer. 1999;19(3):181-91. Exclusion reason: Wrong outcome.
589 McClaran J, Lam Z, Snell L, et al. The importance of the case management approach: perceptions of multidisciplinary team members. Journal of Case Management. 1998;7(3):117-26. Exclusion reason: Wrong outcome. [pmid: 10703377].
590 McCorkle R, Strumpf NE, Nuamah IF, et al. A specialized home care intervention improves survival among older post-surgical cancer patients. Journal of the American Geriatrics Society. Dec. 2000;48(12):1707-13. Exclusion reason: No original data. [pmid: 11129765].
591 McCormick SA. Advanced practice nursing for congestive heart failure. Critical Care Nursing Quarterly. Feb. 1999;21(4):1-8. Exclusion reason: No original data. [pmid: 10646426].
592 McCusker J, Verdon J. Do geriatric interventions reduce emergency department visits? A systematic review. Journals of Gerontology Series A: Biological Sciences & Medical Sciences. Jan. 2006;61(1):53-62. Exclusion reason: No original data. [pmid: 16456194].
593 McDonald AB. Telemonitoring in disease management: a format for successfully facilitating behavior change. Journal of Care Management. Jun. 2000;6(3):24-6. Exclusion reason: Wrong intervention.
594 McEvoy C. Community care and “gerontechnology”. Studies in Health Technology & Informatics. 1998;48:277-9. Exclusion reason: No original data. [pmid: 10186528].
595 McGlynn EA. Choosing chronic disease measures for HEDIS: conceptual framework and review of seven clinical areas. Managed Care Quarterly. 1996;4(3):54-77. Exclusion reason: Wrong intervention. [pmid: 10159034].
596 McKendry MJ, Van Horn J. Tips, tools, and techniques Today's hospital-based case manager: how one hospital integrated/adopted evidence-based medicine using INTERQUAL criteria. Lippincott's Case Management. Mar-Apr. 2004;9(2):61-71. Exclusion reason: Wrong setting. [pmid: 15192500].
597 McKendry MJ, Van Horn J. Today's hospital-based case manager: how one hospital integrated/adopted evidenced-based medicine using InterQual criteria. Lippincott's Case Management. Mar-Apr. 2004;9(2):61-71. Exclusion reason: Wrong setting. [pmid: 15192500].
598 McKenzie CB, Torkelson NG, Holt MA. Care and cost: nursing case management improves both. Nursing Management. Oct. 1989;20(10):30-4. Exclusion reason: Background. [pmid: 2511529].
599 McLeod A, Shearer M, Taylor M. How to use a case manager--a partnership approach. Australian Family Physician. Jan-Feb. 2005;34(1-2):69-71. Exclusion reason: No original data. [pmid: 15727363].
600 McPhaul KM, Rosen J, Bobb S, et al. An exploratory study of mandated safety measures for home visiting case managers. Canadian Journal of Nursing Research. Dec. 2007;39(4):173-89. Exclusion reason: Wrong population. [pmid: 18277794].
601 McRae IS, Butler JRG, Sibthorpe BM, et al. A cost effectiveness study of integrated care in health services delivery: a diabetes program in Australia. BMC Health Services Research. 2008;8:205. Exclusion reason: Wrong intervention. [pmid: 18834551].
602 McWilliam CL, Hoch JS, Coyte PC, et al. Can we afford consumers choice in home care?. [Erratum appears in Care Manag J. 2008;9(1):table of contents Note: Coyte, Peter [corrected to Coyte, Peter C]]. Care Management Journals. 2007;8(4):171-8. Exclusion reason: Wrong intervention. [pmid: 18236956].
603 McWilliam CL, Stewart M, Vingilis E, et al. Flexible client-driven in-home case management: an option to consider. [Erratum appears in Care Manag J. 2008;9(2):table of contents Note: Hoch, Jeffrey [corrected to Hoch, Jeffrey S]]. Care Management Journals. 2004;5(2):73-86. Exclusion reason: Wrong intervention. [pmid: 16047912].
604 Meeks JB. A social work case management experience in a managed care setting: the need for effective communication. Home Health Care Management & Practice. Oct. 2001;13(6):444-51. Exclusion reason: No original data.
605 Meenan RT, Feeny D, Labby D, et al. Using health-related quality of life assessments to evaluate care support within Medicaid. Care Management Journals. 2008;9(2):42-50. Exclusion reason: No original data. [pmid: 18619084].
606 Meier DE, Thar W, Jordan A, et al. Integrating case management and palliative care. Journal of palliative medicine. Feb. 2004;7(1):119-34. Exclusion reason: No original data. [pmid: 15000796].
607 Melville A, Richardson R, Lister-Sharp D, et al. Complications of diabetes: renal disease and promotion of self-management… this paper is an edited version of Effective Health Care volume 6 number 1. Quality in Health Care. Dec. 2000;9(4):257-63. Exclusion reason: No original data. [pmid: 11101711].
608 Meng H, Friedman B, Wamsley BR, et al. Effect of a consumer-directed voucher and a disease-management-health-promotion nurse intervention on home care use. Gerontologist. Apr. 2005;45(2):167-76. Exclusion reason: Wrong intervention. [pmid: 15799981].
609 Mercadante S. Pain treatment and outcomes for patients with advanced cancer who receive follow-up care at home. Cancer. Apr. 15. 1999;85(8):1849-58. Exclusion reason: Wrong intervention. [pmid: 10223581].
610 Merzel C, Crystal S, Sambamoorthi U, et al. New Jersey's Medicaid waiver for acquired immunodeficiency syndrome. Health Care Financing Review. 1992;13(3):27-44. Exclusion reason: Wrong intervention. [pmid: 10120180].
611 Messer B. Reducing lengths of stays in the total joint replacement population. Orthopaedic Nursing. Mar-Apr. 1998:23-5. Exclusion reason: Wrong setting. [pmid: 9601408].
612 Messeri PA, Abramson DM, Aidala AA, et al. The impact of ancillary HIV services on engagement in medical care in New York City. AIDS Care. Aug. Suppl 1. 2002;14:S15-29. Exclusion reason: Wrong outcome. [pmid: 12204139].
613 Metts VL. Management focus. The emotionally intelligent case manager: an unexpected, bird's-eye view… part two of a two-part series. Case in Point. 2008;6(2):11-3. Exclusion reason: Wrong setting.
614 Meyer LC. Home medical equipment. How case managers can augment disease management strategies with HME. Case Manager. 1997;8(4):45-9. Exclusion reason: No original data.
615 Micco A, Hamilton ACS, Martin MJ, et al. Case manager attitudes toward client-directed care. Journal of Case Management. Fall. 1995;4(3):95-101. Exclusion reason: Wrong outcome. [pmid: 7580955].
616 Michael S, Candela L. Using aesthetic knowing to teach diversity of the chronic illness experience to nursing students. Home Health Care Management & Practice. Oct. 2006;18(6):439-43. Exclusion reason: Wrong intervention.
617 Michaels C. A nursing HMO -- 10 months with Carondelet St Mary's Hospital-based nurse case management. Aspen's Advisor for Nurse Executives. Aug. 1. 1991;6(11):3-4. Exclusion reason: No original data. [pmid: 1817601].
618 Michelman M, Collier P, Dion C, et al. A case management protocol: reducing unnecessary Medicare admissions in Florida. Lippincott's Case Management. Mar-Apr. 2005;10(2):72-82. Exclusion reason: Wrong setting. [pmid: 15815222].
619 Middleton J. The effect of case management on glycemic control in patients with type 2 diabetes. Case Manager. Nov-Dec. 2003;14(6):43-7. Exclusion reason: Wrong intervention. [pmid: 14618148].
620 Middleton S, Donnelly N, Harris J, et al. Nursing intervention after carotid endarterectomy: a randomized trial of Co-ordinated Care Post-Discharge (CCPD). Journal of Advanced Nursing. Nov. 2005;52(3):250-61. Exclusion reason: Wrong intervention. [pmid: 16194178].
621 Mieres JH, Phillips LM. The interdisciplinary approach to culturally tailored medical care: “social networking” for decreasing risk: comment on “the effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial ” and “trial of family and friend support for weight loss in African American adults”. Archives of Internal Medicine. Oct. 26. 2009;169(19):1804-5. Exclusion reason: No original data. [pmid: 19858439].
622 Milette L, Hebert R, Veil A. Integrated service delivery networks for seniors: early perceptions of family physicians. Canadian Family Physician. Aug. 2005;51:1104-5. Exclusion reason: No original data. [pmid: 16926947].
623 Miller DK, Lewis LM, Nork MJ, et al. Controlled trial of a geriatric case-finding and liaison service in an emergency department. Journal of the American Geriatrics Society. May. 1996;44(5):513-20. Exclusion reason: Wrong intervention. [pmid: 8617898].
624 Miller LC, Cox KR. Case management for patients with heart failure: a quality improvement intervention. Journal of Gerontological Nursing. May. 2005;31(5):20-8. Exclusion reason: No original data. [pmid: 15916200].
625 Milne CT, Pelletier LC. Enhancing staff skill: developing critical pathways at a community hospital. Journal of Nursing Staff Development. May-Jun. 1994;10(3):160-2. Exclusion reason: No original data. [pmid: 7807236].
626 Minnick AF, Mion LC, Johnson ME, et al. How unit level nursing responsibilities are structured in US hospitals. Journal of Nursing Administration. Oct. 2007;37(10):452-8. Exclusion reason: Wrong setting. [pmid: 17914292].
627 Mion LC, Palmer RM, Anetzberger GJ, et al. Establishing a case-finding and referral system for at-risk older individuals in the emergency department setting: the SIGNET model. Journal of the American Geriatrics Society. Oct. 2001;49(10):1379-86. Exclusion reason: Wrong intervention. [pmid: 11890500].
628 Mitchell JM, Anderson KH. Effects of case management and new drugs on Medicaid AIDS spending. Health Affairs. Jul-Aug. 2000;19(4):233-43. Exclusion reason: Wrong intervention. [pmid: 10916979].
629 Mohler PJ, Mohler NB. Improving chronic illness care: lessons learned in a private practice. Family Practice Management. Nov-Dec. 2005;12(10):50-6. Exclusion reason: Wrong intervention. [pmid: 16366442].
630 Moll S, Severson MA. Deep vein thrombosis: the hidden threat. Care Management. 2004:5-47. Exclusion reason: Wrong intervention.
631 Momany ET, Flach SD, Nelson FD, et al. A cost analysis of the Iowa Medicaid primary care case management program. Health Services Research. Aug. 2006;41(4 Pt 1):1357-71. Exclusion reason: Wrong intervention. [pmid: 16899012].
632 Monsen KA, Kerr MJ. Mining quality documentation data for golden outcomes. Home Health Care Management & Practice. Apr. 2004;16(3):192-9. Exclusion reason: Wrong intervention.
633 Mor V, Intrator O, Feng Z, et al. The revolving door of rehospitalization from skilled nursing facilities. Health Affairs. Jan-Feb. 2010;29(1):57-64. Exclusion reason: Wrong intervention. [pmid: 20048361].
634 Morales-Asencio JM, Morilla-Herrera JC, Martin-Santos FJ, et al. The association between nursing diagnoses, resource utilisation and patient and caregiver outcomes in a nurse-led home care service: longitudinal study. International Journal of Nursing Studies. Feb. 2009;46(2):189-96. Exclusion reason: Wrong outcome. [pmid: 18990392].
635 Morath J. Beyond utilization control: managing care with customers… adapted, with permission, from Patient as Partner: The Cornerstone of Community Health Improvement by the American Organization of Nurse Executives, published by American Hospital Publishing, 1997. All rights reserved. Managed Care Quarterly. Summer. 1998;6(3):40-52. Exclusion reason: No original data. [pmid: 10182531].
636 Moreo K, Greene L. Medication therapy management programs: the case for essential roles of nurse case managers. Care Management. 2010;16(2):7. Exclusion reason: Wrong intervention.
637 Morin D, Aubin M, Vezina L, et al. From hospital to home after cardiac surgery: evaluation of a community nursing care management model. Professional Case Management. Jul-Aug. 2009;14(4):167-75. Exclusion reason: Wrong intervention. [pmid: 19625933].
638 Morishita L, Boult C, Boult L, et al. Satisfaction with outpatient geriatric evaluation and management (GEM). Gerontologist. Jun. 1998;38(3):303-8. Exclusion reason: Wrong intervention. [pmid: 9640850].
639 Morrish DW, Beaupre LA, Bell NR, et al. Facilitated bone mineral density testing versus hospital-based case management to improve osteoporosis treatment for hip fracture patients: additional results from a randomized trial. Arthritis & Rheumatism. Feb. 15. 2009;61(2):209-15. Exclusion reason: Wrong intervention. [pmid: 19177538].
640 Morrison J. Identifying people at high risk of emergency hospital admission: simply measuring previous hospital admission rates would be misleading. BMJ: British Medical Journal. Feb. 5. 2005;330(7486):266. Exclusion reason: No original data. [pmid: 15695251].
641 Morrison RS, Beckworth V. Outcomes for patients with congestive heart failure in a nursing case management model. Nursing Case Management. May-Jun. 1998;3(3):108-16. Exclusion reason: Wrong intervention. [pmid: 10067547].
642 Moscowitz B. Bridging to family and community support for older adults and the Domain Management Model. Topics in Stroke Rehabilitation. Autumn. 2002;9(3):75-86. Exclusion reason: No original data. [pmid: 14523709].
643 Mosley DG, Peterson E, Martin DC. Do hierarchical condition category model scores predict hospitalization risk in newly enrolled Medicare Advantage participants as well as probability of repeated admission scores?. Journal of the American Geriatrics Society. Dec. 2009;57(12):2306-10. Exclusion reason: Wrong intervention. [pmid: 19874405].
644 Mullahy CM. Concurrent review. Time to make a difference. Case Manager. 2005;16(2):10. Exclusion reason: No original data.
645 Mullahy CM. Concurrent review. To move forward, we first look at our past. Case Manager. 2006;17(3):14. Exclusion reason: No original data.
646 Mullen BA, Kelley PAW. Diabetes nurse case management: an effective tool. Journal of the American Academy of Nurse Practitioners. Jan. 2006;18(1):22-30. Exclusion reason: Wrong intervention. [pmid: 16403209].
647 Munoz CC. Addressing the linguistic and cultural needs of case management clients. Case Manager. Nov-Dec. 2001;12(6):58-62. Exclusion reason: No original data. [pmid: 11704736].
648 Munson M, Proctor E, Morrow-Howell N, et al. Case managers speak out: responding to depression in community long-term care. Psychiatric Services. Aug. 2007;58(8):1124-7. Exclusion reason: Wrong intervention. [pmid: 17664526].
649 Murdoch LD, Kunkel SR, Appelbaum RA, et al. Care managers as research interviewers: a test of a strategy for gathering consumer satisfaction information. Journal of Applied Gerontology. Sep. 2004;23(3):234-46. Exclusion reason: Wrong outcome.
650 Murphy M, Noetscher C, Lagoe R. A multihospital effort to reduce inpatient lengths of stay for pneumonia. Journal of Nursing Care Quality. Jun. 1999;13(5):11-23. Exclusion reason: Wrong setting. [pmid: 10343477].
651 Murray LP. The effectiveness of case managers in primary ambulatory care. Case Manager. Jul-Aug. 2003;14(4):66-8. Exclusion reason: Wrong outcome. [pmid: 12869954].
652 Murray ME, Broad JE, Welnick KE. Tips, tools, and techniques. Case manager associate -- a case manager extender. Nursing Case Management. Nov-Dec. 1999;4(6):255-62. Exclusion reason: No original data. [pmid: 10855149].
653 Murray ME, Darmody JV. Clinical and fiscal outcomes of utilization review. Outcomes Management. Jan-Mar. 2004;8(1):19-27. Exclusion reason: Wrong intervention. [pmid: 14740580].
654 Myers F, MacDonald C. Power to the people? Involving users and carers in needs assessments and care planning -- views from the practitioner. Health & Social Care in the Community. 1996;4(2):86-95. Exclusion reason: Wrong outcome.
655 Nakatani H, Shimanouchi S. Factors in care management affecting client outcomes in home care. Nursing & Health Sciences. Dec. 2004;6(4):239-46. Exclusion reason: Wrong population. [pmid: 15507044].
656 Naylor M, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. Exclusion reason: Background. [pmid: 15086645].
657 Naylor MD. Transitional care for older adults: a cost-effective model. LDI Issue Brief. Apr-May. 2004;9(6):1-4. Exclusion reason: No original data. [pmid: 15181894].
658 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. Feb. 17. 1999;281(7):613-20. Exclusion reason: Wrong intervention. [pmid: 10029122].
659 Nelson JM, Arnold-Powers P. Community case management for frail, elderly clients: the nurse case manager's role. Journal of Nursing Administration. Sep. 2001;31(9):444-50. Exclusion reason: Wrong outcome. [pmid: 11561425].
660 Netting FE, Williams FG. Case manager-physician collaboration: implications for professional identity, roles, and relationships. Health & Social Work. Aug. 1996;21(3):216-24. Exclusion reason: No original data. [pmid: 8854126].
661 Netting FE, Williams FG. Geriatric case managers: integration into physician practices. Care Management Journals. 1999;1(1):3-9. Exclusion reason: No original data. [pmid: 10835791].
662 Netting FE, Williams FG. Expanding the boundaries of primary care for elderly people. Health & Social Work. Nov. 2000;25(4):233-42. Exclusion reason: Wrong intervention. [pmid: 11103696].
663 Newcomer R, Arnsberger P, Zhang X. Case management, client risk factors and service use. Health Care Financing Review. 1997;19(1):105-20. Exclusion reason: Wrong intervention. [pmid: 10179994].
664 Newcomer R, Harrington C, Kane R. Implementing the second generation Social Health Maintenance Organization. Journal of the American Geriatrics Society. 2000;48(7):829-34. Exclusion reason: Wrong intervention. [pmid: 10894325].
665 Newcomer R, Kang T, Graham C. Outcomes in a nursing home transition case-management program targeting new admissions. The Gerontologist. Jun. 2006;46(3):385-90. Exclusion reason: Wrong setting. [pmid: 16731878].
666 Newell M. Patient contracting for improved outcomes. Journal of Care Management. Aug. 1997;3(4):76. Exclusion reason: No original data.
667 Newman M, Cohen EL. Theory of the nurse-client partnership. Nurse case management in the 21st century. 1996:119-23. Exclusion reason: No original data.
668 Newman MA, Lamb GS, Michaels C. Nurse case management: the coming together of theory and practice. A developing discipline: selected works of Margaret Newman. National League for Nursing. 1995:249-63. Exclusion reason: No original data.
669 Nichols DJ, Flarey DL. Legal liabilities in case management. Handbook of nursing case management: health care delivery in a world of managed care. Gaithersburg, MD. Aspen Publishers. 1996:424-42. Exclusion reason: No original data.
670 Nixon A. Tell us what you really think! Case managers weigh in on the profession. Case Manager. 2000;11(5):55-9. Exclusion reason: No original data. [pmid: 11935585].
671 Noble H, Meyer J, Bridges J, et al. Examining renal patients' death trajectories without dialysis. End of Life Care Journal. May. 2010;4(2):26-34. Exclusion reason: No original data.
672 Noel HC, Vogel DC. Resource costs and quality of life outcomes for homebound elderly using telemedicine integrated with nurse case management. Care Management. 2000;6(5):22. Exclusion reason: Wrong intervention.
673 Noelker LS. Case management for caregivers. Care Management Journals. 2002;3(4):199-204. Exclusion reason: No original data. [pmid: 12847937].
674 Noelker LS, Bass DM. Service use by caregivers of elderly receiving case management. Journal of Case Management. 1995;4(4):142-9. Exclusion reason: Wrong intervention. [pmid: 8715176].
675 Noetscher CM. Using data in the case management process. Journal of Nursing Care Quality. Nov. Spec No. 1999:86-97. Exclusion reason: No original data. [pmid: 10616277].
676 Nolan MT, Johnson C, Coleman J, et al. Unifying organizational approaches to measuring and managing patient outcomes. Journal of Nursing Administration. Jan. 2000;30(1):27-33. Exclusion reason: Wrong intervention. [pmid: 10650433].
677 Noltimier M, Moe K, Zimmerman M. Informatics. Our special patients -- moving their care online. JEN: Journal of Emergency Nursing. Jun. 1999;25(3):212-5. Exclusion reason: No original data.
678 Nordmann A, Heilmbauer I, Walker T, et al. A case-management program of medium intensity does not improve cardiovascular risk factor control in coronary artery disease patients: the Heartcare I trial. American Journal of Medicine. May. 2001;110(7):543-50. Exclusion reason: Wrong intervention. [pmid: 11343668].
679 Norris K, Merriman MP, Curtis JR, et al. Next of kin perspectives on the experience of end-of-life care in a community setting. Journal of Palliative Medicine. Oct. 2007;10(5):1101-15. Exclusion reason: Wrong intervention. [pmid: 17985967].
680 Norris SL, Messina PJ, Caspersen CJ, et al. Strategies for reducing morbidity and mortality from diabetes through health-care system interventions and diabetes self-management education in community settings: a report on recommendations of the Task Force on Community Preventive Services. MMWR: Morbidity & Mortality Weekly Report. 2001;50(RR-16):1-15. Exclusion reason: No original data. [pmid: 11215787].
681 Norris SL, Nichols PJ, Caspersen CJ, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. May. 2002;22(4 Suppl):15-38. Exclusion reason: Background. [pmid: 11985933].
682 Norris SL, Saadine J, Chowdhury FM, et al. Interventions to promote screening for diabetic retinopathy. Cochrane Database of Systematic Reviews. 2010;(4). Exclusion reason: Wrong intervention.
683 Novak DA. Nurse case managers' opinions of their role. Nursing Case Management. 1998;3(6):231-9. Exclusion reason: Wrong outcome. [pmid: 9934114].
684 Nowak F, Nagle L, Bernardo A. Review: case management programmes improve patient outcomes. [commentary on Ferguson JA, Weinberger M. Case management programs in primary care. J GEN INTERN MED 1998 Feb;13:123-6]. Evidence-Based Nursing. 1998;1(4):128. Exclusion reason: No original data.
685 Nufer Y, Rosenberg H, Smith DH. Consumer and case manager perceptions of important case manager characteristics. Journal of Rehabilitation. Oct-Dec. 1998;64(4):40-6. Exclusion reason: Wrong outcome.
686 Nyamathi A, Flaskerud JH, Leake B, et al. Evaluating the impact of peer, nurse case-managed, and standard HIV risk-reduction programs on psychosocial and health-promoting behavioral outcomes among homeless women. Research in Nursing & Health. Oct. 2001;24(5):410-22. Exclusion reason: Wrong intervention. [pmid: 11746070].
687 Nyamathi A, Nahid P, Berg J, et al. Efficacy of nurse case-managed intervention for latent tuberculosis among homeless subsamples. Nursing Research. Jan-Feb. 2008;57(1):33-9. Exclusion reason: Wrong intervention. [pmid: 18091290].
688 O'Donnell JC, Toseland RW. Does geriatric evaluation and management improve the health behavior of older veterans in psychological distress?. Journal of Aging & Health. Nov. 1997;9(4):473-97. Exclusion reason: No original data. [pmid: 10182389].
689 O'Donnell LT. Ethical dilemmas among nurses as they transition to hospital case management. Professional Case Management. 2007;12(4):219-31. Exclusion reason: Wrong setting. [pmid: 17667785].
690 O'Dowd A. Labour plans 3,000 community matrons. Nursing Times. 2004;100(24):4. Exclusion reason: No original data.
691 O'Dowd A. A district nursing renaissance. Nursing Times. 2005;101(9):24-5. Exclusion reason: No original data. [pmid: 15783152].
692 Oeseburg B, Wynia K, Middel B, et al. Effects of case management for frail older people or those with chronic illness: a systematic review. Nursing Research. May-Jun. 2009;58(3):201-10. Exclusion reason: No original data. [pmid: 19448524].
693 Ohkado A, Williams G, Ishikawa N, et al. The management for tuberculosis control in Greater London in comparison with that in Osaka City: lessons for improvement of TB control management in Osaka City urban setting. Health Policy. Jul. 2005;73(1):104-23. Exclusion reason: Wrong intervention. [pmid: 15911061].
694 Olbort R, Mahler C, Campbell S, et al. Doctors' assistants' views of case management to improve chronic heart failure care in general practice: a qualitative study. Journal of Advanced Nursing. Apr. 2009;65(4):799-808. Exclusion reason: Wrong outcome. [pmid: 19228240].
695 O'Leary KJ, Lindquist LA, Colone MA, et al. Effect of a hospitalist-care coordinator team on a nonteaching hospitalist service. Journal of Hospital Medicine. Mar. 2008;3(2):103-9. Exclusion reason: Wrong setting. [pmid: 18438806].
696 Oliva NL, Newcomer R. The impact of RN case management activities on health services utilization. Communicating Nursing Research. Spring. 2008;41:444. Exclusion reason: Wrong outcome.
697 Olivas GS, Del Togno-Armanasco V, Erickson JR, et al. Case management -- a bottom-line care delivery model: adaptation of the model… part 2. Journal of Nursing Administration. Dec. 1989;19(12):12-7. Exclusion reason: Wrong outcome. [pmid: 2511284].
698 Olson LL. Commentary on Understanding variances in hospital stay. [original article by Bueno MM et al appears in NURS MANAGE 1993;24(11):51-7]. AONE's Leadership Prospectives. 1994;2(3):6. Exclusion reason: No original data.
699 O'Malley PG, Feuerstein IM, Taylor AJ. Impact of electron beam tomography, with or without case management, on motivation, behavioral change, and cardiovascular risk profile: a randomized controlled trial. JAMA. May. 7. 2003;289(17):2215-23. Exclusion reason: Wrong population. [pmid: 12734132].
700 Omar AR, Suppiah N, Chai P, et al. Efficacy of community-based multidisciplinary disease management of chronic heart failure. Singapore Medical Journal. Jun. 2007;48(6):528-31. Exclusion reason: Wrong intervention. [pmid: 17538751].
701 Paez KA, Allen JK. Cost-effectiveness of nurse practitioner management of hypercholesterolemia following coronary revascularization. Journal of the American Academy of Nurse Practitioners. Sep. 2006;18(9):436-44. Exclusion reason: Wrong intervention. [pmid: 16958775].
702 Page CI. Commentary on Deploying patient-focused care in the emergency department. [original article by Donovan M appears in LEADERSHIP MANAGE EMERG NURS 1993:2(10),3-18]. ENA'S Nursing Scan in Emergency Care. Jul-Aug. 1994;4(4):11. Exclusion reason: No original data.
703 Page L, Lang M. Supporting a hospital's bottom line with chronic care management requires careful planning. Clinical excellence strategies 2003. 2002:24-6. Exclusion reason: No original data.
704 Palese A, Comuzzi C, Bresadola V. Global case management: the “nurse case manager” model applied to day surgery in Italy. Lippincott's Case Management. Mar-Apr. 2005;10(2):83-92. Exclusion reason: Wrong setting. [pmid: 15815224].
705 Palmas W, Teresi J, Weinstock RS, et al. Acceptability to primary care providers of telemedicine in diabetes case management. Journal of Telemedicine & Telecare. 2008;14(6):306-8. Exclusion reason: Wrong outcome. [pmid: 18776076].
706 Palsbo SE, Ho PS. Consumer evaluation of a disability care coordination organization. Journal of Health Care for the Poor & Underserved. Nov. 2007;18(4):887-901. Exclusion reason: Wrong intervention. [pmid: 17982213].
707 Papenhausen JL. The effects of nursing case management intervention on perceived severity of illness, enabling skill, self-help, and life quality in chronically ill older adults. 1995:290. Exclusion reason: Wrong intervention.
708 Park E, Huber DL, Tahan HA. The evidence base for case management practice. Western Journal of Nursing Research. Oct. 2009;31(6):693-714. Exclusion reason: Wrong outcome. [pmid: 19349615].
709 Park EJ. A comparison of knowledge and activities in case management practice. 2006:273. Exclusion reason: Wrong population.
710 Park EJ, Huber DL. Case management workforce in the United States. Journal of Nursing Scholarship. 2009;41(2):175-83. Exclusion reason: Wrong outcome. [pmid: 19538702].
711 Parkman CA. CAM trends. Faith and healing. Case Manager. Jan-Feb. 2003;14(1):33-6. Exclusion reason: No original data. [pmid: 12532075].
712 Parrish MM, O'Malley K, Adams RI, et al. Implementation of the Care Transitions Intervention: sustainability and lessons learned. Professional Case Management. Nov-Dec. 2009;14(6):282-95. Exclusion reason: Wrong intervention. [pmid: 19935345].
713 Patrick H, Roberts N, Hutt R, et al. Nursing models and theory. Evaluation of innovations in nursing practice: report and discussion. British Journal of Nursing (BJN). May. 11-24. 2006;15(9):520-3. Exclusion reason: Wrong intervention. [pmid: 16723928].
714 Patterson PK, Maynard H, Chesnut RM, et al. Evidence of case management effect on traumatic-brain-injured adults in rehabilitation. Care Management Journals. 1999;1(2):87-97. Exclusion reason: No original data. [pmid: 10644292].
715 Payne FJ, Sharrett CS, Poretz DN, et al. Community-based case management of HIV disease. American Journal of Public Health. Jun. 1992;82(6):893-4. Exclusion reason: Wrong intervention. [pmid: 1585973].
716 Pearson A, Laschinger H, Porritt K, et al. Comprehensive systematic review of evidence on developing and sustaining nursing leadership that fosters a healthy work environment in healthcare. International Journal of Evidence-Based Healthcare. 2007;5(2):208-53. Exclusion reason: No original data. [pmid: 21631788].
717 Pearson S, Inglis SC, McLennan SN, et al. Prolonged Effects of a Home-Based Intervention in Patients With Chronic Illness. Arch Intern Med. Mar. 27. 2006;166(6):645-50. Exclusion reason: Wrong intervention. [pmid: 16567604].
718 Penhale B, Bradley G, Manthorpe J, et al. Charging for care -- the views of care managers. Working with Older People: Community Care Policy & Practice. Jun. 2001;5(2):23-6. Exclusion reason: Wrong outcome.
719 Pepe MC, Applebaum RA. Ohio's options for elders initiative: cutting corners or the cutting edge?. Journal of Case Management. 1996;5(1):12-8. Exclusion reason: No original data. [pmid: 8715696].
720 Persell SD, Murff HJ, Spigel DR, et al. Does case management improve physiologic outcomes for patients with poorly controlled diabetes?. Journal of Clinical Outcomes Management. 2004;11(7):407-8. Exclusion reason: No original data.
721 Peters-Klimm F, Muller-Tasch T, Schellberg D, et al. Rationale, design and conduct of a randomised controlled trial evaluating a primary care-based complex intervention to improve the quality of life of heart failure patients: HICMan (Heidelberg Integrated Case Management). BMC cardiovascular disorders. 2007;7(25). Exclusion reason: No original data. [pmid: 17716364].
722 Peters-Klimm F, Olbort R, Campbell S, et al. Physicians' view of primary care-based case management for patients with heart failure: a qualitative study. International Journal for Quality in Health Care. Oct. 2009;21(5):363-71. Exclusion reason: Wrong outcome. [pmid: 19684033].
723 Petiprin A. Letter to the editor… “direct contact with the patient”. Case Manager. 2001;12(4):5. Exclusion reason: No original data.
724 Peytremann-Bridevaux I, Gex G, Bridevaux PO, et al. Chronic disease management programs for adults with asthma. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention.
725 Pfeffer GN, Schnack JA. Nurse practitioners as leaders in a quality health care delivery system. Advanced Practice Nursing Quarterly. Fall. 1995;1(2):30-9. Exclusion reason: No original data. [pmid: 9447013].
726 Philis-Tsimikas A, Walker C, Rivard L, et al. Improvement in diabetes care of underinsured patients enrolled in project dulce: a community-based, culturally appropriate, nurse case management and peer education diabetes care model. Diabetes Care. Jan. 2004;27(1):110-5. Exclusion reason: Wrong intervention. [pmid: 14693975].
727 Phillips BR, Kemper P, Applebaum RA. The evaluation of the National Long Term Care Demonstration. 4. Case management under channeling. Health Services Research. Apr. 1988;23(1):67-81. Exclusion reason: No original data. [pmid: 3130331].
728 Phillips GA, Brophy DS, Weiland TJ, et al. The effect of multidisciplinary case management on selected outcomes for frequent attenders at an emergency department. Medical Journal of Australia. Jun. 19. 2006;184(12):602-6. Exclusion reason: Wrong population. [pmid: 16803437].
729 Phillips VL. The role of case managers in a United Kingdom experiment with self-directed care. Journal of Case Management. 1996;5(4):142-5. Exclusion reason: Wrong intervention. [pmid: 9110696].
730 Phillips-Harris C. The integration of primary care and case management in chronic disease. Quality Management in Health Care. Fall. 1996;5(1):1-6. Exclusion reason: No original data. [pmid: 10163104].
731 Phillips-Harris C. Case management: high-intensity care for frail patients with complex needs. Geriatrics. Feb. 1998;53(2):62-4. 7. 8. Exclusion reason: Background. [pmid: 9484286].
732 Pierini D. Case managing the elderly: best bet for the future. Health Progress. Dec. 1988;69(11):42-5. Exclusion reason: Background. [pmid: 10290833].
733 Pigg JS. Case management of the patient with arthritis… implementing case management across the continuum: the transition of the orthopaedic patient. proceedings of selected papers from the NAON 1996 Fall Case Management Conference. New Orleans, LA. November 14-16, 1996. Orthopaedic Nursing. Mar-Apr. 1997;16(2 Suppl):33-40. [pmid: 9155429]. Exclusion reason: No original data.
734 Pillai NV, Kupprat SA, Halkitis PN. Impact of service delivery model on health care access among HIV-positive women in New York City. AIDS Patient Care & Stds. Jan. 2009;23(1):51-8. Exclusion reason: Wrong intervention. [pmid: 19046120].
735 Pimouguet C, Lavaud T, Dartigues JF, et al. Dementia case management effectiveness on health care costs and resource utilization: a systematic review of randomized controlled trials. Journal of Nutrition, Health & Aging. Oct. 2010;14(8):669-76. Exclusion reason: No original data. [pmid: 20922344].
736 Pinquart M, Sorensen S. Helping caregivers of persons with dementia: which interventions work and how large are their effects?. International Psychogeriatrics. Dec. 2006;18(4):577-95. Exclusion reason: Wrong intervention. [pmid: 16686964].
737 Pins CL, Swanson ME. A suburban community emergency department's adaptation of case management. JEN: Journal of Emergency Nursing. Dec. 1993;19(6):503-9. Exclusion reason: Wrong intervention. [pmid: 8309142].
738 Piotrowski MM, Saint S, Hinshaw DB. The safety case management committee: expanding the avenues for addressing patient safety. Joint Commission Journal on Quality Improvement. Jun. 2002;28(6):296-305. Exclusion reason: Wrong setting. [pmid: 12066621].
739 Piturro M. The CMS disease management project: disease management programs tailored to long-term care enjoy the spotlight. Caring for the Ages. 2005;6(2):20. Exclusion reason: No original data.
740 Ploeg J, Biehler L, Willison K, et al. Perceived support needs of family caregivers and implications for a telephone support service. Canadian Journal of Nursing Research. Sep. 2001;33(2):43-61. Exclusion reason: Wrong outcome. [pmid: 11928335].
741 Pointer K. CRITICAL PATH NETWORK. CM redesign: how one organization tackled the process: outcomes measures indicate solid success. Hospital Case Management. Aug. 2004;12(8):119-22. Exclusion reason: Wrong setting. [pmid: 15274509].
742 Polinsky ML, Fred C, Ganz PA. Quantitative and qualitative assessment of a case management program for cancer patients. Health & Social Work. Aug. 1991;16(3):176-83. Exclusion reason: No original data. [pmid: 1654296].
743 Pooler A, Campbell P. NT research. Identifying the development needs of community matrons. Nursing Times. Sep. 12-18. 2006;102(37):36-8. Exclusion reason: Wrong outcome. [pmid: 17004698].
744 Pope D, Fernandes CM, Bouthillette F, et al. Frequent users of the emergency department: a program to improve care and reduce visits. CMAJ Canadian Medical Association Journal. Apr. 4. 2000;162(7):1017-20. Exclusion reason: Wrong population. [pmid: 10763402].
745 Poses RM, Avitall B. Nurse telemanagement improved outcomes and reduced cost of care more than home nurse visits in chronic heart failure. ACP Journal Club. Sep-Oct. 2003;139(2):35. Exclusion reason: No original data. [pmid: 12954027].
746 Potera C. Lowering hospital readmissions and costs. American Journal of Nursing. 2009;109(5):19. Exclusion reason: Wrong intervention.
747 Powell SK. Advanced case management: outcomes and beyond. 2000:337. Exclusion reason: No original data.
748 Powell SK. Public reporting of healthcare data: new arenas. Lippincott's Case Management. Mar-Apr. 2004;9(2):55-6. Exclusion reason: No original data. [pmid: 15192498].
749 Pratt LR. Long-term conditions 5: meeting the needs of highly complex patients. British Journal of Community Nursing. Jun. 11. 2006;11(6):234-5. Exclusion reason: Wrong intervention. [pmid: 16835517].
750 Pressman HT. Traumatic brain injury rehabilitation: case management and insurance-related issues. Physical Medicine & Rehabilitation Clinics of North America. Feb. 2007;18(1):165-74. Exclusion reason: No original data. [pmid: 17292818].
751 Pugh J, Lawrence V. A nurse-facilitator intervention improved the use of ÃŸ-blockers in outpatients with stable congestive heart failure. ACP Journal Club. Jan-Feb. 2004;140(1):22. Exclusion reason: No original data. [pmid: 14711293].
752 Rabiner DJ, Mutran E, Stearns SC. The effect of channeling on home care utilization and satisfaction with care. Gerontologist. Apr. 1995;35(2):186-95. Exclusion reason: Wrong intervention. [pmid: 7750775].
753 Radzwill MA. Integration of case and disease management: why and how?. Disease Management & Health Outcomes. 2002;10(5):277-89. Exclusion reason: No original data.
754 Rahkonen T, Eloniemi-Sulkava U, Paanila S, et al. Systematic intervention for supporting community care of elderly people after a delirium episode. International Psychogeriatrics. Mar. 2001;13(1):37-49. Exclusion reason: Wrong population. [pmid: 11352333].
755 Ramey M, Daniels S. Case managers in the hospital workplace -- a light-hearted view at century's end. Case Manager. Jan-Feb. 2000;11(1):55-8. Exclusion reason: Wrong setting. [pmid: 11935571].
756 Randall GE. Competition, organizational change, and conflict: the changing role of case managers in Ontario's Homecare System. Care Management Journals. 2007;8(1):2-7. Exclusion reason: No original data. [pmid: 17491444].
757 Rastkar R, Zweig S, Delzell JE Jr., et al. Nurse care coordination of ambulatory frail elderly in an academic setting. Case Manager. Jan-Feb. 2002;13(1):59-61. Exclusion reason: No original data. [pmid: 11818910].
758 Ray J. Rehabilitation facility-based case management in evolution: responding to managed care. Topics in Spinal Cord Injury Rehabilitation. Spring. 1998;3(4):36-43. Exclusion reason: No original data.
759 Reed R. An abbreviated model of geriatric assessment and care management: does it work?. Journal of the American Board of Family Practice. Nov-Dec. 1997;10(6):441-3. Exclusion reason: No original data. [pmid: 9407487].
760 Reif S, Smith SR, Golin CE. Medication adherence practices of HIV/AIDS case managers: a statewide survey in North Carolina. AIDS Patient Care & Stds. Sep. 2003;17(9):471-81. Exclusion reason: Wrong intervention. [pmid: 14588085].
761 Reilly S, Miranda-Castillo C, Sandhu S, et al. Case/care management approaches to home support for people with dementia. Cochrane Database of Systematic Reviews. 2010;(2). Exclusion reason: No original data.
762 Renaud KL. Case management and nursing care for families… “Case management of patients with chronic critical illnesses” (December 1996). Critical Care Nurse. Jun. 1997;17(3):16-7. Exclusion reason: Wrong setting. [pmid: 9313407].
763 Renders CM, Valk GD, Griffin SJ, et al. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention.
764 Rentsch HP, Bucher P, Dommen Nyffeler I, et al. Rehabilitation in practice The implementation of the ‘International Classification of Functioning, Disability and Health’ (ICF) in daily practice of neurorehabilitation: an interdisciplinary project at the Kantonsspital of Lucerne, Switzerland. Disability & Rehabilitation. Apr. 22. 2003;25(8):411-21. Exclusion reason: Wrong setting. [pmid: 12745951].
765 Reuben DB. Organizational interventions to improve health outcomes of older persons. Medical Care. May. 2002;40(5):416-28. Exclusion reason: No original data. [pmid: 11961476].
766 Rheaume A, Frisch S, Smith A, et al. Case management and nursing practice… nurse-client and nurse-colleague relationships within community settings. Journal of Nursing Administration. Mar. 1994;24(3):30-6. Exclusion reason: Wrong outcome. [pmid: 8133322].
767 Rich JD, Holmes L, Salas C, et al. Successful linkage of medical care and community services for HIV-positive offenders being released from prison. Journal of Urban Health. Jun. 2001;78(2):279-89. Exclusion reason: No original data. [pmid: 11419581].
768 Richards F III, Pitluk H, Collier P, et al. Reducing unnecessary Medicare hospital admissions for chest pain in Arizona and Florida. Professional Case Management. Mar-Apr. 2008;13(2):74-86. Exclusion reason: Wrong setting. [pmid: 18344829].
769 Richards S, Coast J. Interventions to improve access to health and social care after discharge from hospital: a systematic review. Journal of Health Services & Research Policy. Jul. 2003;8(3):171-9. Exclusion reason: Wrong population. [pmid: 12869344].
770 Riegel B, Carlson B, Glaser D, et al. Standardized telephonic case management in a Hispanic heart failure population: an effective intervention. Disease Management & Health Outcomes. 2002;10(4):241. Exclusion reason: Wrong intervention.
771 Rieve JA. Guidelines & outcomes. Quality management tools, part I. Case Manager. 1997;8(6):38-41. Exclusion reason: No original data.
772 Rieve JA. Health promotion and case management outcomes. Case Manager. Jan-Feb. 1999;10(1):20-1. Exclusion reason: No original data. [pmid: 11000745].
773 Rieve JA. Guidelines & outcomes. Acute care innovations and outcomes in the military medical system. Case Manager. Jul-Aug. 2000;11(4):32-3. Exclusion reason: No original data. [pmid: 11935609].
774 Rieve JA. Guidelines & outcomes. Proving the value of case management. Case Manager. Mar-Apr. 2000;11(2):42. Exclusion reason: No original data. [pmid: 11935522].
775 Rieve JA. Guidelines & outcomes. Best practices in case management. Case Manager. Jan-Feb. 2001;12(1):36-7. Exclusion reason: No original data. [pmid: 11174221].
776 Rieve JA. Guidelines & outcomes. Community case management outcomes. Case Manager. Jul-Aug. 2001;12(4):40-1. Exclusion reason: No original data. [pmid: 11464171].
777 Rieve JA. Outcomes. Accountability and hospital rankings. Case Manager. Mar-Apr. 2003;14(2):29. Exclusion reason: No original data. [pmid: 12649686].
778 Ritchie CA, Thomas DR. Home-based primary care in the VA setting, with a focus on Birmingham, Alabama. Journal of Long Term Home Health Care. 1998;17(4):18-25. Exclusion reason: Wrong intervention. [pmid: 10187110].
779 Rittenhouse DR, Robinson JC. Improving quality in Medicaid: the use of care management processes for chronic illness and preventive care. Medical Care. Jan. 2006;44(1):47-54. Exclusion reason: No original data. [pmid: 16365612].
780 Robbins B, Rye R, German PS, et al. The Psychogeriatric Assessment and Treatment in City Housing (PATCH) program for elders with mental illness in public housing: getting through the crack in the door. Archives of Psychiatric Nursing. Aug. 2000;14(4):163-72. Exclusion reason: Wrong population. [pmid: 10969636].
781 Roberts RM, Dalton KL, Evans JV, et al. A service model of short-term case management for elderly people at risk of hospital admission. Australian Health Review. May. 2007;31(2):173-83. Exclusion reason: Background. [pmid: 17470037].
782 Rogala-Scherer K, Durusky M. Case management of the newly diagnosed leukemia patient. Oncology Nursing Society 32nd Annual Congress. April 24-27, 2007. Las Vegas, NV. Oncology Nursing Forum. Mar. 2007;34(2):554. Exclusion reason: No original data.
783 Roggenkamp SD, White KR, Bazzoli GJ. Adoption of hospital case management: economic and institutional influences. Social Science & Medicine. Jun. 2005;60(11):2489-500. Exclusion reason: Wrong setting. [pmid: 15814174].
784 Rohrbach JI. Critical pathways as an essential part of a disease management program. Journal of Nursing Care Quality. Oct. 1999;14(1):11-5. Exclusion reason: No original data. [pmid: 10575827].
785 Roland M, Dusheiko M, Gravelle H, et al. Follow up of people aged 65 and over with a history of emergency admissions: analysis of routine admission data. BMJ: British Medical Journal. 2005;330(7486):289-92. Exclusion reason: Wrong intervention. [pmid: 15695276].
786 Roman JS, Griswold KS, Smith SJ, et al. How patients view primary care: differences by minority status after psychiatric emergency. Journal of Cultural Diversity. 2008;15(2):56-60. Exclusion reason: Wrong population. [pmid: 18649441].
787 Romania M. The benefits of an emergency department case management program. Pennsylvania Nurse. Sep. 2006;61(3):15. Exclusion reason: No original data. [pmid: 17066837].
788 Romero A, Brown C, Richards F III, et al. Reducing unnecessary Medicare admissions: a six-state project. Professional Case Management. May-Jun. 2009;14(3):143-50. Exclusion reason: Wrong setting. [pmid: 19474641].
789 Rooney EM, Studenski SA, Roman LL. A model for nurse case-managed home care using televideo. Journal of the American Geriatrics Society. Dec. 1997;45(12):1523-8. Exclusion reason: No original data. [pmid: 9400566].
790 Rosemann T, Joos S, Laux G, et al. Case management of arthritis patients in primary care: a cluster-randomized controlled trial. Arthritis & Rheumatism. Dec. 15. 2007;57(8):1390-7. Exclusion reason: Wrong population. [pmid: 18050178].
791 Ross NE. A hospital and community in partnership: “case management coordinated care model in a community setting”. Leadership in Health Services. Nov-Dec. 1993;2(6):27-30. Exclusion reason: No original data. [pmid: 10130775].
792 Roth AM, Ackermann RT, Downs SM, et al. The structure and content of telephonic scripts found useful in a Medicaid Chronic Disease Management Program. Chronic Illness. Jun. 2010;6(2):83-8. Exclusion reason: Wrong outcome. [pmid: 20484324].
793 Rubado DJ, Choi D, Becker T, et al. Determining the cost of tuberculosis case management in a low-incidence state. International Journal of Tuberculosis & Lung Disease. Mar. 2008;12(3):301-7. Exclusion reason: Wrong intervention. [pmid: 18284836].
794 799. Rubenfeld GD. Interventions to improve long-term outcomes after critical illness. Current Opinion in Critical Care. Oct. 2007;13(5):476-81. Exclusion reason: No original data. [pmid: 17762222].
795 Rudy EB, Daly BJ, Douglas S, et al. Patient outcomes for the chronically critically ill: special care unit versus intensive care unit. Nursing Research. Nov-Dec. 1995;44(6):324-31. Exclusion reason: Wrong intervention. [pmid: 7501485].
796 Rundall TG, Shortell SM, Wang MC, et al. As good as it gets? Chronic care management in nine leading US physician organisations. BMJ: British Medical Journal. Oct. 26. 2002;325(7370):958-61. Exclusion reason: Wrong intervention. [pmid: 12399351].
797 Russell D, VorderBruegge M, Burns SM. Effect of an outcomes-managed approach to care of neuroscience patients by acute care nurse practitioners. American Journal of Critical Care. Jul. 2002;11(4):353-62. Exclusion reason: Wrong setting. [pmid: 12102436].
798 Sagan M, Hadjistavropoulos H, Bierlein C, et al. Development and results of a Case Coordination Activity Tracking tool. Care Management Journals. 2004;5(4):203-12. Exclusion reason: Wrong outcome. [pmid: 16294573].
799 Salazar MK. Maximizing the effectiveness of case management service delivery. Case Manager. May-Jun. 2000;11(3):58-63. Exclusion reason: No original data. [pmid: 11935642].
800 Sample C, Ungar C. When the case manager becomes the patient… third in a three-part series on PPH. Inside Case Management. Nov. 1998;5(8):10-2. Exclusion reason: Wrong outcome.
801 Sandberg J, Trief PM, Izquierdo R, et al. A qualitative study of the experiences and satisfaction of direct telemedicine providers in diabetes case management. Telemedicine Journal & E-Health. Oct. 2009;15(8):742-50. Exclusion reason: Wrong outcome. [pmid: 19780691].
802 Sandy LP. Case management in the emergency room. Professional Case Management. Mar-Apr. 2010;15(2):111-3. Exclusion reason: No original data. [pmid: 20234297].
803 Santana MJ, Feeny D, Johnson JA, et al. Assessing the use of health-related quality of life measures in the routine clinical care of lung-transplant patients. Quality of life research : an international journal of quality of life aspects of treatment, care and rehabilitation. Apr. 2010;19(3):371-9. Exclusion reason: Wrong intervention. [pmid: 20146009].
804 Sargent P, Boaden R. NT clinical. Implementing the role of the community matron. Nursing Times. Mar 28-Apr 3. 2006;102(13):23-4. Exclusion reason: No original data. [pmid: 16605144].
805 Sargent P, Boaden R, Roland M. How many patients can community matrons successfully case manage?. Journal of Nursing Management. Jan. 2008;16(1):38-46. Exclusion reason: Wrong outcome. [pmid: 18211334].
806 Sargent P, Pickard S, Sheaff R, et al. Patient and carer perceptions of case management for long-term conditions. Health & Social Care in the Community. Nov. 2007;15(6):511-19. Exclusion reason: Wrong outcome. [pmid: 17956403].
807 Savarese M, Weber CM. Case management for persons who are homeless. Journal of Case Management. 1993;2(1):3-8. Exclusion reason: Wrong population. [pmid: 8490555].
808 Schönberger M, Humle F, Teasdale TW. The development of the therapeutic working alliance, patients' awareness and their compliance during the process of brain injury rehabilitation. Brain Injury. 2006;20(4):445-54. Exclusion reason: Wrong intervention. [pmid: 16716990].
809 Schaedle R, McGrew JH, Bond GR, et al. A comparison of experts' perspectives on assertive community treatment and intensive case management. Psychiatric Services. Feb. 2002;53(2):207-10. Exclusion reason: Wrong population. [pmid: 11821553].
810 Schaefer J, Davis C. Case management and the chronic care model: a multidisciplinary role. Lippincott's Case Management. Mar-Apr. 2004;9(2):96-103. Exclusion reason: No original data. [pmid: 15192504].
811 Schaffer C, Behrendt D. Disease state management across the continuum: bettering lives, providing value. Remington Report. Jul-Aug. 1997;5(4):20-3. Exclusion reason: No original data.
812 Schedlbauer A, Davies P, Fahey T. Interventions to improve adherence to lipid lowering medication. Cochrane Database of Systematic Reviews. 2011;(1). Exclusion reason: Wrong intervention.
813 Schiller AE Jr., Bondmass M, Avitall B. Technology-based home care for disease management. Remington Report. Sep-Oct. 1997;5(5):8. Exclusion reason: Wrong intervention.
814 Schillinger D, Hammer H, Wang F, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Education & Behavior. Oct. 2008;35(5):664-82. Exclusion reason: Wrong intervention. [pmid: 17513690].
815 Schmader KE, Hanlon JT, Pieper CF, et al. Effects of geriatric evaluation and management on adverse drug reactions and suboptimal prescribing in the frail elderly. American Journal of Medicine. Mar. 15. 2004;116(6):394-401. Exclusion reason: Wrong intervention. [pmid: 15006588].
816 Schmidt LT, Gill KJ, Pratt CW, et al. Comparison of service outcomes of case management teams with and without a consumer provider. American Journal of Psychiatric Rehabilitation. 2008;11(4):310-29. Exclusion reason: Wrong population.
817 Schmidt SM, Guo L, Scheer S, et al. Epidemiologic determination of community-based nursing case management for stroke. Journal of Nursing Administration. Jun. 1999;29(6):40-7. Exclusion reason: Wrong intervention. [pmid: 10377924].
818 Schmitt NL. Role transitions for nurses: From care giver to case manager [Ph.D.]. Michigan State University. 2003. Exclusion reason: Wrong outcome.
819 Schoen C, Osborn R, How SKH, et al. In chronic condition: experiences of patients with complex health care needs, in eight countries, 2008. Health Affairs. Jan-Feb. 2009;(1):w1-16. Exclusion reason: Wrong intervention. [pmid: 19008253].
820 Schoenfelder DP, Maas ML, Specht JK. HomeSafe: Supportive assistance for elderly individuals through a nurse-managed plan. Journal of Gerontological Nursing. Apr. 2005;31(4):5-11. Exclusion reason: No original data. [pmid: 15839519].
821 Schofield I, Ford P. The need for specialist nurses to work with older people. British Journal of Nursing. Nov. 9-22. 2000;9(20):2148-54. Exclusion reason: No original data. [pmid: 12271183].
822 Schore J, Peikes D, Peterson G, et al. Fourth Report to Congress on the Evaluation of the Medicare Coordinated Care Demonstration. 2011. Exclusion reason: Background.
823 Schraeder C, Dworak D, Stoll JF, et al. Managing elders with comorbidities. Journal of Ambulatory Care Management. Jul-Sep. 2005;28(3):201-9. Exclusion reason: Wrong outcome. [pmid: 15968212].
824 Schraeder C, Fraser C, Clark I, et al. The effect of primary care management on lipids testing and LDL-C control of elderly patients with comorbidities. Professional Case Management. 2009;14(2):84-95. Exclusion reason: Wrong outcome. [pmid: 19318900].
825 Schraeder C, Shelton P, Britt T, et al. Case management in a capitated system: the community nursing organization. Journal of Case Management. 1996;5(2):58-64. Exclusion reason: Wrong population. [pmid: 8900778].
826 Schulman AJ. Service coordination: program development and initial findings. Journal of Long Term Home Health Care. 1996;15(2):5-12. Exclusion reason: Wrong population. [pmid: 10172676].
827 Schultz IZ, Crook J, Berkowitz J, et al. A prospective study of the effectiveness of early intervention with high-risk back-injured workers--a pilot study. Journal of Occupational Rehabilitation. Jun. 2008;18(2):140-51. Exclusion reason: Wrong outcome. [pmid: 18404361].
828 Schumann A, Nyamathi A, Stein JA. HIV risk reduction in a nurse case-managed TB and HIV intervention among homeless adults. Journal of Health Psychology. Sep. 2007;12(5):833-43. Exclusion reason: Wrong population. [pmid: 17855466].
829 Schur D, Whitlatch CJ. Circumstances leading to placement: a difficult caregiving decision. Lippincott's Case Management. Sep-Oct. 2003;8(5):187-95. quiz 96-7. Exclusion reason: Wrong intervention. [pmid: 14517497].
830 Schwartz B, Dilley J, Sorensen JL. Case management of substance abusers with HIV disease. Journal of Case Management. 1994;3(4):173-8. Exclusion reason: No original data. [pmid: 7735090].
831 Scott J, Rantz M. Managing chronically ill older people in the midst of the health care revolution. Nursing Administration Quarterly. 1997;21(2):55-64. Exclusion reason: No original data. [pmid: 9069953].
832 Scott K. Case management: a quality process. Topics in Health Information Management. 1996;16(3):58-64. Exclusion reason: Wrong setting. [pmid: 10156202].
833 Seddon D, Robinson CA. Carers of older people with dementia: assessment and the Carers Act. Health & Social Care in the Community. May. 2001;9(3):151-8. Exclusion reason: Wrong outcome. [pmid: 11560731].
834 Segal L, Dunt D, Day SE. Introducing coordinated care (2): evaluation of design features and implementation processes implications for a preferred health system reform model. Health Policy. 2004;69(2):215-28. Exclusion reason: Wrong outcome. [pmid: 15212868].
835 Segal L, Dunt D, Day SE, et al. Introducing coordinated care (1): a randomised trial assessing client and cost outcomes. Health policy (Amsterdam, Netherlands). Aug. 2004;69(2):201-13. Exclusion reason: Wrong intervention. [pmid: 15212867].
836 Seltzer MM, Litchfield LC, Kapust LR, et al. Professional and family collaboration in case management: a hospital-based replication of a community-based study. Social Work in Health Care. 1992;17(1):1-22. Exclusion reason: Wrong intervention. [pmid: 1440105].
837 Seow H, Piet L, Kenworthy CM, et al. Evaluating a palliative care case management program for cancer patients: the Omega Life Program. Journal of Palliative Medicine. Dec. 2008;11(10):1314-8. Exclusion reason: Wrong population. [pmid: 19115890].
838 Sesperez J, Wilson S, Jalaludin B, et al. Trauma case management and clinical pathways: prospective evaluation of their effect on selected patient outcomes in five key trauma conditions. Journal of Trauma-Injury Infection & Critical Care. Apr. 2001;50(4):643-9. Exclusion reason: Wrong setting. [pmid: 11303158].
839 Setter SM, Corbett CF, Neumiller JJ, et al. Effectiveness of a pharmacist-nurse intervention on resolving medication discrepancies for patients transitioning from hospital to home health care. American Journal of Health-System Pharmacy. Nov. 15. 2009;66(22):2027-31. Exclusion reason: Wrong intervention. [pmid: 19890086].
840 Shah MR, Flavell CM, Weintraub JR, et al. Intensity and focus of heart failure disease management after hospital discharge. American Heart Journal. Apr. 2005;149(4):715-21. Exclusion reason: Wrong intervention. [pmid: 15990758].
841 Shahady EJ. Diabetes management: an approach that improves outcomes and reduces costs. Consultant. (00107069). 2008;48(4):331. Exclusion reason: Wrong intervention.
842 Shea SC. The “medication interest model”: An integrative clinical interviewing approach for improving medication adherence--part 1: clinical applications. Professional Case Management. 2008;13(6):305-7. Exclusion reason: Wrong intervention. [pmid: 19008755].
843 Shea SC. The “medication interest model”: an integrative clinical interviewing approach for improving medication adherence -- part 2: implications for teaching and research. Professional Case Management. Jan-Feb. 2009;14(1):6-15. Exclusion reason: Wrong intervention. [pmid: 19092595].
844 Sheaff R, Boaden R, Sargent P, et al. Impacts of case management for frail elderly people: a qualitative study. Journal of Health Services & Research Policy. Apr. 2009;14(2):88-95. Exclusion reason: Wrong outcome. [pmid: 19299262].
845 Shearer NBC, Cisar N, Greenberg EA. A telephone-delivered empowerment intervention with patients diagnosed with heart failure. Heart & Lung. 2007;36(3):159-69. Exclusion reason: Wrong intervention. [pmid: 17509423].
846 Shearer S, Simmons WJ, White M, et al. Physician Partnership Project: social work case managers in primary care. Continuum. Jul-Aug. 3. 1995;15(4):1-7. Exclusion reason: No original data. [pmid: 10145058].
847 Shelby-James TM, Currow DC, Phillips PA, et al. Promoting patient centred palliative care through case conferencing. Australian Family Physician. Nov. 2007;36(11):961-4. Exclusion reason: Wrong intervention. [pmid: 18043787].
848 Shelley S, Vollmar B. What is the formula that adds up to heart failure success?. Professional Case Management. Nov. 2010;15(6):325-9. Exclusion reason: Wrong intervention. [pmid: 21057298].
849 Shepperd S, Doll H, Angus RM, et al. Hospital at home admission avoidance. Cochrane Database of Systematic Reviews. 2011;(7). Exclusion reason: Wrong intervention.
850 Sherer R, Stieglitz K, Narra J, et al. HIV multidisciplinary teams work: support services improve access to and retention in HIV primary care. AIDS Care. Aug. Suppl 1. 2002;14:S31-44. Exclusion reason: Wrong intervention. [pmid: 12204140].
851 Sherman JJ, Johnson PK. Nursing care management. Quality Assurance & Utilization Review. 1991;6(4):142-5. Exclusion reason: Wrong setting. [pmid: 1824460].
852 Sherman JJ, Johnson PK. CNS as unit-based case manager. Clinical Nurse Specialist: The Journal for Advanced Nursing Practice. 1994;8(2):76-80. Exclusion reason: Wrong setting. [pmid: 7882248].
853 Shiell A, Kenny P, Farnworth MG. The role of the clinical nurse co-coordinator in the provision of cost-effective orthopaedic services for elderly people. Journal of Advanced Nursing. Sep. 1993;18(9):1424-8. Exclusion reason: Wrong setting. [pmid: 8258601].
854 Shin SM, Kim MJ, Kim ES, et al. Medical Aid service overuse assessed by case managers in Korea. Journal of Advanced Nursing. Oct. 2010;66(10):2257-65. Exclusion reason: Wrong outcome. [pmid: 20626489].
855 Shojania KG, Jennings A, Mayhew A, et al. The effects of on-screen, point of care computer reminders on processes and outcomes of care. Cochrane Database of Systematic Reviews. 2011;(1). Exclusion reason: Wrong intervention.
856 Shueman S. A model of case management for mental health services. Q Rev Bull. 1987;13:314-7. Exclusion reason: Wrong population. [pmid: 3120082].
857 Shumway M, Boccellari A, O'Brien K, et al. Cost-effectiveness of clinical case management for ED frequent users: results of a randomized trial. American Journal of Emergency Medicine. Feb. 2008;26(2):155-64. Exclusion reason: Wrong population. [pmid: 18272094].
858 Siebens H. Applying the domain management model in treating patients with chronic diseases. Joint Commission Journal on Quality Improvement. Jun. 2001;27(6):302-14. Exclusion reason: Wrong intervention. [pmid: 11402777].
859 Sikka R, Waters J, Moore W, et al. Renal assessment practices and the effect of nurse case management of health maintenance organization patients with diabetes. Diabetes Care. Jan. 1999;22(1):1-6. Exclusion reason: Wrong intervention. [pmid: 10333895].
860 Sindhu S, Pholpet C, Puttapitukpol S. Meeting the challenges of chronic illness: a nurse-led collaborative community care program in Thailand. Collegian: Journal of the Royal College of Nursing, Australia. 2010;17(2):93-9. Exclusion reason: Wrong setting. [pmid: 20738062].
861 Singh D. Transforming chronic care: evidence about improving care for people with long term conditions. 2005. Exclusion reason: No original data.
862 Sinha SK, Bessman ES, Flomenbaum N, et al. A systematic review and qualitative analysis to inform the development of a new emergency department-based geriatric case management model. Annals of Emergency Medicine. Jun. 2011;57(6):672-82. Exclusion reason: Wrong intervention. [pmid: 21621093].
863 Sivaram CA, Attebery S, Boyd AL, et al. Introducing case management to a general medicine ward team of a teaching hospital. Academic Medicine. Jun. 1997;72(6):555-7. Exclusion reason: Wrong intervention. [pmid: 9200593].
864 Skelly AH. Culturally tailored intervention for African Americans with type 2 diabetes administered by a nurse case manager and community health worker reduces emergency room visits. Evidence-Based Nursing. Apr. 2010;13(2):51-2. Exclusion reason: No original data. [pmid: 20436151].
865 Skinner J, Carter L, Haxton C. Case management of patients who frequently present to a Scottish emergency department. Emergency Medicine Journal. Feb. 2009;26(2):103-5. Exclusion reason: Wrong population. [pmid: 19164618].
866 Skultety KM, Rodriguez RL. Treating geriatric depression in primary care. Current Psychiatry Reports. Feb. 2008;10(1):44-50. Exclusion reason: Wrong intervention. [pmid: 18269894].
867 Slade MD. Critical Path Network. Inpatient chemotherapy path reduces LOS to three days. Hospital Case Management. Dec. 1996;4(12):183-6. Exclusion reason: Wrong intervention. [pmid: 10162976].
868 Smith D. Improving outcomes through supportive care for cancer patients. Care Management. 2003;9(1):16-28. Exclusion reason: No original data.
869 Smith DH, Johnson ES, Thorp ML, et al. Integrating clinical trial findings into practice through risk stratification: the case of heart failure management. Population Health Management. 2010;13(3):123-9. Exclusion reason: Wrong intervention. [pmid: 20455788].
870 Smith Fawzi MC, Jagannathan P, Cabral J, et al. Limitations in knowledge of HIV transmission among HIV-positive patients accessing case management services in a resource-poor setting. AIDS Care. Oct. 2006;18(7):764-71. Exclusion reason: Wrong outcome. [pmid: 16971286].
871 Smith G, Clarke D. Assessing the effectiveness of integrated interventions: terminology and approach. Medical Clinics of North America. Jul. 2006;90(4):533-48. Exclusion reason: No original data. [pmid: 16843761].
872 Smith MC, Watson J. Case management in the caring-healing paradigm. Applying the art and science of human caring. 1994;(42-2647):47-52. Exclusion reason: No original data. [pmid: 7971228].
873 Smith P, Pass CM, Pounovich-Stream C, et al. Implementing nurse case management in a community hospital. MEDSURG Nursing. Sep. 1992;1(1):47-52. Exclusion reason: Wrong intervention. [pmid: 1306766].
874 Smith SM, Allwright S, O'Dowd T. Effectiveness of shared care across the interface between primary and specialty care in chronic disease management. Cochrane Database of Systematic Reviews. 2010;(2). Exclusion reason: Wrong intervention.
875 Smith SM, Soubhi H, Fortin M, et al. Interventions to improve outcomes in patients with multimorbidity in primary care and community settings. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: No original data.
876 Solomon P, Draine J. The efficacy of a consumer case management team: two year outcomes of a randomized trial. Journal of Mental Health Administration. Spring. 1995;22(2):135-46. Exclusion reason: Wrong population. [pmid: 10142127].
877 Somerfield J, Barber PA, Anderson NE, et al. Changing attitudes to the management of ischaemic stroke between 1997 and 2004: a survey of New Zealand physicians. Internal Medicine Journal. May. 2006;36(5):276-80. Exclusion reason: Wrong intervention. [pmid: 16650191].
878 Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. Journal of Cardiopulmonary Rehabilitation. Sep-Oct. 2003;23(5):341-8. Exclusion reason: Wrong intervention. [pmid: 14512778].
879 Sowell RL. The effect of case management on cost of care for persons with AIDS. 1990:170. Exclusion reason: Wrong intervention.
880 Sowell RL. Clinical issues. Reconstruction case management. JANAC: Journal of the Association of Nurses in AIDS Care. Nov-Dec. 1997;8(6):43-5. Exclusion reason: No original data.
881 Sowell RL, Phillips KD, Seals BF, et al. Social service and case management needs of HIV-infected persons upon release from prison/jail. Lippincott's Case Management. Jul-Aug. 2001;6(4):157-68. Exclusion reason: No original data. [pmid: 16398065].
882 Spath P. Guest column. Evaluate the contribution of social services: use survey tool for CM improvement. Hospital Case Management. Dec. 2000;8(12):182. Exclusion reason: No original data. [pmid: 11125921].
883 Spath P. Guest column. How to measure the value of case management: process, financial, satisfaction measures crucial. Hospital Case Management. Feb. 2000;8(2):29-32. Exclusion reason: No original data. [pmid: 10787574].
884 Sperry S. Opportunities and challenges: strategies for implementing multidisciplinary documentation forms. Aspen's Advisor for Nurse Executives. Jun. 3. 1994;9(9):1-4. suppl 1-2. Exclusion reason: No original data. [pmid: 8003376].
885 Sperry S, Birdsall C. Outcomes of a pneumonia critical path. Nursing Economic$. 1994;12(6):332. Exclusion reason: Wrong intervention. [pmid: 7885490].
886 Spettell CM, Rawlins WS, Krakauer R, et al. A comprehensive case management program to improve palliative care. Journal of Palliative Medicine. Sep. 2009;12(9):827-32. Exclusion reason: Wrong population. [pmid: 19719372].
887 Spillane LL, Lumb EW, Cobaugh DJ, et al. Frequent users of the emergency department: can we intervene?. Academic Emergency Medicine. Jun. 1997;4(6):574-80. Exclusion reason: Wrong intervention. [pmid: 9189190].
888 Spooner SH, Yockey PS. Complementary nursing--an acute care case management model. Part II--Evaluation. Nursing Case Management. Nov-Dec. 1997;2(6):257-66. Exclusion reason: Wrong setting. [pmid: 9481314].
889 Squires RW. Cardiology abstract reviews. [Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical events in men and women with coronary artery disease: the Stanford Coronary Risk Intervention Project (SCRIP). Haskell WL, Alderman EL, Fair JM, Maron DJ, Mackey SF, Superko HR, Williams PT, Johnstone IM, Champagne MA, Kraus RM, Farquhar JW. Circulation 1994;89:975-990]. Journal of Cardiopulmonary Rehabilitation. Jan-Feb. 1995;15(1):74-5. Exclusion reason: Wrong intervention.
890 Stahler GJ, Shipley TF Jr., Bartelt D, et al. Evaluating alternative treatments for homeless substance-abusing men: outcomes and predictors of success. Journal of Addictive Diseases. 1995;14(4):151-67. Exclusion reason: Wrong population. [pmid: 8929938].
891 Stanhope V, Matejkowski J. Understanding the role of individual consumer-provider relationships within assertive community treatment. Community Mental Health Journal. Aug. 2010;46(4):309-18. Exclusion reason: Wrong population. [pmid: 19568933].
892 Stanton MP, Walizer EM, Graham JI, et al. Case management: a case study. Nursing Case Management. Jan-Feb. 2000;5(1):37-45. Exclusion reason: No original data. [pmid: 10855157].
893 Steele DJR, Hamilton E, Arnaout MA. A case management model to improve hemodialysis outpatient outcomes. Hemodialysis International. Apr. 2007;11(2):247-51. Exclusion reason: Wrong setting. [pmid: 17403178].
894 Steeman E, Moons P, Milisen K, et al. Implementation of discharge management for geriatric patients at risk of readmission or institutionalization. International Journal for Quality in Health Care. Oct. 2006;18(5):352-8. Exclusion reason: Wrong intervention. [pmid: 16861721].
895 Stein CH, Craft SA. Case managers' experiences of personal growth: learning from consumers. Community Mental Health Journal. Apr. 2007;43(2):183-95. Exclusion reason: Wrong population. [pmid: 17021952].
896 Steiner BD, Denham AC, Ashkin E, et al. Community Care of North Carolina: improving care through community health networks [corrected]. [published erratum appears in ANN INTERN MED 2008 Sep-Oct;6(5):468]. Annals of Family Medicine. Jul-Aug. 2008;6(4):361-7. Exclusion reason: No original data. [pmid: 18626037].
897 Stempel J, Carlson A, Michaels C, et al. Working in partnership. Nurse case management in the 21st century. 1996:124-32. Exclusion reason: No original data.
898 Stessman J, Hammerman-Rozenberg R, Cohen A. Home hospitalization in the spectrum of community geriatric care… selected proceedings from the 1st International Conference on Home Care: Developments and Innovations, Jerusalem, May 1996. Disability & Rehabilitation. Apr. 1997;19(4):134-41. Exclusion reason: Wrong intervention. [pmid: 9158929].
899 Stewart S, Horowitz JD. Home-Based Intervention in Congestive Heart Failure. Circulation. Jun. 18. 2002;105(24):2861-6. Exclusion reason: Wrong intervention. [pmid: 12070114].
900 Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on planned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. The Lancet. Sep. 25. 1999;354(9184):1077-83. Exclusion reason: Wrong intervention. [pmid: 10509499].
901 Stewart S, Pearson S, Horowitz JD. Effects of a Home-Based Intervention Among Patients With Congestive Heart Failure Discharged From Acute Hospital Care. Arch Intern Med. May. 25. 1998;158(10):1067-72. Exclusion reason: Wrong intervention. [pmid: 9605777].
902 Stewart S, Pearson S, Luke CG, et al. Effects of home-based intervention on unplanned readmissions and out-of-hospital deaths. Journal of the American Geriatric Society. Feb. 1998;46(2):174-80. Exclusion reason: Wrong intervention. [pmid: 9475445].
903 Stewart S, Vandenbroek AJ, Pearson S, et al. Prolonged Beneficial Effects of a Home-Based Intervention on Unplanned Readmissions and Mortality Among Patients With Congestive Heart Failure. Arch Intern Med. Feb. 8. 1999;159(3):257-61. Exclusion reason: Wrong intervention. [pmid: 9989537].
904 Stomper AP. Chronic disease management: what happens when home health care is completed?. Home Health Care Management & Practice. Jun. 1998;10(4):53-6. Exclusion reason: No original data.
905 Storey CL. The psychotherapeutic dimensions of clinical case management with a combat veteran. Smith College Studies in Social Work (Haworth). 2009;79(3-4):443-52. Exclusion reason: No original data.
906 Storfjell JL, Mitchell R, Daly GM. Nurse-managed healthcare. New York's Community Nursing Organization. Journal of Nursing Administration. Oct. 1997;27(10):21-7. Exclusion reason: No original data. [pmid: 9379237].
907 Stowers M, Williams M. Improving the cancer patient journey: the impact of a regional cancer coordination model. Australian Journal of Cancer Nursing. 2008;9(1):5-11. Exclusion reason: Wrong outcome.
908 Strzelecki S, Brobst R. The development of an acute care case manager orientation. Journal of Nursing Staff Development. Sep-Oct. 1997;13(5):266-71. Exclusion reason: No original data. [pmid: 9362824].
909 Stuckey HL, Dellasega C, Graber NJ, et al. Diabetes nurse case management and motivational interviewing for change (DYNAMIC): study design and baseline characteristics in the Chronic Care Model for type 2 diabetes. Contemporary clinical trials. Jul. 2009;30(4):366-74. Exclusion reason: Wrong intervention. [pmid: 19328244].
910 Sullivan R, Paten A, Audet K, et al. Implementation of case management at St. Vincent's Hospital Sydney. Nursing Monograph. 1992:8. Exclusion reason: No original data.
911 Sullivan WP, Fisher BJ. Intervening for success: strengths-based case management and successful aging. Journal of Gerontological Social Work. 1994;22(1-2):61-74. Exclusion reason: No original data.
912 Sundance P, Cope DN, Kirshblum S, et al. Systematic care management: clinical and economic analysis of a national sample of patients with spinal cord injury. Topics in Spinal Cord Injury Rehabilitation. 2004;10(2):17-34. Exclusion reason: Wrong intervention.
913 Suter P, Hennessey B, Harrison G, et al. Home-based chronic care: an expanded integrative model for home health professionals. Home Healthcare Nurse. Apr. 2008;26(4):222-9. Exclusion reason: No original data. [pmid: 18408515].
914 Sutherland D, Hayter M. Structured review: evaluating the effectiveness of nurse case managers in improving health outcomes in three major chronic diseases. Journal of Clinical Nursing. Nov. 2009;18(21):2978-92. Exclusion reason: No original data. [pmid: 19747197].
915 Sweeney L, Halpert A, Waranoff J. Patient-centered management of complex patients can reduce costs without shortening life. American Journal of Managed Care. Feb. 2007;13(2):84-92. Exclusion reason: Wrong intervention. [pmid: 17286528].
916 Swindle DN, Weyant JL, Mar PS. Nurse case management: collaborative beyond the hospital walls. Journal of Case Management. 1994;3(2):51-5. Exclusion reason: No original data. [pmid: 8000323].
917 Tahan HA. Identifying and reducing risk of medical errors. Case Manager. May-Jun. 2005;16(3):80-2. Exclusion reason: No original data. [pmid: 15999091].
918 Tahan HA, Campagna V. Case management roles and functions across various settings and professional disciplines. Professional Case Management. Sep-Oct. 2010;15(5):245-77. quiz 78-9. Exclusion reason: Background. [pmid: 20616764].
919 Tahan HA, Downey WT, Huber DL. Case managers' roles and functions: Commission for Case Manager Certification's 2004 research, part II. Lippincott's Case Management. Mar-Apr. 2006;11(2):71-87. quiz 8-9. Exclusion reason: Wrong outcome. [pmid: 16582699].
920 Taylor CB, Miller NH, Smith PM, et al. The effect of a home-based, case-managed, multifactorial risk-reduction program on reducing psychological distress in patients with cardiovascular disease. Journal of cardiopulmonary rehabilitation. May-Jun. 1997;17(3):157-62. Exclusion reason: Wrong intervention. [pmid: 9187981].
921 Taylor IC, McConnell JG. ‘Assessment and care management’--a hospital perspective. Ulster Medical Journal. Oct. 1994;63(2):185-92. Exclusion reason: Wrong intervention. [pmid: 8650832].
922 Taylor JCS, Bestall JC, Cotter S, et al. Clinical service organisation for heart failure. Cochrane Database of Systematic Reviews. 2010;(11). Exclusion reason: Wrong intervention.
923 Taylor M. Tele-case management lets Iowa heart patients go home and stay there. H&HN: Hospitals & Health Networks. May. 2008;82(5):33. Exclusion reason: No original data.
924 Taylor P. Protocols in practice. Case management program for breast cancer education. Nursing Case Management. 1999;4(3):135-44. Exclusion reason: No original data. [pmid: 10476183].
925 Taylor RS, Dalal H, Jolly K, et al. Home-based versus centre-based cardiac rehabilitation. Cochrane Database of Systematic Reviews. Jan. 20. 2010;(1):CD007130. Exclusion reason: Wrong intervention. [pmid: 20091618].
926 Tennille J, Solomon P, Blank M. Case managers discovering what recovery means through an HIV prevention intervention. Community Mental Health Journal. Oct. 2010;46(5):486-93. Exclusion reason: Wrong outcome. [pmid: 20549558].
927 Terra SM. An evidence-based approach to case management model selection for an acute care facility. Is there really a preferred model?. Professional Case Management. 2007;12(3):147-57. Exclusion reason: Wrong setting. [pmid: 17513996].
928 Terra SM. Regulatory issues. Recovery audit contractors and their impact on case management. Professional Case Management. 2009;14(5):217-23. Exclusion reason: No original data. [pmid: 19491716].
929 Theodos P. Fall prevention in frail elderly nursing home residents: a challenge to case management: part I. Lippincott's Case Management. Nov-Dec. 2003;8(6):246-51. Exclusion reason: Wrong intervention. [pmid: 14646782].
930 Theodos P. Fall prevention in frail elderly nursing home residents: a challenge to case management: part II. Lippincott's Case Management. Jan-Feb. 2004;9(1):32-44. Exclusion reason: Wrong intervention. [pmid: 15076837].
931 Thibault L. Paving the way. Outcome planner for the orthopaedic patient at home… implementing case management across the continuum: the transition of the orthopaedic patient. proceedings of selected papers from the NAON 1996 Fall Case Management Conference. New Orleans, LA. November 14-16, 1996. Orthopaedic Nursing. 1997:53-4. Exclusion reason: No original data.
932 Thiebaud P, Demand M, Wolf SA, et al. Impact of disease management on utilization and adherence with drugs and tests: the case of diabetes treatment in the Florida: a Healthy State (FAHS) program. Diabetes Care. Sep. 2008;31(9):1717-22. Exclusion reason: Wrong intervention. [pmid: 18523144].
933 Tholcken M, Clark MC, Tschirch P. Educational innovations. Case management in the undergraduate curriculum. Journal of Nursing Education. Jan. 2004;43(1):45-8. Exclusion reason: No original data. [pmid: 14748535].
934 Thomas D. Case management for long-term conditions. Nursing Management - UK. 2009;15(10):22-7. Exclusion reason: No original data.
935 Thomas ME. The providers' coordination of care: a model for collaboration across the continuum of care. Professional Case Management. 2008;13(4):220-27. Exclusion reason: No original data. [pmid: 18636007].
936 Thomas ND. Case management from urban and suburban perspectives. Journal of Case Management. 1998;7(4):139-46. Exclusion reason: Wrong outcome. [pmid: 10703380].
937 Thomas S. Managed clinical networks: delivering the NSF. Primary Health Care. May. 2005;15(4):22-4. Exclusion reason: No original data.
938 Thomas S. Supporting people with long-term conditions. Primary Health Care. Feb. 2005;15(1):13-4. Exclusion reason: No original data.
939 Thornlow DK. Nursing patient safety research in rural health care settings. Annual Review of Nursing Research. 2008;26:195-218. Exclusion reason: No original data. [pmid: 18709751].
940 Thorpe KE, Ogden LL, Galactionova K. Chronic conditions account for rise in Medicare spending from 1987 to 2006. Health Affairs. Apr. 2010;29(4):718-24. Exclusion reason: Wrong intervention. [pmid: 20167626].
941 Thuemmler C, Morris C. Global case management: Scotland: real-time monitoring of patient flow as an instrument to optimize quality of care in acute receiving units. Lippincott's Case Management. Sep-Oct. 2005;10(5):254-60. Exclusion reason: Wrong setting. [pmid: 16205208].
942 Tichawa U. Creating a continuum of care for elderly individuals. Journal of Gerontological Nursing. Jan. 2002;28(1):46-52. Exclusion reason: Wrong setting. [pmid: 11829225].
943 Tidwell L, Holland SK, Greenberg J, et al. Community-based nurse health coaching and its effect on fitness participation. Lippincott's Case Management. Nov-Dec. 2004;9(6):267-79. Exclusion reason: Wrong intervention. [pmid: 15602336].
944 Timberlake A. APN care management model delivers results for community hospital… advance practice nurse. COR Clinical Excellence. Feb. 2001;2(2):5-6. Exclusion reason: No original data.
945 Tobacman JK, Kissinger P, Wells M, et al. Implementation of personal health records by case managers in a VAMC general medicine clinic. Patient Education & Counseling. Jul. 2004;54(1):27-33. Exclusion reason: Wrong intervention. [pmid: 15210257].
946 Tonges MC. Job design for nurse case managers. Intended and unintended effects on satisfaction and well-being. Nursing Case Management. Jan-Feb. 1998;3(1):11-23. quiz 4-5. Exclusion reason: Wrong setting. [pmid: 9526392].
947 Topp R, Tucker D, Weber C. Effect of a clinical case manager/clinical nurse specialist on patients hospitalized with congestive heart failure. Nursing Case Management. Jul-Aug. 1998;3(4):140. Exclusion reason: Wrong setting. [pmid: 9856058].
948 Tosun N, Akbayrak N. Global case management: using the case management model for the care of patients with acute myocardial infarction in a military hospital in Turkey. Lippincott's Case Management. Jul-Aug. 2006;11(4):207-15. Exclusion reason: Wrong setting. [pmid: 16926693].
949 Tracey F, Taylor IC, McConnell JG. A prospective study of the process of assessment and care management in the discharge of elderly patients from hospital. Ulster Medical Journal. May. 1998;67(1):36-40. Exclusion reason: Wrong intervention. [pmid: 9652198].
950 Treiger TM. Technology in support of health care reform: case management at the ready. Case in Point. 2009;7(6):24-7. Exclusion reason: No original data.
951 Trella B, Cohen EL. Integrating services across the continuum: the challenge of chronic care. Nurse case management in the 21st century. 1996:87-104. Exclusion reason: No original data.
952 Trinidad EA. Case management: a model of CNS practice. Clinical Nurse Specialist: The Journal for Advanced Nursing Practice. Jul. 1993;7(4):221-3. Exclusion reason: No original data. [pmid: 8348464].
953 Tsai JH, Salazar MK, Graham KY, et al. Case management for injured workers. A descriptive study using a record review. AAOHN Journal. Sep. 1999;47(9):405-15. Exclusion reason: Wrong population. [pmid: 10661052].
954 Tucker D, DiRico L. GN management. Managing costly Medicare patients in the hospital. Geriatric Nursing. Sep-Oct. 2003;24(5):294-7. Exclusion reason: No original data. [pmid: 14571245].
955 Tullett M, Neno R. Approaches to long-term conditions management and care for older people: similarities or differences?. Journal of Nursing Management. Mar. 2008;16(2):167-72. Exclusion reason: No original data. [pmid: 18269547].
956 Turner-Bowker DM, Saris-Baglama RN, Anatchkova M, et al. A computerized asthma outcomes measure is feasible for disease management. American Journal of Pharmacy Benefits. Apr. 1. 2010;2(2):119-24. Exclusion reason: Wrong intervention. [pmid: 20852675].
957 Twyman DM, Libbus MK. Case-management of AIDS clients as a predictor of total inpatient hospital days. Public Health Nursing. Dec. 1994;11(6):406-11. Exclusion reason: Wrong setting. [pmid: 7870658].
958 Urden LD. Heart failure collaborative care: an integrated partnership to manage quality and outcomes. Outcomes Management for Nursing Practice. Apr-Jun. 1998;2(2):64-70. Exclusion reason: No original data. [pmid: 9582818].
959 Valentim M. First evaluation of nurse's care at emergency rooms: the approximate of model the case management strategy. Online Brazilian Journal of Nursing. Sep. 1. 2007;6(3):11. Exclusion reason: Wrong intervention.
960 Van Achterberg T, Stevens FJ, Crebolder HF, et al. Coordination of care: effects on the continuity and quality of care. International Journal of Nursing Studies. Dec. 1996;33(6):638-50. Exclusion reason: Wrong intervention. [pmid: 8970861].
961 van der Feltz-Cornelis CM, van Oppen P, Ader HJ, et al. Randomised controlled trial of a collaborative care model with psychiatric consultation for persistent medically unexplained symptoms in general practice. Psychotherapy & Psychosomatics. 2006;75(5):282-9. Exclusion reason: Wrong intervention. [pmid: 16899964].
962 Van Doren ES, Bowman J, Landstrom GL, et al. Structure and process variables affecting outcomes for heart failure clients. Lippincott's Case Management. Jan-Feb. 2004;9(1):21-6. Exclusion reason: Wrong setting. [pmid: 15076834].
963 Van Horn ER. Loss and depression after traumatic injury: the importance of case management in the recovery process. Professional Case Management. Mar-Apr. 2009;14(2):66-73. quiz 4-5. Exclusion reason: Wrong intervention. [pmid: 19318896].
964 Van Zandt SE, D'Lugoff MI, Kelley L. A community-based free nursing clinic's approach to management of health problems for the uninsured: the hepatitis C example. Family & Community Health. Oct. 2002;25(3):61-70. Exclusion reason: No original data. [pmid: 12802143].
965 Vasquez MS. Home care today. Preventing rehospitalization through effective home health nursing care. Home Healthcare Nurse. Feb. 2008;26(2):75-81. Exclusion reason: No original data. [pmid: 18301108].
966 Vasquez MS. Preventing Rehospitalization through effective home health nursing care. Professional Case Management. Jan-Feb. 2009;14(1):32-8. Exclusion reason: Wrong intervention. [pmid: 19092599].
967 Veeder NW. Care management as management. Care Management Journals. Winter. 2001-2002;3(2):68-76. Exclusion reason: Wrong outcome. [pmid: 12455217].
968 Vermeire EIJJ, Wens J, Van Royen P, et al. Interventions for improving adherence to treatment recommendations in people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention.
969 Verran JA, Mark B. Contextual factors influencing patient outcomes. Individual/group/environment: interactions and clinical practice interface. Patient outcomes research: examining the effectiveness of nursing practice. Proceedings of the State of the Science Conference sponsored by the National Center for Nursing Research. September 11-13, 1991. Rockville, Maryland. United States Department of Health and Human Services Public Health Service. 1992:121-43. Exclusion reason: No original data.
970 Vetter MJ, Bristow L, Ahrens J. A model for home care clinician and home health aide collaboration: diabetes care by nurse case managers and community health workers. Home healthcare nurse. Sep. 2004;22(9):645-8. Exclusion reason: Wrong intervention. [pmid: 15359179].
971 Vickers LF, O'Neill CM. An interdisciplinary home healthcare program for patients with Parkinson's disease. Rehabilitation Nursing. Nov-Dec. 1998;23(6):286-9. Exclusion reason: No original data. [pmid: 10223029].
972 Vinton L, Crook WP, LeMaster K. Factors related to frustration among aging services case managers. Care Management Journals. 2003;4(1):2-7. Exclusion reason: Wrong outcome. [pmid: 14502872].
973 Vinton L, Kim YS. Paying family members to provide home care: an evaluation of one program. Journal of Case Management. 1996;5(3):99-105. Exclusion reason: Wrong outcome. [pmid: 9257624].
974 Vista AA. An exploratory study of the relationship between home health patient satisfaction and patient outcomes [Ph.D.]. Walden University. 2000. Exclusion reason: Wrong outcome.
975 Volmink J, Garner P. Directly observed therapy for treating tuberculosis. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: Wrong intervention.
976 Volmink J, Garner P. Interventions for promoting adherence to tuberculosis management. Cochrane Database of Systematic Reviews. 2010;(8). Exclusion reason: Wrong intervention.
977 Von Korff M, Gruman J, Schaefer J, et al. Perspective. Collaborative management of chronic illness. Annals of Internal Medicine. 1997;127(12):1097-102. Exclusion reason: No original data. [pmid: 9412313].
978 Wagner EH. The role of patient care teams in chronic disease management. BMJ: British Medical Journal. 2000;320(7234):569-72. Exclusion reason: Background. [pmid: 10688568].
979 Walker C, Hogstel MO, Curry LC. Hospital discharge of older adults. American Journal of Nursing. 2007;107(6):60-71. Exclusion reason: No original data. [pmid: 17519609].
980 Walker MK, Sebastian JG, Moorhead S. Complementarity of advanced practice nursing roles in enhancing health outcomes of the chronically ill: acute care nurse practitioners and nurse case managers. Nursing roles: evolving or recycled?. 1997:170-90. Exclusion reason: No original data.
981 Walters AEJ, Turnock AC, Walters HE, et al. Action plans with limited patient education only for exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. May. 2010;(5):CD005074. Exclusion reason: Wrong intervention. [pmid: 20464737].
982 Walters J, Schwartz CF, Monaghan H, et al. Long-term outcome following case management after coronary artery bypass surgery. Journal of Cardiac Surgery. Mar. 1998;13(2):123-8. Exclusion reason: Wrong setting. [pmid: 10063958].
983 Wang EA, Hong CS, Samuels L, et al. Transitions clinic: creating a community-based model of health care for recently released California prisoners. Public Health Reports. Mar-Apr. 2010;125(2):171-7. Exclusion reason: No original data. [pmid: 20297743].
984 Warren E, Hart G, Winterbottom J, et al. An evaluation of a nurse specialist/case manager intervention in the management of epilepsy. Epilepsia. 1999;40(2). Exclusion reason: Unable to locate.
985 Warren RL, Wirtalla C, Leibensberger A. Preliminary observations on reduced utilization in skilled nursing facility rehabilitation. American Journal of Physical Medicine & Rehabilitation. Aug. 2001;80(8):626-33. Exclusion reason: No original data. [pmid: 11475487].
986 Warrick LH, Christianson JB, Williams FG, et al. The design and implementation of hospital-based coordinated care programs. Hospital & Health Services Administration. 1990;35(4):505-24. Exclusion reason: Wrong outcome. [pmid: 10107384].
987 Warrick LH, Netting FE, Christianson JB, et al. Hospital-based case management: results from a demonstration. Gerontologist. Dec. 1992;32(6):781-8. Exclusion reason: Wrong outcome. [pmid: 1478497].
988 Wasson JH, Ahles T, Johnson D, et al. Resource planning for patient-centered, collaborative care. Journal of Ambulatory Care Management. Jul-Sep. 2006;29(3):207-14. Exclusion reason: Wrong intervention. [pmid: 16788353].
989 Waszynski CM, Murakami W, Lewis M. Community care management. Advanced practice nurses as care managers. Care Management Journals. 2000;2(3):148-52. Exclusion reason: Wrong intervention. [pmid: 11398570].
990 Waterman H, Waters K, Awenat Y. The introduction of case management on a rehabilitation floor. Journal of Advanced Nursing. Nov. 1996;24(5):960-7. Exclusion reason: Wrong setting. [pmid: 8933256].
991 Watt HM. Community-based case management: a model for outcome-based research for non-institutionalized elderly. Home Health Care Services Quarterly. 2001;20(1):39-65. Exclusion reason: Background. [pmid: 11878075].
992 Weightman C. Long-term management of patients with multiple sclerosis. British Journal of Community Nursing. Jul. 2006;11(7):303-7. Exclusion reason: No original data. [pmid: 16926711].
993 Weissert W, Chernew M, Hirth R. Titrating versus targeting home care services to frail elderly clients: an application of agency theory and cost-benefit analysis to home care policy. Journal of Aging & Health. Feb. 2003;15(1):99-123. Exclusion reason: No original data. [pmid: 12611411].
994 Weissert WG, Hirth RA, Chernew ME, et al. Case management: effects of improved risk and value information. The Gerontologist. Dec. 2003;43(6):797-805. Exclusion reason: Wrong intervention. [pmid: 14704377].
995 Weng HC. Impacts of a government-sponsored outpatient-based disease management program for patients with asthma: a preliminary analysis of national data from Taiwan. Disease Management. Feb. 2005;8(1):48-58. Exclusion reason: Wrong intervention. [pmid: 15722704].
996 Wennberg JE, Bronner K, Skinner JS, et al. Inpatient care intensity and patients' ratings of their hospital experiences. Health Affairs. Jan-Feb. 2009;28(1):103-12. Exclusion reason: Wrong intervention. [pmid: 19124860].
997 Whellan DJ, Hasselblad V. Metaanalysis and review of heart failure disease management randomized controlled clinical trials. American Heart Journal. 2005;149:722-9. Exclusion reason: Background. [pmid: 15990759].
998 While A. While's words. Staking a claim to manage chronic disease. British Journal of Community Nursing. Apr. 2005;10(4):196. Exclusion reason: No original data. [pmid: 15966360].
999 White KR, Bazzoli GJ, Roggenkamp SD, et al. Does case management matter as a hospital cost-control strategy?. Health Care Management Review. Jan-Mar. 2005;30(1):32-43. Exclusion reason: Wrong setting. [pmid: 15773252].
1000 Wideman M, Pizzello L, Lemke S. Impact of nursing case management on an underserved population. Home Health Care Management & Practice. Dec. 2008;21(1):17-22. Exclusion reason: Wrong population.
1001 Wieckowski J, Simmons J. Translating evidence-based physical activity interventions for frail elders. Home Health Care Services Quarterly. 2006;25(1-2):75-94. Exclusion reason: No original data. [pmid: 16803739].
1002 Wilcox AB, Dorr DA, Burns L, et al. Physician perspectives of nurse care management located in primary care clinics. Care Management Journals. 2007;8(2):58-63. Exclusion reason: Wrong outcome. [pmid: 17595923].
1003 Willenbring ML. Integrating qualitative and quantitative components in evaluation of case management. Progress and issues in case management. 1992;127:223-50. Exclusion reason: Wrong outcome. [pmid: 1435997].
1004 Willenbring ML. Case Management for homeless public inebriates. 1997. Exclusion reason: Wrong population.
1005 Williams A, Hanchett M. Evolving models of case management in home infusion. Journal of the Association for Vascular Access. Winter. 2004;9(4):207-13. Exclusion reason: No original data.
1006 Williams CM, Petrelli J, Murphy M. Development and implementation of a geriatric care/case management program in a military community-based family medicine residency. Military Medicine. Nov. 2000;165(11):809-15. Exclusion reason: No original data. [pmid: 11143424].
1007 Williams JK. Case management: opportunities for service providers. Home Health Care Services Quarterly. 1993;14(1):5-40. Exclusion reason: Wrong outcome. [pmid: 10128387].
1008 Wilsker D, Roberts K, Skeels MF, et al. Faculty case management: an innovative approach in a primary health care clinic. Case Manager. Sep-Oct. 2002;13(5):62-8. Exclusion reason: No original data. [pmid: 12239516].
1009 Wimberley ET, Blazyk S. Monitoring patient outcome following discharge: a computerized geriatric case-management system. Health & Social Work. Nov. 1989;14(4):269-76. Exclusion reason: Wrong setting. [pmid: 2599485].
1010 Winder PG. Case management by nurses at a county facility. QRB. Jul. Quality Review Bulletin. 1988;14(7):215-9. Exclusion reason: No original data. [pmid: 3140165].
1011 Wingard R. Reducing early mortality in patients on dialysis: lessons from the RightStart program. Nephrology nursing journal : journal of the American Nephrology Nurses' Association. Mar-Apr. 2009;36(2):215-20. Exclusion reason: Wrong setting. [pmid: 19397178].
1012 Wingate S. Commentary on “The impact of using nursing presence in a community heart failure program”. Journal of Cardiovascular Nursing. Mar-Apr. 2007;22(2):97-8. Exclusion reason: No original data.
1013 Wisser S, Aliotta SL. Case management best practices that pave the way for real world success. Case Manager. Jan-Feb. 2003;14(1):54-7. Exclusion reason: Background. [pmid: 12532078].
1014 Wolber T, Ward D. Implementation of a diabetes nurse case management program in a primary care clinic: a process evaluation. Journal of Nursing & Healthcare of Chronic Illnesses. Jun. 2010;2(2):122-34. Exclusion reason: Wrong outcome.
1015 Wolfe GS. HIV/AIDS: developing a disease management program. Remington Report. Jul-Aug. 1997;5(4):34-9. Exclusion reason: Wrong intervention.
1016 Wolff JL, Starfield B, Anderson G. Prevalence, Expenditures, and Complications of Multiple Chronic Conditions in the Elderly. Arch Intern Med. Nov. 11. 2002;162(20):2269-76. Exclusion reason: Wrong intervention. [pmid: 12418941].
1017 Wong FKY, Chow SKY, Chan TMF. Evaluation of a nurse-led disease management programme for chronic kidney disease: a randomized controlled trial. International Journal of Nursing Studies. Mar. 2010;47(3):268-78. Exclusion reason: Wrong intervention. [pmid: 19651405].
1018 Woodend K. The role of community matrons in supporting patients with long-term conditions. Nursing Standard. Jan. 25-31. 2006;20(20):51-4. Exclusion reason: No original data. [pmid: 16459765].
1019 Wright K, Allen K, Weinhardt J, et al. Effectiveness of interdisciplinary post-stroke case management in improving patient outcomes: a pilot study. Journal of Stroke and Cerebrovascular Diseases. 2000;9(4):205. Exclusion reason: No original data.
1020 Wright K, Hazelett S, Jarjoura D, et al. The AD-LIFE trial: working to integrate medical and psychosocial care management models. Home Healthcare Nurse. May. 2007;25(5):308-14. Exclusion reason: Wrong outcome. [pmid: 17495560].
1021 Wright K, Ryder S, Gousy M. An evaluation of a community matron service from the patients' perspective. British Journal of Community Nursing. Sep. 2007;12(9):398-403. Exclusion reason: Wrong outcome. [pmid: 18026002].
1022 Wright K, Ryder S, Gousy M. Community matrons improve health: patients' perspectives. British Journal of Community Nursing. Oct. 2007;12(10):453-9. Exclusion reason: Wrong outcome. [pmid: 18073645].
1023 Wulff CN, Thygesen M, Sondergaard J, et al. Case management used to optimize cancer care pathways: a systematic review. BMC Health Serv Res. 2008;8:227. Exclusion reason: Background. [pmid: 18986554].
1024 Wynia K, Annema C, Nissen H, et al. Design of a Randomised Controlled Trial (RCT) on the effectiveness of a Dutch patient advocacy case management intervention among severely disabled Multiple Sclerosis patients. BMC Health Services Research. 2010;10:142. Exclusion reason: No original data. [pmid: 20507600].
1025 Yarmo D, Scanlan N, Edge V, et al. Embracing the continuum of care: an Australian private hospital's experience. Journal of Case Management. Fall. 1998;7(3):127-34. Exclusion reason: Wrong intervention. [pmid: 10703378].
1026 Yau DCN, Leung ACT, Yeoh CS, et al. Global case management: Hong Kong Care for the hospital-discharged frail elders by nurse case managers: a process evaluation of a longitudinal case management service project. Lippincott's Case Management. Jul-Aug. 2005;10(4):203-12. Exclusion reason: Wrong outcome. [pmid: 16056117].
1027 Yordi C, DuNah R, Bostrom A, et al. Caregiver supports: outcomes from the Medicare Alzheimer's disease demonstration. Health Care Financing Review. 1997;19(2):97-117. Exclusion reason: Wrong outcome. [pmid: 10345408].
1028 Yordi CL. Case management in the social health maintenance organization demonstrations. Health Care Financing Review. Dec. Spec No. 1988:83-8. Exclusion reason: Wrong outcome. [pmid: 10312977].
1029 Yoshie S, Saito T, Takahashi M, et al. Effect of work environment on care managers' role ambiguity: an exploratory study in Japan. Care Management Journals. 2008;9(3):113-21. Exclusion reason: Wrong outcome. [pmid: 18847095].
1030 Young HM, Haight K. Case management in a retirement community. Nursing Administration Quarterly. 1993;17(3):34-8. Exclusion reason: No original data. [pmid: 8502420].
1031 Young S. Professional relationships and power dynamics between urban community-based nurses and social work case managers: advocacy in action. Professional Case Management. Nov-Dec. 2009;14(6):312-20. Exclusion reason: Wrong outcome. [pmid: 19935349].
1032 Young T, Busgeeth K. Home-based care for reducing morbidity and mortality in people infected with HIV/AIDS. Cochrane Database of Systematic Reviews. 2010;(5). Exclusion reason: Wrong intervention. [pmid: 20091575].
1033 Yu DS, Thompson DR, Lee DT. Disease management programmes for older people with heart failure: crucial characteristics which improve post-discharge outcomes. Eur Heart J. Mar. 2006;27(5):596-612. Exclusion reason: Background. [pmid: 16299021].
1034 Yuan LP, Manderson L, Ren MY, et al. School-based interventions to enhance knowledge and improve case management of schistosomiasis: a case study from Hunan, China. Acta tropica. Nov-Dec. 2005;96(2-3):248-54. Exclusion reason: Wrong intervention. [pmid: 16202594].
1035 Zaller ND, Holmes L, Dyl AC, et al. Linkage to treatment and supportive services among HIV-positive ex-offenders in Project Bridge. Journal of Health Care for the Poor & Underserved. May. 2008;19(2):522-31. Exclusion reason: Wrong population. [pmid: 18469423].
1036 Zander K. Nursing case management: strategic management of cost and quality outcomes. Journal of Nursing Administration. May. 1988;18(5):23-30. Exclusion reason: No original data. [pmid: 3367227].
1037 Zander K. Nursing case management: resolving the DRG paradox. Nursing Clinics of North America. Sep. 1988;23(3):503-20. Exclusion reason: No original data. [pmid: 3138667].
1038 Zander K, Warren C. Issues and interventions Converting case managers from MD/service to unit-based assignments: a before and after comparison. Lippincott's Case Management. Jul-Aug. 2005;10(4):180-4. Exclusion reason: Wrong setting. [pmid: 16056113].
1039 Zausig YA, Grube C, Boeker-Blum T, et al. Inefficacy of simulator-based training on anaesthesiologists' non-technical skills. Acta Anaesthesiologica Scandinavica. May. 2009;53(5):611-9. Exclusion reason: Wrong intervention. [pmid: 19419355].
1040 Zawadski RT, Eng C. Case management in capitated long-term care. Health Care Financing Review. Dec. Spec No. 1988:75-81. Exclusion reason: No original data. [pmid: 10312976].
1041 Zazworsky D. Project targets patients in Latino community. Patient Education Management. Oct. 2007;14(10):117-8. Exclusion reason: No original data.
1042 Zerull L, Cohen EL. Nurse case management in a rural community. Nurse case management in the 21st century. 1996:133-9. Exclusion reason: Wrong setting.
1043 Ziebarth D. Parish nursing used in a multidisciplinary team approach to case manage Emergency Department's high utilization patients. Wisconsin Parish Nurse Coalition. May. 2009;8(2):6-7. Exclusion reason: No original data.
1044 Zimmer JG, Eggert GM, Treat A, et al. Nursing homes as acute care providers. A pilot study of incentives to reduce hospitalizations. Journal of the American Geriatrics Society. Feb. 1988;36(2):124-9. Exclusion reason: Wrong intervention. [pmid: 3276766].
1045 Zink MR. Episodic case management in home care. Home Healthcare Nurse. Oct. 2005;23(10):655-62. Exclusion reason: No original data. [pmid: 16217216].
1046 Zurovac D, Larson BA, Skarbinski J, et al. Modeling the financial and clinical implications of malaria rapid diagnostic tests in the case-management of older children and adults in Kenya. American Journal of Tropical Medicine & Hygiene. Jun. 2008;78(6):884-91. Exclusion reason: Wrong intervention. [pmid: 18541764].
1047 Zwarenstein M, Goldman J, Reeves S. Interprofessional collaboration: effects of practice-based interventions on professional practice and healthcare outcomes. Cochrane Database of Systematic Reviews. Jul. 8. 2009;(3):CD000072. Exclusion reason: Wrong population. [pmid: 19588316].
1048 Zwarenstein M, Reeves S, Straus SE, et al. Case management: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: No original data.