# Inclusion and Exclusion Criteria

Abstract Level Eligibility Criteria

Study Characteristic | Inclusion/Exclusion
Population | Include: all ages >18; adults with medical illnesses and complex care needs Exclude: Mental health only
Interventions | Include: case management, care coordination, care management and disease management programs and others that may have elements of case management (e.g., coordination, medical monitoring) Exclude: disease management without care coordination, low intensity telephonic and short duration interventions, screening interventions
Comparators | Include: Usual care or other model of case management
Outcomes | Include: Relevant outcome measured (patient, resource utilization, or process measurement outcomes as listed in Key Questions.
Timing/Duration | Include: Duration >30 days
Setting | Include: Outpatient settings (i.e., primary care, specialty care, and home care)
Study Design | Include: Randomized trial, cohort, case control, systematic review, meta-analysis

Full-Text Eligibility Criteria

Study Characteristic | Inclusion/Exclusion
Population | Include: all ages >18; adults with medical illnesses and complex care needs Exclude: Mental health only
Interventions | Include: case management, care coordination, care management and disease management programs and others that may have elements of case management (e.g., coordination, medical monitoring) Exclude: disease management without care coordination, low intensity telephonic and short duration interventions, screening interventions
Comparators | Include: Usual care or other model of case management
Outcomes | Include: Patient (health) outcomes, resource utilization (e.g., hospitalizations, primary care visits), or process measurement outcomes (e.g. medication adherence)
Timing/Duration | Include any study duration >30 days
Setting | Include all outpatient settings (e.g., primary care) Exclude: Inpatient, hospital-based case management