# Exact Search Strings

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)

1947 to August Week 3 2010 (Updated 8/16/2011)

Search Strategy:

1. exp Patient Care Planning/ (48371)
2. ((manag$ or oversee$ or supervis$ or coordin$) adj5 ((patient$ adj3 care) or (case or cases))).mp. (36118)
3. 1 and 2 (8866)
4. limit 3 to English language (8356)
5. limit 4 to “all adult (19 plus years)” (2594)
6. limit 5 to yr=“2002 -Current” (1491)
7. limit 5 to yr=“1902 - 2001” (1103)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

<2nd Quarter 2010> (Updated 8/16/2011)

Search Strategy:

1. case manag$.ti,hw,kw. (597)

Database: EBM Reviews - Cochrane Database of Systematic Reviews

<2005 to August 2010> (Updated 8/16/2011)

Search Strategy:

1. case manag$.ti,kw. (9)
2. case manag$.oh,tw. (106)
3. 1 or 2 (106)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

<3rd Quarter 2010> (Updated 8/16/2011)

Search Strategy:

1. case manag$.ti,kw,tw. (86)

Database: CINAHL Plus with Full Text

1937-December 15, 2010 (Updated 8/16/2011)

Search Strategy:

S25 S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 (2474)
S24 S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23
S23 S3 and S14
S22 S3 and S13
S21 S3 and S12
S20 S3 and S11
S19 S3 and S10
S18 S3 and S7
S17 S3 and S6
S16 S3 and S5
S15 S3 and S4
S14 (MH “Attitude of Health Personnel+”)
S13 (MH “Professional-Patient Relations+”)
S12 (MH “Disease Attributes+”)
S11 (MH “Emergency Medical Services+”)
S10 S8 or S9
S9 (MH “Hospitalization+”)
S8 (MH “Hospitals+”)
S7 (MH “Mortality+”)
S6 (MH “Attitude to Health”)
S5 (MH “Quality of Life”)
S4 (MH “Outcome Assessment”) OR (MH “Nursing Outcomes”)
S3 S1 or S2
S2 (MH “Case Managers”)
S1 (MH “Case Management”)

Database: ClinicalTrials.gov

November 29, 2011

Search Strategy:

“case management” OR “case manager” OR “care coordination” OR “self-management support” OR “individual service coordination” OR “care management” OR “care managers” ∣ Recruitment: Closed Studies, Exclude Unknown checked ∣ Age Group: Adult, Senior (221)

WHO International Clinical Trials Registry Platform (ICTRP)

( http://apps.who.int/trialsearch/AdvSearch.aspx )

November 29, 2011

Search Strategy:

Search Terms in the Title Field: case management OR care coordination OR self-management support OR case manager OR individual service coordination OR care management OR care managers ∣ Recruitment Status: ALL (144)