# Acronyms and Abbreviations

AD: Alzheimer's disease
ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
APN: Advanced practice nurse
BMI: Body mass index
BP: Blood pressure
BS: Bachelor of science
CER: Comparative effectiveness review
CG: Caregiver
CHF: Congestive heart failure
CHW: Community health worker
CM: Case management
CMS: Centers for Medicare and Medicaid Services
COPD: Chronic obstructive pulmonary disease
DBP: Diastolic blood pressure
DM: Diabetes mellitus
DOT: Directly observed therapy
ED: Emergency department
EHC: Effective Health Care Program
EPC: Evidence-based Practice Center
FFS: Fee-for-service
FTF: Face-to-face
GDS: Global Deterioration Scale
GRACE: Geriatric Resources for Assessment and Care of Elders
HBPC: Home-based Primary Care
HDL: High-density lipoprotein cholesterol
HgA1c: Hemoglobin A1c
HMO: Health maintenance organization
IADL: Instrumental activities of daily living
IV: Intravenous
LDL: Low-density lipoprotein cholesterol
LPN: Licensed practical nurse
MADDE: Medicare Alzheimer's Disease Demonstration and Evaluation
MCCD: Medicare Coordinated Care Demonstration
MCO: Managed care organization
MMSE: Mini-mental State Examination
MSW: Master of social work
NP: Nurse practitioner
NPI: Neuropsychiatric inventory
NR: Not reported
NYHA: New York Heart Association
NYU: New York University
OP: Outpatient
PACE: Program for All-Inclusive Care of the Elderly
PCP: Primary care provider
PICOTS: Populations, interventions, comparators, outcomes, timing, and setting
PS: Psychosocial
QOL: Quality of life
RD: Registered dietitian
RN: Registered nurse
SBP: Systolic blood pressure
SF-36: Short form (36) Health Survey
SNF: Skilled nursing facility
SW: Social worker
TB: Tuberculosis
TC: Total cholesterol
TEP: Technical Expert Panel
TOO: Task Order Officer
U.K.: United Kingdom
U.S.: United States
VAMC: Veterans Affairs Medical Center