# Acknowledgments

The researchers at the Evidence-based Practice Center would like to acknowledge the following people for their contributions.

We are grateful to our Task Order Officer, Christine Chang, M.D., M.P.H., for her support and guidance in developing this report, and our Associate Editor, Meera Viswanathan, Ph.D., for her review of the report and meaningful comments. Key Informants and members of the Technical Expert Panel were instrumental in the formation of the parameters and goals of this review. We would also like to thank those who worked so conscientiously on the research team in searching the literature, retrieving and screening citations, extracting data, developing evidence tables, preparing figures, and editing the report—Martha Schechtel, R.N., Jessica Griffin, M.S., Andrew Hamilton, M.L.S., M.S., Robin Paynter, M.L.S., Basmah Rahman, M.P.H., Jesse H. Wagner, M.A., and Leah Williams. Finally, we thank Mark Helfand, M.D., M.P.H., for his insights, editorial review, and continued support.