# Results

## Literature Search

Of the 1,556 citations identified through the literature searches, 1,514 were excluded at various stages of review. One additional study was identified through grey literature searches. No additional studies were identified from one identified systematic review on PCA3^80^; this review was excluded from analyses as having no primary data. The 43 included articles reported the results of observational cohort studies with matched comparisons of PCA3 and other selected biomarkers. The PRISMA flow diagram (Figure 3) illustrates the review process for published studies, exclusions at each step and the selection results.

Figure 3 PRISMA diagram for selection of published studies

Figure 3 is a PRISMA diagram illustrating the review of articles identified via literature search for this systematic review. 1556 records identified through the literature search. Of these 1513 were excluded at various stages of screening and 43 records were included.

For Key Question (KQ) 1 and KQ 2, no randomized or comparative intervention trials were identified that included the use of PCA3 testing and reported long-term outcomes, or intermediate outcomes other than diagnostic accuracy. Of the 43 articles included, six studies addressing KQ 1 and KQ 2 were found to have duplicate data and were excluded from analyses34,47,81-84. Two other studies85,86 were excluded because reported data were not in a format usable for these analyses. Of the remaining 34 studies, 24 addressed KQ 1 and/or KQ 2 (Table 1, Table 2a).

Table 1 General descriptions of the included studies in matched populations

Author^a^, Year, Country | Enrollment Period (Month/Year) | Reference Standard | Biopsies Reported / Total Biopsies | Unreported Biopsies Explained^b^ | % Positive Biopsies | Number P / RP | Key Question Addressed | Potential COI Funding^c^ / Disclosures^d^
Adam90, 2011, South Africa | 07/09 - 02/10 | Biopsy | 105 / 107 | Yes | 43 | -- | 1, 2 | No / Yes
Ankerst65, 2008 European cohort, NAm cohort | NR | Biopsy | 443 / 443 | NA | 28 | -- | 2 | No / Yes
Aubin91, 2010, International, U.S. | NR | Biopsy | 1072 / 1140 | Yes | 18 | -- | 2 | Yes / Yes
Auprich92, 2011 Austria, Germany, U.S. | 7/08 – 7/09 | Biopsy | 127 / 127 | NA | 35 | -- | 2 | No / NR
Bollito93, 2012, Italy | 10/08 – 12/10 | Biopsy | 1237 / 1246 | Yes | 26 | -- | 1, 2 | No / No
Cao94, 2011, China | 06/09 – 04/10 | Biopsy | 131 / 143 | Yes | 60 | -- | 1, 2 | No / NR
de la Taille95, 2011, Europe | 02/08 - 08/09 | Biopsy | 516 / 528 | Yes | 40 | -- | 1 | Yes / Yes
Deras96, 2008, Canada, U.S. | 04/04 – 05/06 | Biopsy | 557 / 570 | Yes | 36 | -- | 1, 2 | NR / No
FDA Summary Document97, 2012 U.S. | NR | Biopsy | 466 / 495 | Yes | 22 | -- | 2 | Yes / Yes
Feero98, 2012, Italy | 5/10 – 12/10 | Biopsy | 151 / 151 | NA | 32 | -- | 1 | NR / NR
Goode99, 2012, U.S. | NR | Biopsy | 456 / 456 | NA | 19 | -- | 1, 2 | NR / NR
Hessels100, 2010,The Netherlands | 07/03 - 09/06 | Biopsy/P | 336 / 351 | Yes | 40 | 70 | 1, 2, 3 | No / NR
Mearini101, 2009, Italy | NR | Biopsy | 96 / 96 | NA | 73 | -- | 1, 2 | No / No
Nyberg102, 2010, Sweden | 01/08 - 09/08 | Biopsy | 62 / 62 | NA | 29 | -- | 1, 2 | No / No
Ochiai,103 2011, Japan | 05/07 - 05/08 | Biopsy | 105 / 105 | Yes | 36 | -- | 1, 2 | Yes / No
Ouyang104, 2009, U.S. | NR | Biopsy | 92/ 106 | Yes | 47 | -- | 1, 2 | No / NR
Pepe105, 2012, Italy | 10/09 – 09/11 | Biopsy | 74 / 74 | NA | 36 | -- | 2 | NR / NR
Perdona,31 2011, Italy | 10/08 - 10/09 | Biopsy | 218 / 218 | NA | 33 | -- | 1, 2 | No / No
Ploussard106, 2010, Europe | 08/06 – 07/07 | Biopsy | 301 / 301 | NA | 24 | -- | 2 | NR / Yes
Rigau107, 2010, Spain | NR | Biopsy | 215 / 262 | No | 34 | -- | 1, 2 | No / NR
Roobol,^108^2010, Europe | 09/07 - 02/09 | Biopsy | 721 / 721 | NA | 17 | -- | 1, 2 | NR / Yes
Schilling,109 2010, Germany | 01/08 - 06/08 | Biopsy | 32 /32 | Yes | 56 | -- | 1, 2 | NR / No
Wang110, 2009, U.S. | 09/06 – 12/07 | Biopsy | 187 / 192 | Yes | 46 | -- | 1, 2 | No / Yes
Wu111, 2012, U.S. | NR | Biopsy | 103 / 188 | Yes | 36 | -- | 2 | No / NR
Auprich112, 2011 Germany, U.S., Austria | 11/06 - 10/09 | P | -- | -- | -- | 305 | 3 | No / No
Durand113, 2012, France | 02/09 – 06/10 | P | -- | -- | -- | 160 | 3 | NR / No
Kusuda88, 2011, Japan | 10/01 - 07/04 | P | -- | -- | -- | 120 | 3 | NR / NR
Liss114, 2011, U.S. | 05/07 - 04/08 | P | -- | -- | -- | 98 | 3 | Yes / NR
Nakanishi115, 2008, U.S. | 06/05 - 05/06 | P | -- | -- | -- | 96 | 3 | Yes / Yes
Ploussard116, 2011, France | 02/09 - 06/10 | P | -- | -- | -- | 106 | 3 | No / No
Tosoian89, 2010, U.S. | 00/95 – 00/09 | Biopsy surveillance | 294 / 301 | No | 13 | -- | 3 | Yes / NR
Van Poppel117 2011, Austria, Belgium, France, Netherlands | NR | P | -- | -- | -- | 175 | 3 | Yes / Yes
Vlaeminck-Guillem118, 2011, France | 01/08 – 05/10 | P | -- | -- | -- | 102 | 3 | NR / Yes
Whitman119, 2008, U.S. | 09/06 - 11/07 | P | -- | -- | -- | 72 | 3 | Yes / Yes

COI = conflict of interest; FDA = U.S. Food and Drug Administration; NA = Not applicable; Nam = North American; NR = Not reported; P = prostatectomy; RP = radical prostatectomy

a In alphabetical order for studies with a reference standard of biopsy (N=24), then alphabetical order for studies with a reference standard of prostatectomy (N=9) or biopsy surveillance (N=1).

b ‘Unreported biopsies’ are biopsies completed without results reported. This column indicates whether the studies provided an explanation for missing biopsy results.

c ‘Yes’ indicates that funding for the study was provided entirely or in part by a developer of a PCA3 assay used in the study; ‘No’ indicates funding from another source.

d ‘Yes’ indicates that one or more authors disclosed a paid consultancy or other relationship with the developer of a PCA3 assay used in the study.

Table 2 Reported criteria for specific inclusion/exclusion of subjects for studies

Table 2a Reported criteria for specific inclusion/exclusion of subjects for studies addressing KQ 1 and KQ 2

Author^a,b^, Year | tPSA Cutoff (ng/ml) | Abnormal DRE (%) | Positive Biopsy | Initial Biopsy (%) | Positive Family History (%) | African-American | Other Risk Factors | Specific Exclusion Criteria
Adam90, 2011 | All values | Yes | No | 82 | Yes | Yes | NR | BPH, indwelling catheters
Ankerst65, 2008 | ≥2.5 | Yes (19) | No | 0 | 5.9 | NR | NR | NR
Aubin91, 2010 | 2.5-10 (<60y) 3-10 (≥60y) | No | No | 0 | No | NR | NR | tPSA levels >10; meds that affect tPSA levels; HGPIN, ASAP
Auprich92, 2011 | ≥2.5 to 6.5 - 50 | Yes (11) | No | 0 | NR | NR | NR | tPSA levels > 50
Bollito93, 2012 | ≥ 2.5 | No | No | 59 | NR | NR | NR | Suspicious DRE; HGPIN; ASAP
Cao94, 2011 | ≥4 | Yes | No | NR | NR | NR | NR | Meds that affect tPSA levels
de la Taille95, 2011 | 2.5-10 | Yes (19) | No | 100 | NR | NR | NR | tPSA levels >10
Deras96, 2008 | ≥ 2.5 | Yes (15) | No | 50 | Yes | Yes | Yes | NR
FDA Summary97, 2012 | NR | Yes | No | 0 | NR | Yes | NR | Meds that affect tPSA levels; UTI / prostatitis; treatment
Feero98, 2012 | 2.0-20 | No | No | 100 | NR | NR | NR | tPSA levels > 20
Goode99, 2012 | ≥ 4 | Yes | No | 63 | NR | NR | NR | NR
Hessels100, 2010 | >3 | Yes | No | Mixed; NR | Yes | NR | NR | NR
Mearini101, 2009 | >1 | Yes | No | NR | NR | NR | NR | NR
Nyberg102, 2010 | ≥ 2.5 | Yes | No | 55 | NR | NR | NR | NR
Ochiai103, 2011 | 2.5-50 | Yes | No | 81 | NR | NR | NR | Meds that affect tPSA levels
Ouyang104, 2009 | ≥ 4 | NR | No | NR | NR | NR | NR | NR
Pepe105, 2012 | 4-10 | Yes | No | 0 | NR | NR | NR | tPSA levels > 10
Perdona31, 2011 | < 10 | Yes (22) | No | 61 | No | No | NR | tPSA levels > 10; meds that affect tPSA levels; previous dx PCa
Ploussard106 | 2.5-10 | No | No | 0 | NR | NR | NR | tPSA levels > 10; , meds that affect tPSA levels; initial biopsies
Rigau107, 2010 | ≥ 4 | Yes (26) | No | 74 | NR | NR | NR | Meds that affect tPSA levels
Roobol108, 2010 | ≥ 3.0 | No | No | 71 | No | NR | NR | NR
Schilling109, 2010 | >4 | Yes | No | 56 | No | No | NR | NR
Wang110, 2009 | NR | Yes | No | 73 | Yes (19) | NR | Yes | History PCa
Wu111, 2012 | ≥ 10 | Yes (13) | No | 0 | NR | NR | NR | NR

Table 2b Reported criteria for specific inclusion/exclusion of subjects for studies addressing KQ 3

Author^a,b^, Year | Positive Biopsy | Description | Specific Exclusion Criteria
Auprich112, 2011 | Yes | Clinically localized PrC | Meds that affect PSA levels
Durand113, 2012 | Yes | Localized PrC | NR
Hessels100, 2010 | Yes | PrC | NR
Kusuda88, 2011 | Yes | Clinically localized PrC | NR
Liss114, 2011 | Yes | PrC | NR
Nakanishi115, 2008 | Yes | PrC | Not age 40-70, PSA levels ≥ 50; or taking meds that affect PSA levels
Ploussard116, 2011 | Yes | “Low risk” localized PrC | Not “low risk” (PSA ≤ 10; stage T1c-T2a; Gleason score 6)
Tosoian89, 2010 | Yes | “Low risk” PrC patients (Epstein criteria) in a surveillance program | Positive biopsy but not “low risk” based on Epstein criteria
van Poppel117, 2011 | Yes | Biopsy positive PrC | NR
Vlaeminck-Guillem118, 2011 | Yes | Biopsy positive | Neoadjuvant treatment
Whitman119, 2008 | Yes | Biopsy positive | Meds that affect PSA levels

ASAP = atypical small acinar proliferation; BPH = benign prostatic hyperplasia; DRE = digital rectal exam; HGPIN = high-grade prostatic intraepithelial neoplasia; NA = Not applicable; No = Not a criterion for inclusion; NR = not reported; PrC = prostate cancer; PSA = prostate specific antigen; tPSA = total prostate specific antigen; UTI = urinary tract infection

a In alphabetical order for KQ 1/KQ 2 studies (N=24) in Table 2a, then in alphabetical order for KQ 3 studies (N=11) in Table 2b.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. In Table 2a, rows 3, 7, 10, and 17-19 are shaded. There is no shading in Table 2b.

For KQ 3, no randomized or comparative intervention trials were identified that included the use of PCA3 testing and reported intermediate or long-term outcomes. Twelve observational studies were identified that addressed KQ 3 (Table 1, Table 2b), but one was excluded due to duplicate data.87 Two studies reported on short-term health outcomes (i.e., biochemical recurrence and time to progression to treatment from active surveillance).88,89Table 1 provides general descriptive information on all studies. Table 2 describes study inclusion/exclusion criteria, and Table 3 describes the populations studied. Table 4 provides key information on PCA3 testing. In later sections, Table 17 details the characteristics of matched biopsy and prostatectomy studies addressing KQ 3; Table 18 provides information on comparators investigated along with PCA3 scores in studies addressing KQ 3.

Table 3 Characteristics of populations studied

Author^a^, Year | Reference Standard | Age Distribution in Years Mean (sd) / Median (Range) | Race Distribution, % | % Positive DRE | % Positive Family History | Coexisting Pathology Name, %
Adam90, 2011 | Biopsy | NR / 67 (35-89) | White 25.7; AA 68.6; Other 5.7 | 48.6 | 4.8 | NR
Ankerst65, 2008 | Biopsy | NR / 66 (11-83) | White 97.5; AA 2.0; Other 0.5 | 18.7 | NR | NR
Aubin91, 2010 | Biopsy | 66.1 (6.0) / 66.1 (52.7-80) | NR | NR | 13.8 | NR
Auprich92,2011 | Biopsy | NR / 63 (50-70) | NR | 11 | NR | NR
Auprich112,2011 | P | NR / 63 (44-79) | NR | 23.9 | NR | NR
Bollito93, 2012 | Biopsy | NR / 67 (42-89) | NR | 0 | NR | NR
Cao94, 2011 | Biopsy | NR | Asian (Chinese) 100 | NR | NR | NR
de la Taille95, 2011 | Biopsy | 63 (7.6) / 63 | NR | NR | NR | NR
Deras96, 2008 | Biopsy | 64 / 64 (32-89) | White 82.5; AA 5.3; Hispanic 2.3; Asian 0.4; Other 9.6 | NR | NR | NR
FDA Summary97, 2012 | Biopsy | NR / 67 (44-92) | White 87.5; AA 9.1; Other 2.6 | NR | NR | NR
Feero98, 2012 | Biopsy | NR / 64 (48-87) | NR | 0 | NR | HGPIN, 24; BPH, 44
Goode99, 2012 | Biopsy | NR / 66 (41-90) | NR | NR | NR | HGPIN; ASAP
Hessels100, 2010 | Biopsy | 63 / 64 (38-83) | NR | NR | NR | NR
Kusuda88, 2011 | P | 67.2 (6.5) / NR | NR | NR | NR | NR
Liss114, 2011 | P | 62.7 (7.2) / NR | NR | 16 | NR | NR
Mearini101, 2009 | Biopsy | NR | NR | NR | NR | BPH, 27
Nakanishi115, 2008 | P | 60 / 60 (45-70) | White 78.1; AA 15.6; Hispanic 6.3 | NR | NR | NR
Nyberg102, 2010 | Biopsy | NR / 63 (IQR 57-70) | NR | NR | NR | HGPIN, 5
Ochiai103, 2011 | Biopsy | NR / 66 (44-87) | Asian (Japanese) 100 | NR | NR | NR
Ouyang104, 2009 | Biopsy | NR | White 98; AA 2 | NR | NR | NR
Pepe105, 2012 | Biopsy | NR / 64 (48-74) | NR | NR | NR | NR
Perdona31, 2011 | Biopsy | NR / 66 (60-72) | NR | NR | 4.6 | NR
Ploussard106, 2010 | Biopsy | 64.6 / 65.4 (43.3-83.4) | NR | NR | NR | ASAP, 4
Ploussard116, 2011 | P | 62 / 62 (43-75) | NR | NR | NR | NR
Rigau107, 2010 | Biopsy | Mean 65.7 / Range 44-85 | NR | 26.5 | NR | NR
Roobol108, 2010 | Biopsy | 70.0 / 70.2 (63.6-77.5) | NR | 13.1 | NR | NR
Schilling109, 2010 | Biopsy | NR / 67 (42-88) | NR | NR | NR | NR
Tosoian89, 2010 | Biopsy surveillance | 68.2 (6.2) / 68.2 (50.3-84.2) | White 91.8; AA 5.4; Other 2.8 | NR | NR | NR
Vlaeminck-Guillem118, 2011 | P | 62 (6) / 63 (47-72) | NR | NR | NR | NR
Wang110,2009 | Biopsy | 62 (8.3) / Median NR (44-86) | White 91.5; AA 5.3; Other 3.2 | 16 | 18.7 | HGPIN, 5.9 ASAP, 2.1
Whitman119, 2008 | P | NR / 58 (42-73) | White 75; AA 25 | NR | NR | NR
Wu111, 2012 | Biopsy | 63.5 (7.4) / NR | NR | 13 | NR | HGPIN; ASAP

AA = African American; ASAP = atypical small acinar proliferation; BPH = benign prostatic hyperplasia; DRE = digital rectal exam; HGPIN = high-grade prostatic intraepithelial neoplasia; sd = standard deviation; tPSA = total prostate specific antigenNR = not reported; P = prostatectomy

a Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Rows 3, 8, 11, and 21-23 are shaded.

Table 4 PCA3/DD3 assay characteristics

Author^a^, Year | Attentive Massage Used | Specimen | Method Used | Assay Specified | Reporting Units | House-keeping Gene | Handling Temperatures Holding (C); Storage (C) | Informative Results %
Adam90, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 98
Aubin91, 2010 | Yes | UU | TMA | “Gen-Probe” | PCA3 Score | PSA | NR; -70 | 94
Auprich92, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | NR
Auprich112, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 100
Bollito93, 2012 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 96
de la Taille95, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 99
Deras96, 2008 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR; -70 | 100
FDA Summary Document97, 2012 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 93
Feero98, 2012 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | NR
Goode99, 2012 | Yes | UU | TMA | Progensa reagents by Bostwick | PCA3 Score | PSA | NR | 100
Hessels100, 2010 | Yes | US | TMA | Aptima | PCA3 Score | PSA | NR | 96
Liss114, 2011 | Yes | UU | TMA | NR | PCA3 Score | PSA | 2-8; NR | 100
Nakanishi115, 2008 | Yes | UU | TMA | “Gen-Probe” | PCA3 Score | PSA | 2-8; -70 | 100
Nyberg102, 2010 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 100
Ochiai103, 2011 | Yes | UU | TMA | Aptima | PCA3 Score | PSA | NR; -70 | 100
Perdona31, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 100
Ploussard116, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | NR
Roobol108, 2010 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 100
Schilling109, 2010 | Yes | UU | TMA | “Gen-Probe” | PCA3 Score | PSA | NR | 99
Tosoian89, 2010 | Yes | UU | TMA | Aptima | PCA3 Score | PSA | NR; -80 | 98
Vlaeminck-Guillem118, 2011 | Yes | UU | TMA | Progensa | PCA3 Score | PSA | NR | 100
Wang110, 2009 | Yes | UU | TMA | “Gen-Probe” | PCA3 Score | PSA | 30; NR | 97
Whitman119, 2008 | Yes | UU | TMA | “Gen-Probe” | PCA3 Score | PSA | NR | 100
Fradet85, 2004 | Yes | UU | NASBA | uPM3 | Probability | PSA | NR; 2-8 | 86
Tinzl86, 2004 | Yes | UU | NASBA | uPM3 | PCA3 Score | PSA | 4; -20 | 79
Wu111, 2012 | Yes | UU | TMA | PCA3Plus by Bostwick | PCA3 Score | PSA | NR | NR
Cao94, 2011 | Yes | US | QRT-PCR | NR | PCA3 Score | PSA | 4; -20 | 92
Kusuda88, 2011 | NR | LN | QRT-PCR | NR | Quantification | GADPH | NR | NR
Mearini101, 2009 | Yes | US | QRT-PCR | NR | Quantification | Beta actin | NR -70 | NR
Ouyang104, 2009 | Yes | US | QRT-PCR | NR | PCA3 Score | GADPH | NR; -80 | 87
Rigau107, 2010 | Yes | US | QRT-PCR | NR | PCA3 Score | PSA | NR; -80 | 82
Ankerst65, 2008 | NR | NR | NR | NR^b^ | PCA3 Score | PSA | NR | NR
Ploussard106, 2010 | NR | UU | NR | NR^c^ | PCA3 Score | PSA | NR | NR

LN = lymph node tissue; NASBA = nucleic acid sequence-based amplification; NR = not reported; QRTPCR = quantitative real time polymerase chain reaction; TMA = transcription-mediated amplification; U = urine unsedimented; US = urine sedimented.

a Studies are in alphabetical order by methodology.

b Ankerst analyzed data from a study concurrently reported by Haese et al., 2008^82^. Haese indicated that PCA3 testing was done using Progensa.

c This paper did not specify the PCA3 assay used, but two authors (van Poppel, de la Taille) disclosed an advisor and investigator relationship with GenProbe, making it likely that Progensa was the assay used.

Table 17 Characteristics of matched studies addressing KQ3 with biopsy and prostatectomy results

Author, Year | Biopsy GS, % | Clinical Stage,% | Number of P | P Gleason Scores, % | Pathologic Stage, % | “Low Risk” Prostate Cancer Category, % | Conclusions – PCA3:
Auprich, 2011^112^ | <7, 50.8 ≥7, 49.2 | - | 305 | < 7, 27.9 ≥ 7, 72.1 | NR | Insignificant^a^, 10 | Median scores lower with low TV and insignificant PrC^b^ (p<0.001); improves multivariate AUC
Cao, 2011^94^ | ≤ 6, 50 = 7, 38 ≥ 8, 12 | ≤T2a, 25; T2b, 52; T3, 23 | - | - | - | Low risk^b^, 8.1 | Has significant correlation with low risk group; no RP
de la Taille, 2011^95^ | < 6, 1 = 6, 52 = 7, 42 > 7, 5 | T1c, 86; T2, 13; T3, 1 | - | - | - | Indolent^c^, 25 | Median scores higher with GS ≥7, % positive cores > 33%, and significant PrC; no RP
Durand, 2012^113^ | = 6, 43.1 = 7, 50.6 > 7, 6.3 | T1a/b, 0.6 T1c, 81.8 T2, 18.2 | 160 | = 6, 43.1 = 7, 50.6 ≥ 8, 6.3 | ≤ pT2, 70.6 pT3, 27.5 pT4, 1.9 | NR | Score >35 correlates with (r=0.34, p < 0.01) and predicts (OR 2.7;p=0.04) TV; predicts positive surgical margins (OR 2.4, p=0.04) and GS >6 (p<0.001)
Hessels, 2010^100^ | ≤ 6, 74.3 = 7, 22.9 ≥ 7, 2.8 | NR | 70 | <7, 43 ≥7, 57 | pT2, 59.0 p T3, 42.0 | Indolent^d^ / Insignificant, 8.5 | Predictive value for aggressiveness features not confirmed in this study
Kusuda, 2011^88^ | - | - | 120 | ≤ 6, 56.7 = 7, 33.3 ≥ 8, 10.0 | pT2, 55.8 pT3, 42.5 pT4, 1.7 | NR | PCA3 expression in LN tissue can predict biochemical recurrence-free survival after prostatectomy
Liss, 2011^114^ | ≤ 6, 53.1 > 6, 47.9 | NR | 98 | ≤ 6, 29.9 > 6, 71.1 | pT2, 77.3 pT3a, 16.5 ≥pT3b, 6.2 | NR | Association with PNI (p=0.05), not pathological stage, GS > 6, or EPE
Nakanishi, 2008^115^ | = 6, 40.6 = 7, 53.1 = 8, 6.3 | T1c, 70.8 ≥ T2, 29.2 | 96 | = 6, 15.6 = 7, 77.1 = 8, 3.1 = 9, 4.2 | pT2, 82.3 pT3a, 10.4 pT3b, 7.3 | Low volume / low grade^e^, 11 | Median scores higher for low volume/low grade vs. significant PCa (p=0.007); correlation with TV (p=0.01)
Ploussard, 2011^116^ | = 6, 100 | | 106 | = 6, 58.4 = 7, 41.6 | ≤ pT2, 76.4 pT3, 23.6 | Low risk cohort^f^ in active surveillance | Correlates with (r=0.41, p<0.001) and at > 25 predicts (p=0.01) TV and insignificant PrC (p=0.02)
Tosoian, 2010^89^ | < 7, 57.9 ≥ 7, 42.0 | NR | - | - | - | Low risk^g^ PrC patients in active surveillance | Score was not significantly associated with short-term biopsy progression.
van Poppel, 2011^117^ | ≤ 6, 53 = 7, 43 > 7, 4 | T1c, 79 T2-T2c, 21 T3a, 1 | 175 | < 7, 32.1 ≥ 7, 67.9 | T2a-c, 78.6 T3a-b, 21.4 | Indolent^h^, 21.7 | Median scores lower with GS <7 (p<0.001) and stage pT2a-pT2c (p=0.01)
Vlaeminck-Guillem, 2011^118^ | = 6, 47 = 7, 45 = 8/9, 8 | T1, 84 T2, 16 | 102 | NR | NR | Low volume / low grade^j^, 8.2 | Score correlated with TV (p< 0.001), multifocality (p = 0.012), and apical / basal invasion (p<0.05)
Whitman, 2008^119^ | = 6, 69.4 = 7, 20.8 = 8/9, 9.7 | T1, 71.2 T2, 28.8 | 72 | = 6, 58.3 = 7, 31.9 = 8/9, 9.7 | pT2, 70.9 pT3a, 20.8 pT3b, 8.3 | - | Correlated with TV (r=0.38, p < 0.01) and was an independent predictor of TV <0.05 (p=0.04) and ECE (p=0.01); improves multivariate AUC

AUC = area under the curve; ECE = extracapsular extension; GS = Gleason score; LN = lymph node; NR = not reported; P = prostatectomy; PCA3 = prostate cancer antigen 3 gene; PNI = perineural invasion;

SVI = seminal vesicle invasion; TV = tumor volume

a Defined by Epstein criteria: organ confined, tumor volume less than 0.5 cc, absence of Gleason grade 4 or 5.

b Defined as tPSA ≤ 10 ng/mL, GS ≤ 6, clinical stage ≤ T2a.

c Defined by Epstein criteria: stage T1c, PSAD < 0.15 ng/mL, biopsy GS ≤ 6, percent positive cores ≤ 33%.

d Defined as organ confined, TV < 0.5 mL and absence of Gleason grad 4 or 5 disease.

e Defined as organ confined, dominant tumor volume less than 0.5 cc, and absence of Gleason grade 4 or 5.

f Defined as tPSA ≤ 10, clinical stage T1c-T2a, GS 6 prior to radical prostatectomy.

f Defined by Epstein criteria: stage T1c, PSAD < 0.15, biopsy GS ≤ 6, ≤ 2 positive cores, and no more than 50% involvement of any one core.

h Defined by Epstein criteria: stage T1c, PSAD < 0.15 ng/mL, biopsy GS ≤ 6, percent positive cores ≤ 33%.

Organ confined cancer (pT2 or less) with a total tumor volume of less than 0.5 ml, and absence of Gleason grade 4 or 5 disease (contemporary Epstein criteria).

Table 18 Comparators investigated with PCA3 scores in matched studies addressing KQ 3

Numbers of Subjects and Reported Comparators | Auprich 2011^112^ | Cao 2010^94^ | de la Taille 2011^95^ | Durand 2012^113^ | Hessels 2010 100 | Kusuda 2011 88 | Liss 2011^114^ | Nakanishi 2008^115^ | Ploussard 2011^116^ | Tosoian 2010^89^ | van Poppel 2011^117^ | Vlaeminck-Guillem 2011^118^ | Whitman 2008^119^
No. of biopsy patients | - | 131 | 515 | - | 336 | - | - | - | - | 294 | 348 | - | -
No. of prostatectomy patients | 305 | - | - | 160 | 70 | 120 | 98 | 96 | 106 | - | 175 | 102 | 72
Biomarkers | - | - | %fPSA, PSAD | - | - | - | PSAD | - | %fPSA, PSAD | - | %fPSA, PSAD | %fPSA | -
Biopsy: Gleason score | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Biopsy: Clinical stage | No | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | Yes | Yes | Yes
Biopsy: Localized/organ confined PCa | Yes | NR | NR | Yes | NR | Yes | Yes | NR | Yes^d^ | Yes^f^ | NR | NR | NR
Biopsy: Percent tumor positive cores | Yes | No | Yes | Yes | No | No | No | Yes | Yes | No | Yes | No | No
Biopsy: Percent tumor per core | No | No | No | No | No | No | No | No | Yes | No | No | No | No
Biopsy: Prostate volume | Yes | Yes | Yes | No | Yes | No | No | Yes | Yes | No | Yes | Yes | No
Prostatectomy: Gleason score | Yes | NA | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes
Prostatectomy: Pathological stage | No | NA | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes
Prostatectomy: Tumor volume | Yes | NA | No | Yes | Yes | Yes | No | Yes | Yes | No | No | Yes | Yes
Prostatectomy: Multifocality | No | NA | NA | No | No | No | No | No | No | No | No | Yes | No
Prostatectomy: Extracapsular extension | Yes | NA | NA | No | No | No | Yes | No | No | No | No | No | Yes
Prostatectomy: Seminal vesicle invasion | Yes | NA | NA | No | No | No | No | No | No | No | No | No | No
Prostatectomy: Perineural invasion | No | NA | NA | No | No | No | Yes | No | No | No | No | Yes | No
Prostatectomy: Surgical margin status | No | NA | NA | Yes | No | Yes | No | No | No | No | No | Yes | No
Risk criteria: Epstein | Mod^a^ | No | No | No | No | No | No | No | Yes^e^ | Yes^f^ | Yes^g^ | No | No
Risk criteria: Other (see footnote) | No | Yes^b^ | No | No | Yes^c^ | No | No | No | No | No | No | Yes^h^ | No
Lymph node mRNA expression | NA | NA | NA | NA | NA | Yes^i^ | NA | NA | NA | NA | NA | NA | NA
PCa progression | No | No | No | No | No | Yes^i^ | No | No | No | Yes^j^ | No | No

%fPSA = percent free prostate specific antigen; Mod = modified Epstein criteria; NA = not applicable; NR = not reported; PCa = prostate cancer; PSAD = total prostate specific antigen density; RP = radical prostatectomy; TV = tumor volume

a Insignificant PCa = organ-confined PCa, TV < 0.5 mL, GS < 7.

b Low risk PCa = tPSA ≤ 10 ng/mL, GS ≤ 6, clinical stage ≤ T2a; high risk PCa = tPSA >20, GS ≥ 8, clinical stage ≥ T3a.

c Insignificant PCa = low tumor volume/low grade.

d Study enrolled only patients with “low risk” PCa, defined as tPSA ≤ 10 ng/mL, clinical stage T1c-T2a and biopsy GS = 6.

e Insignificant PCa = organ-confined, no Gleason pattern 4 or 5, TV < 0.5 mL.

f Study enrollment criteria were based on the Epstein criteria: clinical stage T1c, PSA density < 0.15 ng/mL/cm^3^, GS ≤ 6, 2 or less biopsy cores with cancer and maximum 50% involvement in any one core.

g Indolent PCa = clinical stage T1c, PSA density < 0.15, biopsy GS ≤ 6, % positive cores ≤ 33%.

h Significant PCa = RP GS ≥ 7, pathological stage pT3 or greater, TV ≥ 0.5 mL.

i Biochemical recurrence based on lymph node metastasis identified by PCA3 RNA expression in lymph node tissue.

j Progression to treatment in an active surveillance program, defined by surveillance biopsy with any Gleason pattern 4 or 5, >2 positive cores, or more than 50% involvement of any core with cancer.

### Grey Literature Search

The process for evaluation of grey literature search results is summarized in Figure 4 and Appendix C. Two clinical trial registry citations were potentially relevant to the review:

- Prostate Cancer Antigen 3 (PCA-3) Gene Project (NCT01177436) – The status of this trial is unclear (last update August, 2010). Of interest was the use of three housekeeping genes for PCA3 testing in addition to KLK3 (PSA): ACTB (beta-actin), TUA (Ka 1 tubulin), and GAPDH (glyceraldehyde-3-phosphate). Results may resolve remaining concerns about potential bias related to the use of KLK3 as the housekeeping gene.
- Clinical Evaluation of the Progensa^®^ PCA3 Assay in Men With a Previous Negative Biopsy Result (NCT01024959) – This trial, conducted by GenProbe and completed in April, 2011, provided data for the premarket (PMA) submission to FDA that was approved. However, the published article reporting the results of this clinical trial was not available for review.

Figure 4 PRISMA diagram for identified grey literature

ACMG = American College of Medical Genetics; AHRQ = Agency for Healthcare Research and Quality; AMP = Association for Molecular Pathology; ASCO = American Society of Clinical Oncology; AUA = American Urological Association; CADTH = Canadian Agency for Drugs and Technologies in Health; CAP = College of American Pathologists; EuNetHTA = European Network for Health Technology Assessment; FDA = U.S. Food and Drug Administration; HSRPROJ = Health Services Research Projects in Progress; NCCN = National Cancer Consortium Network; NICE = U.K. National Institute for Health and Clinical Excellence; PCRI = Prostate Cancer Research Institute; RePORTER = National Institutes of Health Research Portfolio Online Reporting Tools Expenditures and Results tool; UK HTA = United Kingdom Health Technology Assessment Programme; WHO = World Health Organization

Figure 4 is a PRISMA diagram illustrating the review of articles identified via grey literature search for this systematic review. For regulatory information, the U.S. Food and Drug Administration (FDA) website was searched for PMA or 510(k) summaries for commercially FDA approved diagnostic tests for PCA3. No documents were identified. ClinicalTrials.gov was searched. Six studies were identified but all were excluded (4 met exclusion criterion, 1 was an incomplete trial, and 1 was an unpublished trial). The World Health Organization web site was searched and no studies were identified. Conference abstracts and papers from 7 professional societies were searched. These included the College of American Pathologists, the American Urological Association, the American Society of Clinical Oncology, the American College of Medical Genetics, the Association of Molecular Pathology, the NCCN Annual Congress, and PCRI. The search of these sources yielded 272 citations. All of these met exclusion criteria (255 with title and abstract screen and 17 with full text review). Three sources for grants and federally funded projects were searched. The first was NIH RePORTER, which is a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions. The second was HSRPROJ, which is a database providing access to ongoing grants and contracts in health services research. The third was AHRQ GOLD, which is an online searchable database of AHRQ grants, working papers and HHS recovery act projects. The search of all 3 databases yielded 26 citations. Twenty were excluded on title and abstract screen, 5 on full text review. Following full text review one article was included in this report. Searches were performed for seven organizations publishing guidance and review documents (ANZHTA, CADTH, Cochrane, EuNetHTA, EuroGENTest, Nat. Guidelines Clearinghouse, NNICE, and UK HTA). Ninety eight documents were identified; all met exclusion criterion during title and abstract screen. Finally a single manufacturer provided a scientific information packet or SIP. This packet included 24 citations: 6 excluded during title and abstract review and 18 excluded following full text review.

Overall, the search of grey literature yielded one study, reported in the FDA Summary of Safety and Effectiveness Data for Gen-Probe's PROGENSA^®^ PCA3 Assay (PMA P100033).

## Potential Biases in Included Studies

The populations in the included studies were largely drawn from academic medical centers where patients with elevated tPSA results and/or other risk factors (e.g., positive DRE, family history, African American race) were seeking referral or specialty care. Observational studies of such opportunistic cohorts are subject to specific biases.

### Verification Bias

Men will be offered prostate biopsy based on the extent of tPSA elevations, suspicious findings on a digital rectal exam (DRE), a combination of the two or, less commonly, other risk factors such as family history or race. In order to obtain an unbiased estimate of diagnostic accuracy for tPSA at specific cutoffs, it is necessary that the identification of prostate cancer not be related to tPSA levels. This is a potential problem as studies have shown that higher tPSA levels are indicative of a higher likelihood for the presence of prostate cancer. Men are more likely to undergo prostate biopsy, if the tPSA is high (e.g., 10-20 ng/mL), rather than close to lower cutoffs used to define a positive tPSA screening test (e.g., 3-4 ng/mL). If a study reports results in which biopsy is tPSA-related, the sensitivity and specificity at select tPSA cutoffs will not be accurate. If those not accepting biopsy are considered missing, this is considered “partial verification” bias. All studies included in the evidence review are opportunistic cohorts of men agreeing to biopsy, and will be subject to this bias. However, no study addressed this potential bias. We addressed this bias through modeling the effect of verification bias on the tPSA measurements. A detailed discussion of this bias and the modeling performed can be found in Appendix J.

### Spectrum Bias

Spectrum effects should also be considered when evaluating diagnostic tests generated from convenience samples collected at referral centers. For example, such studies are likely to represent men at higher risk of prostate cancer than in the total cohort of screened men, and might be at higher risk of more aggressive cancers as well (e.g., those with rapid rise in PSA). The positive biopsy rate in such referral populations will depend on multiple factors, including the tPSA cutoff, the number of men with elevated tPSA who opt out of biopsy (e.g., men with lower tPSA levels and lower risk), and/or the proportions of men with other important risk factors. In 17 included studies, biopsy positive rates ranged from 16.9 to 72.9 percent, with a median of 36 percent. Although this may not influence the clinical sensitivity and specificity estimates it certainly will influence the positive and negative predictive values (as the disease prevalence varies).

A second spectrum effect of more concern relates to the range of severity of disease between those identified with an elevated PCA3 score compared with those with a positive comparator test. For example, suppose two tests have the same sensitivity and specificity estimated in a cohort of biopsied men. In order to show the true clinical validity, it would be necessary to examine the men with positive biopsies having discordant test results (i.e., positive by one test but negative by the other). If the men positive by one test have similar tumor characteristics and/or severity of disease to those positive by the other test, then the sensitivity/specificity estimates could be both statistically and clinically equivalent. However, if one test identifies a difference in tumor characteristics and/or severity of disease that the other test does not, the estimates could be statistically equivalent but clinically different.

### Sampling Bias

Analysis of tPSA (and related comparators) was also subject to a sampling bias. A subset of studies restricted enrollment to tPSA results in the “grey zone” (e.g., 2.5 ng/mL to less than 10 ng/mL). The impact of this restriction would be to reduce the prevalence of disease in the study group, as there is a positive correlation between tPSA and prevalence of prostate cancer. In addition this would also reduce the tPSA test performance (sensitivity/specificity) as those men with higher tPSA levels are not enrolled in the study. It is at the higher tPSA levels that the test is most predictive. This would reduce the apparent performance of tPSA measurements, and increase the difference between the PCA3 and tPSA performance estimates. Overall, this bias reduces the external validity (generalizability) of studies in a general population. This bias cannot be avoided by statistical analysis. These studies could be removed from consideration. Instead, we have chosen to address this bias by stratifying analyses by selection criteria. That is, studies of the “grey zone” were summarized separately from the studies that include all levels of elevated tPSA.

## Analyses Relating to KQs 1 and 2

### KQ 1 Testing PCA3 and Comparators To Identify Prostate Cancer in Men Having an Initial Biopsy

Among the 17 studies addressing KQ 1 (Table 1), only two reported results in populations where all men were having initial biopsies (Table 5).95,98 Both studies reported data on tPSA and %fPSA; one95 also reported on PSA density. The actual data will be presented in later analyses (KQ 1/KQ 2 combined), but there were too few data for reliable interpretations. The five matched analyses performed (see Table 5 footnote a) are outlined in Methods, and discussed in detail as part of the analyses.

Table 5 Summary of matched analyses (of five)^a^ that can be performed for each PCA3 comparator, with analysis restricted to studies only on initial biopsies

Study Author^b^, Year | N | Initial Biopsy | tPSA | %fPSA | PSA Velocity | PSA Density | cPSA | Validated Nomogram
de la Taille95, 2011 | 516 | 100% | A,C,D,E | C,D,E | - | A,C,D | - | -
Ferro98, 2012 | 151 | 100% | B | A,D | - | - | - | -
All | 667

%fPSA = percent free prostate specific antigen; cPSA = complexed prostate specific antigen; N = number; tPSA = total prostate specific antigen

The dash (‘-’) indicates no data provided for that comparator.

a The letters ‘A’ through ‘E’ represent the analyses: A = AUC, B = Mean/median values, C = PCA3 > 35, D = Sensitivity/Specificity and E = Regression.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Both rows are shaded.

#### Strength of Evidence

When data were restricted to the two studies reporting only on populations of men having an initial prostate biopsy, only one comparison could be made, the D analysis for %fPSA. Both studies were poor quality. It is not possible to evaluate consistency (between-study results). In addition, estimates of effect size will be imprecise. This results in assigning grades of “insufficient” for the reported comparisons of PCA3 with tPSA, %fPSA, and PSA density, and other comparators (PSA velocity, complexed PSA and externally validated nomograms) with no matched studies.

### KQ 2 Testing PCA3 and Comparators in Men Having Repeat Biopsy

Among the 21 studies addressing KQ 2 (Table 1, Table 2b), seven65,91,92,97,105,106,111 reported results in populations where all of the men were having a repeat biopsy (Table 6). Studies are ranked by number of patients enrolled. Five studies reported on tPSA,65,91,92,106,111 four on %fPSA91,92,105,106 and two on externally validated nomograms.65,97 All studies were poor quality. The actual data were included in later analyses, but there were too few data for any one analysis to provide reliable interpretations.

Table 6 Summary of matched analyses (of five)^a^ that can be performed for each PCA3 comparator, with analysis restricted to studies reporting results only in repeat biopsy

Study Author^b^, Year | N | Initial Biopsy | tPSA | %fPSA | PSA Velocity | PSA Density | cPSA | Validated Nomogram
Pepe105, 2012 | 74 | 0% | - | B^a^ | - | - | - | -
Wu111, 2012 | 103 | 0% | A,D | - | - | C | - | -
Auprich92, 2011 | 127 | 0% | A,B | B,D | B,D | - | - | -
Ploussard106, 2010 | 301 | 0% | A,D | A,D | - | - | - | -
Ankerst65, 2008 | 443 | 0% | A,B,D | - | - | - | - | A
FDA Summary97, 2012 | 466 | 0% | - | - | - | - | - | A,E
Aubin91, 2010 | 1,072 | 0% | C,D | A,D | - | - | - | -
All | 2,586

%fPSA = % free prostate specific antigen; cPSA = complexed prostate specific antigen; FDA = U.S. Food and Drug Administration; N = number; tPSA = total prostate specific antigen

A dash (‘-’) indicates no data provided for that comparator.

a The letters ‘A’ through ‘E’ represent the analyses: A = AUC, B = mean/sd, C = PCA3 > 35, D = Sensitivity/Specificity and E = Regression.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Rows 1, 4, and 7 are shaded.

#### Strength of Evidence

When data were restricted to these seven studies, the number of comparisons possible for each matched analysis remained small due to three “grey zone” studies.91,105,106 For example, the “D” analysis for tPSA has three sets of data, but two are for all levels of tPSA and one is restricted to the “grey zone.” All studies were poor quality. Due to these differences in inclusion criteria, it is difficult to evaluate consistency. Estimates of effect size will, necessarily, also be imprecise. Strength of evidence was deemed insufficient for all comparisons of PCA3 with tPSA, %fPSA, PSA velocity, PSA density, complexed PSA and externally validated nomograms in this population of men.

### Potential To Combine KQs 1 and 2: Testing PCA3 and Comparators in Men Having Initial or Repeat Biopsy

The sections above addressed the nine studies that exclusively studied men having an initial (KQ 1) or repeat biopsy (KQ 2). However, 15 additional studies included matched results of PCA3 and the comparators (Table 7). Eleven reported the proportion of men having initial and repeat biopsies,31,90,93,96,99,102,103,107-110 but four did not report biopsy history.94,100,101,104 The results from these studies were most often not stratified by biopsy history.

Table 7 Summary of matched analyses (of five)^a^ that can be performed for each PCA3 comparator, with analysis restricted to studies on initial and repeat biopsies

Author Study^b^, Year | N | Initial Biopsy | tPSA | %fPSA | PSA Velocity | PSA Density | cPSA | Validated Nomogram
Pepe105, 2012 | 74 | 0% | - | B^a^ | - | - | - | -
Wu111, 2012 | 103 | 0% | A,D | - | - | A,C,D | - | -
Auprich92, 2011 | 127 | 0% | A,B | A,B | A,B | - | - | -
Ploussard106, 2010 | 301 | 0% | A,D | A,D | - | - | - | -
Ankerst65, 2008 | 443 | 0% | A,B,D | - | - | - | - | A
FDA Summary97, 2012 | 446 | 0% | - | - | - | - | - | A,E
Aubin91, 2010 | 1,072 | 0% | C,D | A,D,E | - | - | - | -
Deras96,2008 | 557 | 51% | A,C,D | - | - | - | - | -
Nyberg102, 2010 | 62 | 55% | A,B,C,D | - | - | - | - | -
Bollito93, 2012 | 1246 | 59% | A,B,D | A,B,D | - | - | - | -
Perdona31, 2011 | 218 | 61% | A,B,D,E | B,E | - | - | - | A,B,D
Goode99, 2012 | 456 | 63% | A,C,D | - | - | D | - | -
Roobol108, 2010 | 721 | 71% | A | - | - | - | - | -
Wang110, 2009 | 181 | 73% | C | - | - | - | - | -
Rigau^107^2010 | 215 | 74% | A,D | - | - | - | - | -
Ochiai103, 2011 | 105 | 81% | A,B,C,D | - | - | A,B,D | - | D
Adam90, 2011 | 105 | 82% | A,C,D | - | - | - | - | -
Schilling109, 2010 | 32 | 86% | A,C,D | - | - | - | - | -
Ferro98, 2012 | 151 | 100% | B | A,D | - | - | - | -
de la Taille95, 2011 | 516 | 100% | A,C,D,E | C,D,E | - | A,C,D | - | -
Ouyang, 2009^104^ | 92 | - | A | - | - | - | - | -
Mearini101, 2009 | 96 | - | A | - | - | - | - | -
Cao94, 2011 | 131 | - | A | - | - | - | - | -
Hessels100, 2010 | 336 | - | A | - | - | - | - | -

%fPSA = % free prostate specific antigen; cPSA = complexed prostate specific antigen; N = number; tPSA = total prostate specific antigen

A dash (‘-’) indicates no data provided for that comparator.

a The letters ‘A’ through ‘E’ represent the analyses: A = AUC, B = mean/sd, C = PCA3 > 35, D = Sensitivity/Specificity and E = Regression.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (2.5-10 ng/mL) when enrolling patients. Rows 1, 4, 7, 11, 19, and 20 are shaded.

At this point, one could have ignored the data in these 15 additional studies, as they did not directly apply to either KQ 1 or KQ 2. Instead, based on the inadequate strength of evidence found for the prior individual analyses that focused on only those men with initial or with repeat biopsies, we chose to examine whether data from the studies that could be stratified by biopsy history might be suitable for a combined analysis (Table 7). Prior to performing this combined analysis, however, it was necessary to determine whether biopsy status was an important covariate that could bias the findings. An examination of Table 7 found that the most common comparator was tPSA, and the most common analysis, by far, was the area under the curve (AUC), indicated by an “A.”

Fifteen of the 19 studies that reported AUC results for both PCA3 and tPSA also provided the proportion of study subjects with no previous prostate biopsies. A regression analysis of AUC difference (PCA3 – tPSA) versus the proportion of men with an initial biopsy would provide evidence regarding suitability of the combined analysis. The raw data for this figure can be found in Table 10.

Table 10 Comparing PCA3 scores and tPSA elevations in matched studies via AUC analysis

Table 10a Results from 20 matched studies reporting results for all study subjects^a^

Author Study^b^, Year | Number | Initial Bx | PCA3 AUC | tPSA AUC | Difference | P-value^c^
Adam90, 2011 | 105 | 82% | 0.7054 | 0.8443 | -0.1389 | -
Nyberg102, 2010 | 62 | 55% | 0.7418 | 0.7961 | -0.0543 | 0.07
Aubin91, 2010 | 1,072 | 0% | 0.6430 | 0.6120 | 0.0310
Roobol108, 2010 | 721 | 71% | 0.6350 | 0.5810 | 0.0540 | 0.14
Ankerst65, 2008 | 443 | 0% | 0.6650 | 0.6070 | 0.0580 | >0.05
Rigau107, 2010 | 215 | 74% | 0.6600 | 0.6020 | 0.0580 | -
Hessels100, 2010 | 336 | - | 0.7200 | 0.6500 | 0.0700 | -
Wu111, 2012 | 103 | 0% | 0.6400 | 0.5700 | 0.0700
Ouyang104, 2009 | 92 | - | 0.6700 | 0.5900 | 0.0800 | -
Bollito93, 2012 | 1246 | 59% | 0.6780 | 0.5850 | 0.0930
Mearini101, 2009 | 96 | - | 0.8140 | 0.6960 | 0.1180 | <0.05
Ochiai103, 2011 | 105 | 81% | 0.8507 | 0.7243 | 0.1264 | 0.025
Ploussard106, 2010 | 301 | 0% | 0.6880 | 0.5530 | 0.1350 | -
Auprich92,2011 | 127 | 0% | 0.7030 | 0.5680 | 0.1350 | -
Deras96, 2008 | 557 | 50% | 0.6860 | 0.5470 | 0.1390 | -
Cao94, 2011 | 131 | - | 0.7390 | 0.5660 | 0.1730 | -
de la Taille95, 2011 | 516 | 100% | 0.7610 | 0.5770 | 0.1840 | <0.001
Perdona31, 2011 | 218 | 61% | 0.8280 | 0.6360 | 0.1920 | <0.001
Schilling109, 2010 | 32 | 56% | 0.8100 | 0.6100 | 0.2000 | -
Goode99, 2012 | 456 | 63% | 0.7260 | 0.5110 | 0.2150 | <0.001
Median Difference (all data, N=20) | 6,934 | | | | 0.1055
Median Difference (only “grey zone” studies; N=4) | 2,107 | | | | 0.1595
Median Difference (excluding “grey zone” studies; N=16) | 4,827 | | | | 0.0865

AUC = area under the curve; Bx = biopsy; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

A dash (‘-‘) = no value reported.

a Comparisons of difference for Figure 5A were between all reported subjects, regardless of repeat/initial biopsy status.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (2.5-10 ng/mL) when enrolling patients. In Table 10a, rows 3, 13, 17, and 18 are shaded.

c Reported p-value for the comparison of the two AUCs computed among the same set of men.

Table 10b Results from three matched studies reporting results stratified by biopsy status^a^

Author Study^b^, Year | Number | Initial Bx | PCA3 AUC | tPSA AUC | Difference | P-value^c^
Bollito93, 2012 | 511 | 0% | 0.7840 | 0.5530 | 0.2310 | -
Bollito93, 2012 | 735 | 100% | 0.6140 | 0.6130 | 0.0010 | -
Goode99, 2012 | 169 | 0% | 0.6050 | 0.5000 | 0.1050 | -
Goode99, 2012 | 287 | 100% | 0.7720 | 0.5520 | 0.2200 | -
Perdona31, 2011 | 85 | 0% | 0.7480 | 0.5960 | 0.1520 | -
Perdona31, 2011 | 133 | 100% | 0.8730 | 0.6600 | 0.2130 | -

AUC = area under the curve; Bx = biopsy; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

A dash (‘-‘) = no value reported.

a Comparisons of difference for Figure 5B replaced composite proportions for four studies with results from initial and repeat biopsy subgroups

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (2.5-10 ng/mL) when enrolling patients. In Table 10b, rows 5 and 6 are shaded.

c Reported p-value for the comparison of the two AUCs computed among the same set of men.

Figure 5A shows the analysis. Based on linear regression, the slope (-0.00227) was not significant (p=0.97), indicating that there was no significant relationship between the biopsy status and AUC difference for PCA3 versus tPSA elevations. In addition, a subset of three of the 15 studies reported AUCs stratified by initial and repeat biopsy status (Table 10). Figure 5B shows the analysis with the replacement of the three “composite” AUCs with initial and repeat biopsy subgroup AUCs. The slope (-0.01307) was also not significant (p=0.81).

Figure 5 Scatterplots showing the relationship between the proportion of men with an initial biopsy versus the differences in the area under the curves (AUC) for PCA3 scores versus tPSA elevations

AUC = area under the curve; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: The horizontal axis shows the proportion of men with an initial biopsy (range 0 to 100%). The vertical axis shows the AUC Difference (AUC_PCA3_ – AUC_tPSA_); a value of 0 (dashed horizontal line) indicates the two AUCs are equivalent. Each circle indicates the results from one included study. Results from studies reporting only on the “grey zone” (e.g., tPSA results 2.5-10 ng/mL) are filled. Figure 5A shows studies providing the proportion of men with initial biopsies as presented in Tables 5 and 7. There is no significant relationship, as indicated by the solid line and 95% CI. Figure 5B draws data from the same studies, but includes data for the initial and repeat biopsy groups from three studies31,93,99 summarized as composite data in Figure 5A. There is still no significant relationship. The most outlying study had a negative AUC difference and reported data from a 69% black South African study (82% initial biopsy).90

Figure 5a examines the relationship between effect size (AUC difference) and biopsy status. The X axis defines the proportion of initial biopsy in % and ranges from 0 to 100%. The Y axis defines the AUC difference calculated by subtracting tPSA from PCA3. A solid regression line with 95% prediction limits shown as dashed lines is superimposed on the matched points. Figure 5b draws data from the same studies as 5A but showss the analysiswith the replacement of the three “composite” AUCS with initial and repeat biopsy subgroup AUCs.

Examining Table 7 also indicated that 14 studies (16 datasets) reported the ROC curves for both PCA3 and tPSA. A regression analysis of (PCA3 – tPSA) sensitivities at a constant specificity of 50 percent versus the proportion of men with an initial biopsy would also provide evidence regarding the suitability of the combined analysis. The raw data for this figure can be found in Table 13. Figure 6 shows the described analysis. Based on linear regression, the slope (0.02956) is not significant (p=0.79). Again, there appears to be little or no association between the biopsy history and the relative performance of PCA3 and tPSA.

Table 13 Differences in PCA3 and tPSA sensitivities (difference)^a^ at PCA3 false positive (1-specificity) rates from 20% to 80%

Study Author^b^ | N | % Initial Bx | 20% | 30% | 40% | 50% | 60% | 70% | 80%
Schilling109 | 32 | 56 | 57 (19) | 71 (29) | 90 (45) | 95 (39) | 95 (17) | 100 (6) | 100 (6)
Nyberg102 | 62 | 55 | 50 (-11) | 61 (-11) | 73 (-4) | 89 (0) | 94 (-3) | 94 (-6) | 94 (-6)
Wu111 | 103 | 0 | 37 (13) | 45 (5) | 67 (27) | 77 (35) | 82 (29) | 82 (9) | 82 (-2)
Adam90 | 105 | 82 | 50 (-19) | 68 (-7) | 75 (0) | 78 (-9) | 78 (-13) | 80 (-18) | 90 (-10)
Ochiai103 | 105 | 81 | 74 (23) | 87 (30) | 92 (20) | 97 (7) | 98 (9) | 100 (8) | 100 (8)
Goode99 (repeat) | 167 | 0 | 34 (13) | 43 (11) | 56 (24) | 73 (26) | 79 (14) | 85 (15) | 90 (5)
Rigau107 | 215 | 74 | 32 (-2) | 57 (15) | 64 (14) | 77 (11) | 84 (11) | 87 (9) | 93 (10)
Perdona31 | 218 | 61 | 70 (24) | 79 (21) | 82 (21) | 88 (25) | 97 (20) | 100 (17) | 100 (12)
Goode99 (initial) | 289 | 100 | 60 (37) | 77 (44) | 82 (43) | 82 (24) | 88 (33) | 95 (19) | 98 (3)
Ploussard106 | 301 | 0 | 40 (12) | 56 (21) | 71 (25) | 80 (21) | 83 (13) | 89 (11) | 93 (11)
Ankerst65 | 443 | 0 | 38 (-1) | 51 (3) | 67 (9) | 76 (11) | 83 (9) | 88 (7) | 95 (9)
Bollito93 (repeat) | 509 | 0 | 69 (42) | 76 (31) | 81 (31) | 86 (29) | 91 (22) | 91 (15) | 93 (8)
de la Taille95 | 516 | 100 | 57 (27) | 71 (29) | 77 (27) | 85 (26) | 89 (21) | 93 (17) | 95 (7)
Deras96, 2008 | 557 | 50 | 45 (21) | 55 (22) | 63 (19) | 74 (20) | 82 (25) | 89 (13) | 95 (5)
Bollito93 (initial) | 728 | 100 | 42 (2) | 48 (-3) | 57 (-1) | 61 (0) | 66 (-1) | 77 (-2) | 90 (1)
Aubin91 | 1,072 | 0 | 49 (13) | 60 (18) | 68 (11) | 74 (7) | 79 (5) | 85 (2) | 94 (3)
Medians (13 studies, 16 datasets) | 4,979 | | 49 (13) | 61 (19) | 72 (21) | 79 (20) | 83 (15) | 89 (9) | 94 (5)
Medians (4 ‘grey zone’ studies) | 2,107 | | 53 (19) | 65 (21) | 74 (23) | 83 (23) | 86 (17) | 91 (14) | 95 (9)
Medians (9 studies, 11 datasets)^c^ | 2,810 | | 45 (13) | 57 (15) | 67 (20) | 77 (20) | 84 (17) | 89 (9) | 94 (5)

Bx = prostate biopsy; N = number; tPSA = total prostate specific antigen

a Difference = (PCA3 sens – tPSA sens) when (1-specificity) is held constant at values ranging from 20% to 80%. For example, at a 1-specificity of 50%, the PCA3 sensitivity in the Schilling study is 95% and the tPSA sensitivity is 39% lower or 56%.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients, as well as the summary line where the results of those studies are summarized. Rows 8, 10, 13, 16, and 18 are shaded.

c After removal of Adam90, a study focusing on a South African 69% black population; 11 estimates since 2 each for Goode & Bollito.

Figure 6 A scatterplot showing the relationship between the proportion of men with an initial biopsy versus the difference in PCA3 and tPSA sensitivities at a specificity of 50%

PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: The horizontal axis shows the proportion of men with an initial biopsy (range 0 to 100%). The vertical axis shows the difference in sensitivity (PCA3 sensitivity – tPSA sensitivity) of detecting prostate cancer, when the specificity is held constant at 50%; a value of 0 (dashed horizontal line) indicates the sensitivities are equivalent. Each circle indicates the results from one included study. Results from four studies focusing on the “grey zone” 31,91,95,106 are filled circles. The original data for this figure were shown in Table 13. There was no significant relationship (slope = -0.09, p=0.26) for the 16 studies, as indicated by the solid line and 95% confidence intervals. Removing the one study90 (filled square) from South Africa in which 69% of men were black resulted in a slope closer to zero (slope = -0.06; p=0.44). Removing this study and the four “grey zone” studies results in a similar slope (slope = -0.15, p=0.16).

Figure 6 examines the relationship between proportion of men with an initial biopsy and sensitivity difference between PCA3 and tPSA. The horizontal axis shows the proportion of men with an initial biopsy (range 0 to 100%.) The vertical axis shows the diference in sensitivity (PCA3 sensitivity - tPSA sensitivty) of detecting prostate cancer, when the specificity is held constant at 50%; a value of 0 (dashed horizontal line) indicates the specificities are equivalent. Each circle indicates the results from one included study. Results from four studies focusing on the “grey zone” are filled. One observation (filled square) was from a study in which most men were black.

Together, these two analyses shown in Figures 5 and 6 provided evidence that combining results from studies of initial biopsies, repeat biopsies, and mixtures of initial and repeat biopsies did not appear to impact the comparison of PCA3 with tPSA elevations.

One other matched analysis provided additional support for this finding. Two studies93,99 provided matched PCA3/tPSA ROC curves separately for men who had an initial biopsy, and those receiving a repeat biopsy (also Table 13). Therefore, these were matched within-study comparisons of the relative effectiveness of the two markers in these biopsy-specific subgroups. The first study93 found that tPSA performed much better in initial compared with repeat biopsies, while PCA3 performed much worse in initial compared with repeat biopsied men. This is consistent with some who have argued that tPSA would be expected to perform poorly in the repeat biopsy setting, as those tumors associated with high tPSA were identified in the initial round of testing and would not be present in a population having repeat biopsies. However, the second study99 found much different patterns. The tPSA performed almost equally as well in initial and repeat biopsy settings, and PCA3 performed much better in initial compared with repeat biopsies. These two studies reported almost opposite findings.

Such analyses cannot be performed for any of the other comparators. However, given the lack of data for those comparisons, we chose to comprehensively list all potentially relevant results, regardless of the biopsy status of the enrolled men. The following sections provide the results of the combined analysis of KQ 1 and KQ 2.

### Description of Included Studies for KQ 1/KQ 2 “Combined”

As noted in Methods, the inclusion criteria restricted study inclusion to matched studies. These were defined as studies that provided estimates of diagnostic test performance for PCA3 and at least one other comparator (e.g., tPSA elevations or %fPSA) using the same patient population. Thus, a study of PCA3 alone, or a comparator alone, would not be included. In examining the included studies, it was clear that, although the same population was used, the reports rarely applied a true matched analysis. However, the results were still considered as being “matched,” due to the application of the test(s) to the same underlying population. We preserved this population matching by computing differences between PCA3 test results and comparator test results within each study. These matched differences could then be compared across studies.

For example, one study of biopsied patients might report an AUC for PCA3 and then separately report an AUC for tPSA in the same population. The difference in the two would then be computed and compared with the difference in AUCs from other similarly matched studies. Although this restriction limited the number of included publications, it was aimed at improving the consistency of results. For example, an analysis of unmatched studies might have provided sufficient information to stratify PCA3 performance by number of previous biopsies. Similar data could be obtained from the literature for tPSA. Comparing the results between these unmatched studies might have shown differences related to variations in study populations or design rather than the variable of interest.

All studies were judged to be of poor quality, based on reasons including: use of convenience data (i.e., opportunistic cohorts of men having prostate biopsy); potential biases (e.g., verification, selection, spectrum); incomplete or unclear study protocol (e.g., inclusion criteria, missing key variables); limited analyses and no matched analyses (or raw data from which to conduct matched analysis); and/or lack of blinding or reporting on blinding. In addition, four of the 24 studies addressing KQ 1 and KQ 2 were funded by GenProbe and a third of the 24 (N=8) indicated conflicts of interest for investigators (Table 1). All of these studies focused on determining the diagnostic accuracy of PCA3 testing using biopsy results as the reference or gold standard. No studies were identified that reported on intermediate outcomes other than diagnostic accuracy, or long-term clinical outcomes.

### Evaluation of PCA3 and Other Comparators To Identify KQs 1 and 2 Intermediate and Long-Term Outcomes

#### Comparator: Total Serum PSA

Study design was a crucial criterion for this comparison, because tPSA measurements were integral to decisionmaking regarding uptake of prostate biopsy after the finding of an initial tPSA elevation through prostate cancer screening. Men were likely offered biopsy based on the extent of tPSA elevations, suspicious findings on a digital rectal exam (DRE), a combination of the two or, less commonly, other risk factors such as family history or race. This led to only a subset of initially identified men having the “gold standard” test (biopsy) that defines one of the outcomes of interest – diagnostic accuracy. This association of test result with uptake of the diagnostic test has been labeled verification bias.

As noted, verification bias would have occurred in this setting because men with higher tPSA elevation were more likely to undergo biopsy compared with men with lower levels. Thus, test sensitivity would have been overestimated (as a higher proportion of cancers with lesser elevations would not have been identified by biopsy). This bias would have underestimated specificity (or overestimated the false positive rate), because the larger number of men without cancer and negative biopsy results were not identified via biopsy. See Appendix J for a more complete description of verification bias, an example relevant to prostate cancer and tPSA elevations, a review of directly relevant literature, and an evaluation of what will, or will not be compromised in this comparison. Appendix J also contains a more complete description of the modeling used to overcome the major impact of verification bias and a more extensive comparison of PCA3 and tPSA test performance characteristics.

These analyses indicated that the relative performance of tPSA elevations (sensitivity at a given specificity) was, at most, modestly influenced by verification bias, but the tPSA cutoff level at which this performance occurred cannot be directly observed. We employed a simple model to determine approximate tPSA cutoff levels in the presence of verification bias. This bias would be less likely to have been an issue for the other comparators (e.g., %fPSA, PSA density), but the extent of this bias is likely related to the correlation between that comparator and tPSA measurements. In addition, this correlation may be low because these comparators were not routinely used in all men with a tPSA/DRE positive result and may, therefore, not be strongly associated with biopsy uptake. A second known bias, sampling bias, was related to a subset of studies that limited their reporting to men in the “grey zone” of tPSA measurements and was variably defined in these studies as between 2.5 and 10 ng/mL,91,95,106 2.0 and 20 ng/mL98 or 4 and 10 ng/mL.105 These studies would have underestimated the performance of tPSA compared with studies that included all men with elevated results. We accounted for this bias by stratifying results, when possible.

#### Total PSA and the Intermediate Outcome of Diagnostic Accuracy

##### Key Points

The extent of tPSA elevations was compared with PCA3 scores to determine their diagnostic accuracy to predict prostate biopsy results (cancer/no cancer). Measures included in the analyses were the sensitivity, specificity (or the false-positive rate equal to 1-specificity), and positive and negative predictive values. As a reminder, only studies in which the performance estimates for both comparators were made in the same population were included in the five analyses listed below.

- Area under the curve (AUC). Twenty studies (Table 10) reported AUC estimates for tPSA and PCA3 in the same population and the difference of the two [AUC(PCA3) – AUC(tPSA)] was computed. Overall, 18 of the 20 studies found a positive difference. The two90,102 studies finding tPSA elevations to have a greater AUC were among the smaller studies. Removing the four studies31,91,95,106 that restricted recruitment to the tPSA “grey zone” resulted in an AUC difference of 0.0865 in the remaining 16 studies (Table 10).
- Reported median, interquartile range, range and estimated logarithmic means/standard deviations (SD). Eight studies (Table 11) provided sufficient data for analysis, and none of these directly reported a logarithmic SD (most, if not all studies examining the distribution found both PCA3 and tPSA to be highly right skewed). The logs SDs were estimated from the ranges or inter-quartile ranges. The differences, reported as z-scores, indicated that one study102 (the smallest) found tPSA to be slightly better than PCA3 at separating populations of positive and negative prostate biopsies, while the remaining seven others found a larger difference in favor of PCA3.
- Performance at a PCA3 cutoff score of 35. Nine studies (Table 12) reported the sensitivity and specificity of PCA3 at this cutoff. We computed the difference in sensitivity (PCA3 – tPSA) when tPSA was held at the PCA3-related specificity. Eight of the nine studies reported a positive difference (median 16.3 percent, range -9.5 to 35 percent) favoring PCA3 (Table 12).
- ROC curves - sensitivity/specificity. Fourteen studies and 16 datasets (Table 13) provided a ROC curve, or data representing a ROC curve, for both markers. At a specificity of 50 percent, the difference in corresponding specificities (PCA3 – tPSA) was zero or positive for all included studies except the one performed in a majority black population.90 Removing the four studies that restricted recruitment to the tPSA “grey zone”31,91,95,106 and the one study performed in a majority black population90, the difference in sensitivity favored PCA3 by 20 percent (range 0 to 39 percent).
- Regression analysis. Only one study provided sufficient data to apply the respective regression coefficients to create a relative odds ratio (OR) between the 25^th^ and 75^th^ centiles of the two distributions.31 A second study95 reported all but the inter-quartile range, and that was estimated from the first study so that both datasets could be evaluated. In both studies, the ratio of the ORs (PCA3 / tPSA) was greater than 1 (1.38 and 1.97). These two studies31,95 both restricted recruitment to the tPSA “grey zone,” so the results were likely to overestimate the relative superiority of PCA3 by underestimating tPSA performance.

Table 11 Comparison of PCA3 and tPSA differences in central estimates in men with positive and negative prostate biopsy results, after accounting for study-specific variability in measurements

Author Study^a^, Year | N | Median PCA3 Score: Positive Bx | Median PCA3 Score: Negative Bx | Median PCA3 Score: Pooled Log SD | Median PCA3 Score: Z_PCA3_^b^ | Median tPSA (ng/mL): Positive Bx | Median tPSA (ng/mL): Negative Bx | Median tPSA (ng/mL): Pooled Log SD | Median tPSA (ng/mL) Z_PCA3_^b^ | Z_PCA3_ – Z_tPSA_
Nyberg102, 2010 | 62 | 49.0 | 22.0 | 0.4150 | 0.84 | 12.6 | 6.2 | 0.2918 | 1.06 | -0.22
Ankerst65, 2008 | 443 | 34.3 | 19.4 | 0.4480 | 0.55 | 8.2 | 6.7 | 0.3604 | 0.24 | 0.31
Perdona31, 2011 | 218 | 72.0 | 22.0 | 0.4264 | 1.21 | 8.0 | 6.0 | 0.1514 | 0.83 | 0.38
Ferro98, 2012 | 151 | 57.0 | 28.0 | 0.3469 | 0.89 | 7.9 | 6.8 | 0.1438 | 0.45 | 0.44
Bollito93, 2012 | 1,246 | 63.0 | 35.0 | 0.4530 | 0.56 | 7.4 | 6.3 | 0.6873 | 0.09 | 0.47
Hessels100, 2010 | 336 | 50.0 | 18.0 | 0.5492 | 0.81 | 8.3 | 5.9 | 0.4836 | 0.31 | 0.50
Ochiai103, 2011 | 105 | 59.5 | 14.2 | 0.3489 | 1.78 | 10.7 | 6.3 | 0.2875 | 0.80 | 0.98
Auprich92, 2011 | 127 | 75.0 | 35.0 | 0.2929 | 1.13 | 8.8 | 8.1 | 0.4605 | 0.08 | 1.05
Number / Medians | 2,687 | 58.3 | 22.0 | | | 6.3 | 8.3
Aubin91, 2010 c | 1,072 | 33.8 | 16.7 | - | - | - | - | - | - | -
de la Taille95, 2011 c | 516 | 50.0 | 18.0 | - | - | 5.8 | 5.2 | - | - | -

Bx = prostate biopsy; N = number; SD = standard deviation; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

a Ordered by Z_PCA3_ – Z_tPSA_ result; shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Rows 3, 4, 10, and 11 are shaded.

b Z score = (log (Positive Bx median) – log (Negative Bx median)) / pooled log SD within each study.

c The last two studies91,95 reported partial information for comparison of biopsy positive and negative median values, but did not provide sufficient data to compute Z scores.

Table 12 Differences in PCA3 and tPSA sensitivities at the fixed specificity associated with the commonly used PCA3 score cutoff of 35^a^

Study Author^b,c^, Year | N | Initial Bx | Positive Bx | PCA3 1-Spec (%) | PCA3 Sens (%) | tPSA Sens (%)^a^ | Difference (%)
Adam90, 2011 | 105 | 82% | 42.9% | 50.0 | 77.7 | 87.2 | -9.5
Wu111, 2012 | 103 | 0% | 36.0% | 23.0 | 38.0 | 32.0 | 6.0
Bollito93, 2012 | 1,246 | 59% | 25.9% | 49.1 | 72.0 | 62.5 | 9.5
Aubin91, 2010 | 1,072 | 0% | 17.7% | 21.4 | 48.4 | 35.5 | 12.9
Ochiai103, 2011 | 105 | 81% | 36.0% | 25.4 | 74.3 | 54.5 | 19.8
Deras96,2008 | 557 | 50% | 36.0% | 26.1 | 53.9 | 32.5 | 21.4
Wang110, 2009 | 187 | 73% | 46.5% | 20.0 | 52.9 | 24.5 | 28.4
de la Taille95, 2011 | 516 | 100% | 40.0% | 24.0 | 64.0 | 33.0 | 31.0
Goode99, 2012 | 456 | 63% | 19.3% | 25.0 | 62.0 | 27.0 | 35.0
Median Difference | 4,409 | | | | | | 16.3

Bx = prostate biopsy; Diff = (PCA3 % Sens – tPSA % Sens); N = number; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen; Spec = specificity (1-specificity=false positive rate); Sens = sensitivity (detection rate)

a Sensitivity for tPSA elevation at the same 1-specificity (false positive rate) found for a PCA3 score at a cutoff of 35 in that study.

b Shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Rows 4 and 8 are shaded.

c Note that a small study by Nyberg et al102 was deleted from this table because the reported PCA3 sensitivity and 1-specificity were not consistent with the reported PCA3 ROC curve.

Note: The number of true positives = N * Positive * Sens (e.g., for Adam, TP=105*42.9% * 77.7% = 35); FN=N*Positive-TP; TN=N*(100-Positive)*Spec; FP=N*(100-Positive)-TN.

##### Interpretation

The results of analyzing the literature regarding the matched analyses of PCA3 score versus extent of tPSA elevations was summarized in Table 8. A more complete description of how these data were computed has been provided in Appendix J. Table 8 compares the diagnostic accuracy of PCA3 scores and tPSA elevations to independently identify men who would have a positive biopsy (prostate cancer). In Table 8A, the false-positive rate (1-specificity) was held constant, while in Table 8B, the sensitivity (detection rate) was held constant. This display was chosen because an undetected cancer was not considered equivalent to a falsely positive prostate biopsy and, therefore, comparing a loss in sensitivity with a gain in specificity was difficult. The last column shows the difference between the two estimates (PCA3 – tPSA). When comparing the sensitivities (Table 8A), this column contains the improvement in prostate cancer detection. When comparing the false-positive rates, it contains the reduction in biopsies performed on men without prostate cancer.

Table 8 Modeled comparison of PCA3 and tPSA elevations to identify men with prostate cancer, with either the false positive rate (1 – specificity) or the sensitivity held constant

A) False Positive Rate (FPR) Held Constant
FPR (1 -Specificity) | PCA3 Cutoff (Score) | PCA3 Sensitivity | tPSA Cutoff (ng/mL) | tPSA Sensitivity | Improvement in Prostate Cancer Detection
80% | 9.3 | 95.1% | 1.8 | 86.8% | 8.3%
70% | 12.6 | 91.0% | 2.5 | 78.1% | 12.9%
60% | 16.4 | 88.7% | 3.2 | 72.2% | 16.5%
50% | 21.0 | 79.1% | 4.1 | 60.5% | 18.6%
40% | 26.8 | 71.2% | 5.2 | 50.8% | 20.4%
30% | 34.9 | 61.2% | 6.8 | 39.8% | 21.4%
20% | 47.4 | 48.8% | 9.3 | 28.0% | 20.8%
B) Sensitivity Held Constant
Sensitivity | PCA3 Cutoff (Score) | PCA3 FPR (1-Specificity) | tPSA Cutoff (ng/mL) | tPSA FPR (1-Specificity) | Reduction in Biopsies
95% | 9.3 | 80.0% | 1.1 | 89.8% | 9.8%
90% | 13.3 | 68.2% | 1.5 | 85.1% | 16.9%
85% | 16.9 | 58.9% | 1.9 | 78.7% | 19.8%
80% | 20.4 | 50.2% | 2.3 | 72.5% | 22.3%
70% | 27.7 | 38.7% | 3.2 | 60.1% | 21.4%
60% | 36.0 | 28.9% | 4.1 | 50.0% | 21.1%
50% | 46.0 | 20.9% | 5.3 | 39.5% | 18.6%

DR = proportion of biopsy positive men with a PCA3 score or tPSA elevation at or above the cutoff level; FPR = proportion of biopsy negative men with a PCA3 score or tPSA elevation at or above the cutoff level; tPSA = total prostate specific antigen

For example, assume that one would like to set test sensitivities to 85 percent. Using the row with 85 percent sensitivity (shaded row, Table 8B), only 59 percent of men without cancer would be subject to biopsy with PCA3 testing (cutoff score of about 17). Using tPSA elevations, 79 percent of those men without cancer would be biopsied (cutoff of 1.9 ng/mL). This means that using PCA3 instead of tPSA elevations, the same proportion of cancers might be detectable while performing 20 percentage points fewer biopsies. Additional tables at fixed PCA3 and tPSA cutoff levels, individual risks and positive and negative predictive values at several difference prostate cancer rates can be found in Appendix J (Tables J1 through J4).

### Characteristics of Studies Reporting Data Used in Five Analyses for KQs 1 and 2 Combined

Twenty two studies addressing KQ 1 and KQ 2 reported PCA3 and tPSA comparisons that could be used in one or more of the five analyses of matched studies (Table 9). Of interest are the five studies that used an upper cutoff for tPSA elevations to define a “grey zone.”31,91,95,98,106 When the tPSA range was truncated, it would reduce the effectiveness of the marker to predict biopsy outcome. In general, this was confirmed in our analyses, and, for that reason, the results may be stratified by this characteristic, the entries shaded in tables, and the observations noted in Figures. All study quality ratings were poor.

Table 9 Summary results for five analytic comparisons^a^ of PCA3 versus tPSA in matched populations of men having prostate biopsies

Author Study^b^, Year | N | Initial Biopsy | AUC | Mean/SD | PCA3>35 | Sens/Spec | Reg
Adam90, 2011 | 105 | 82% | -0.1389 | - | 3.1% | 1% | -
Nyberg102, 2010 | 62 | 55% | -0.0543 | -0.22 | -23.3% | 0% | -
Bolitto93 (initial), 2012 | 735 | 100% | 0.0010 | - | - | 0% | -
Aubin91, 2010 | 1,072 | 0% | 0.0310 | - | 12.9% | 7% | -
Roobol108, 2010 | 721 | 71% | 0.0540 | - | - | - | -
Rigau107, 2010 | 215 | 74% | 0.0580 | - | - | 11% | -
Ankerst65, 2008 | 443 | 0% | 0.0580 | 0.31 | - | 11% | -
Hessels100, 2010 | 336 | NR | 0.0700 | 0.50 | - | - | -
Wu111, 2012 | 103 | 0% | 0.0700 | - | 6.0% | 28% | -
Ouyang104,2009 | 92 | NR | 0.0800 | - | - | - | -
Bolitto93 (composite), 2012 | 1,246 | 59% | 0.0930 | 0.47 | 9.5% | - | -
Goode99 (repeat), 2012 | 169 | 0% | 0.1050 | | - | 26% | -
Mearini101, 2009 | 96 | NR | 0.1180 | - | - | - | -
Ochiai103, 2011 | 105 | 81% | 0.1264 | 0.98 | 19.8% | 7% | -
Ploussard106, 2010 | 301 | 0% | 0.1350 | - | - | 21% | -
Auprich92, 2011 | 127 | 0% | 0.1350 | 1.05 | - | - | -
Deras96, 2008 | 557 | 51% | 0.1390 | - | 21.4% | 20% | -
Cao94, 2011 | 131 | NR | 0.1730 | - | - | - | -
de la Taille95, 2011 | 516 | 100% | 0.1840 | - | 31.0% | 26% | 1.38
Perdona31, 2011 | 218 | 61% | 0.1920 | 0.38 | - | 25% | 1.97
Schilling109, 2010 | 32 | 86% | 0.2000 | - | - | 39% | -
Goode99 (composite), 2012 | 456 | 63% | 0.2150 | - | 35.0% | - | -
Goode99 (initial), 2012 | 287 | 100% | 0.2200 | - | - | 24% | -
Bolitto93 (repeat), 2012 | 511 | 0% | 0.2310 | - | - | 29% | -
Wang110, 2009 | 187 | 73% | - | - | 28.4% | - | -
Ferro98, 2012 | 151 | 100% | - | 0.44 | - | - | -

N = number; NR = not reported; Sens = sensitivity; Spec = specificity; tPSA = total prostate specific antigen

a AUC = area under the curve for PCA3 minus the AUC of tPSA; Mean/DS = difference in separation between PCA3 scores and tPSA results, when expressed as z-scores; PCA3>35 = difference of the PCA3 minus the tPSA sensitivities at the specificity found for a PCA3 cutoff of 35; Sens/Spec = difference between PCA3 and tPSA sensitivity at a specificity of 50%; Reg = relative change in the PCA3 ORs (between the 25^th^ and 75^th^ centiles) and the corresponding tPSA ORs. The corresponding full analyses resulting in these summaries can be found on the following pages.

b Order based on AUC difference; shaded rows indicate studies focusing on the “grey zone” of tPSA (e.g., 2.5-10 ng/mL) when enrolling patients. Rows 4, 15, 19, 20, and 26 are shaded.

#### PCA3 and tPSA: Area Under the Curve

Twenty studies and 22 datasets reported the diagnostic performance of PCA3 and extent of tPSA elevation among men with initially screen positive test results (elevated tPSA with or without positive DRE) to discriminate between positive and negative biopsy test results. These studies and related information are shown in Table 10. Five studies65,91,92,106,111 in which all individuals already had one or more negative biopsies were among the included studies, in order to strengthen the analysis of PCA3 and tPSA elevations. The studies are ordered by effect size, the difference between the matched AUC estimates of PCA3 minus tPSA (positive numbers indicate PCA3 performed better, negative numbers indicate tPSA performed better).

All but two studies90,102 found the matched AUC point estimate for PCA3 higher than that for tPSA. Those two studies were among the five smallest reported, with 62 and 105 enrollees, respectively. The largest effect size was reported by the smallest study of all109, reporting matched results for only 32 men. The median AUC difference for all studies was 0.1055 (range -0.1389 to 0.2150). Only eight31,65,95,99,101-103,108 of the 20 studies reported the matched p-values comparing the two AUCs. Using these as a guide, at least the 10 studies from row 11 (Mearini101) to the end of the table are likely to have been statistically significant. No study reported a statistically significant lower performance for PCA3. The study reporting a difference of -0.139 did not report a p-value, but did provide the respective 95%confidence intervals (CI) on the PCA3 and tPSA AUC estimates. These overlapped, indicating the differences were not likely to be significant (0.705, 95% CI: 0.599 to 0.812; and 0.844, 95% CI: 0.765 to 0.910, respectively).

None of the studies reported a confidence interval or standard deviation for the matched difference of the two AUCs. Although the AUCs for PCA3 and tPSA ranged widely (indicating relatively high heterogeneity), the variability of the differences seemed more consistent. This may be due to the requirement that only paired estimates of the AUCs be included in this analysis.

Four studies31,91,95,106 enrolled only men with tPSA levels less than 10 ng/mL, essentially limiting their population to the so-called “grey zone.” In general, only one to two percent of biopsy negative men had tPSA levels over 10, while about 20 percent of biopsy positive men were in this range.120,121 Removing this subset from the overall population of men with positive tPSA/DRE was likely to have the effect of reducing the ability of tPSA to predict positive prostate biopsies. Thus, one would have expected these studies to show greater differences in favor of PCA3. The four studies focusing on the “grey zone” are highlighted in grey in Table 10. All but one91 was near the bottom of the table, indicating that they did, in fact, find greater differences. The median difference in AUC in the “grey zone” studies was 0.1595. If these four studies were removed, the AUC difference was reduced to 0.0865. Although not formally computed, the heterogeneity would also be expected to be reduced. One could argue that these four “grey zone” studies should have been excluded, as they did not, technically, satisfy fully the inclusion criteria. However, they were included for two reasons. First, the performance in this subset had clinical implications. For example, some may argue that clinicians could intervene based solely on a very elevated tPSA, but use additional markers to evaluate the remaining “grey zone” patients. This assumes that very elevated tPSA results are, by themselves, sufficiently informative for decisionmaking, and performance would not benefit from adding a second useful and independent marker like PCA3. Should PCA3 come into routine practice, it is not clear that use only in the “grey zone” would be an effective approach. Second, the “grey zone” stratification identified a source of heterogeneity and helped demonstrate the validity of these analyses.

An estimate of the potential for publication bias for this analysis could be generated under the assumption that the standard error of the AUC difference was proportional to the reciprocal of the square root of the number of enrolled men for each study. Figure 7 shows a plot of the computed AUC difference (x-axis) versus its estimated precision (i.e., the reciprocal of the square root of the sample size [y-axis]). The solid vertical line shows the median difference of 0.1055 while the dashed vertical line at 0.000 shows where the AUC would be equivalent. As predicted, the data were found to fit a symmetric “inverted funnel,” suggesting that at least some of the variability was due to the small samples sizes for several of the studies. The results seemed far more consistent for the 11 largest studies31,65,91,93,95,96,99,100,106-108 that provided matched results for 200 or more men.

Figure 7 Examining the relationship between effect size (AUC difference) and an estimate of precision

AUC = area under the curve; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: In this analysis, precision is estimated by the reciprocal of the square root of N (the number of study subjects). The vertical dashed line indicates the points at which the two tests (PCA3 and tPSA) perform equally. The filled circles indicate studies focusing on the “grey zone” of tPSA.

Figure 7 examines the relationship between effect size (AUC difference) and an estimate of precision. The X axis defines the AUC difference calculated by subtracting tPSA from PCA3. The Y axis represents precision, is estimated by the reciprocal of the square root of N, and ranges from a high of 0.20 to a low of 0. A vertical dashed line at 0 on the X scale indicates the points at which the two terms perform equally. A summary line representing the scatter of matched points appears at 0.1055 on the X scale.

Figure 8a explores the relationship of the AUC difference, this time comparing the results against the average AUC (average of PCA3 and tPSA AUCs). The actual AUC for the markers may be indicative of extraneous factors (e.g., tPSA cutoff level, age of enrollees) that may vary among the 20 studies included in this analysis. Of interest, the two studies90,102 reporting the negative AUC differences were two of the three highest average AUCs. However, regression analysis showed no significant relationship between average AUC and the AUC difference (slope not significant; p=0.72). The median average AUC was 0.6605 (range 0.5525 to 0.7875). Figure 8b displays the tPSA AUC on the x-axis versus the PCA3 AUC on the y-axis for the same studies shown in Figure 8a. The dashed “line of identity” indicates all values where the tPSA and PCA3 AUCs would be equal. On average, the observations fall above the line, showing that the PCA3 AUC is higher than the tPSA AUC within a given study. As expected, the four studies in the “grey zone” of tPSA (filled circles) tend to have higher differences that fall farther from the line of identity.

Figure 8a The relationship between AUC difference and average AUC for PCA3 and tPSA

AUC = area under the curve; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: The solid line indicates the results of linear regression (AUC_Difference = -0.3120 * Avg_AUC + 0.3068). The dashed lines show the 95% prediction limits. The filled circles indicate studies focusing on the “grey zone” of tPSA .

Figure 8a examines the relationship between AUC difference and average AUC for PCA3 and t PSA. The X axis represents the average AUC for PCA3 and tPSA and ranges from 0.60 to 0.80. The Y axis is the difference ins AUC between PCA3 and tPSA. A solid line is drawn indicating the linear regression of this relationship with is AUCDifference = 0.3120**Average AUC + 0.3068. The 95% prediction limits are shown by dashed lines. The slope is not significant.

Figure 8b Scatterplot showing the reported tPSA AUC versus the reported PCA3 AUC

AUC = area under the curve; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: The dashed line shows the points at which the two AUCs would be equivalent. The majority of observations are above the line, indicating the PCA3 AUCs are, on average, higher. The filled circles indicate studies focusing on the “grey zone” of tPSA.

Figure 8b is a scatterplot showing treh reported tPSA AUC versus the reported PCA3 AUC. The dashed line shows the poinats at which the two AUCs would be equivalent. The majority of observations are above the line, indiating the PCA3 AUCs are, on average higher.

Eighteen studies identified the methodology used for PCA3 testing (Table 4). Two used Aptima reagents (GenProbe),100,103 10 specified using the Progensa^®^ kit,31,90,92,93,95,96,99,102,106,108 and two reported only using a “GenProbe” test.91,109 Among the remaining six studies, four used a quantitative RT-PCR method,94,101,104,107 The remaining two studies64,106 did not specify the method, but disclosures suggested that both were likely using the current GenProbe assay (Progensa).65,111 AUC differences (PCA3-tPSA) for fourteen studies using GenProbe reagents were compared with the proportion of men having an initial biopsy (figure not shown). This regression analysis showed no significant relationship between the AUC difference and initial biopsy status (slope -0.0472; p=0.52). The slope indicates that over the range of AUCs shown in Figure 8a (0.6 to 0.8), the difference in AUC would be -0.0094 or about a 1 percent lower for all initial biopsied patients compared with all repeat biopsied patients. The same analysis for six studies using other assays also showed no significant relationship (slope 0.0854; p=0.27), but the slope indicated a 1.7 percent higher AUC for the same comparison. Therefore, the analysis does not provide statistically significant evidence that assay methodology is an important consideration.

Among the six of 20 studies that reported the racial/ethnic distribution in the study population (Table 3),65,90,94,96,103,104 one was in an Asian (Japanese) population103 and this group's AUC difference of 0.126 was slightly higher than the summary estimate of 0.1055 Another Asian study94 (China) had an AUC difference estimate of 0.173. Only one study performed in South Africa reported on a population composed of a majority of black men (68.6 percent, Table 3),90 and the group's AUC difference of -0.139 was the lowest observed in all studies (Table 10). The four North American studies reporting a small black population (5.3^96,110^ and 2 percent65,104) had AUC differences near the consensus estimate.

Each reviewed study was assigned a QUADAS quality score of good, fair, or poor. Among the 20 included studies in the AUC differences computation (Table 10), all were rated poor. Only one of the studies was blinded in both directions (i.e., laboratory blinded to outcome, and clinicians blinded to laboratory results), and only two were blinded in a single direction (one in each direction).

#### PCA3 and tPSA: Reported Medians and Standard Deviations

Eight studies (Table 11) reported some information concerning the distributions of PCA3 and tPSA levels among men with screen positive test results (elevated tPSA with or without positive DRE) who subsequently had positive or negative biopsy results. Results from these studies and related information are also shown in Table 11. The distributions of both markers are highly right skewed and have been shown to be reasonably Gaussian after a logarithmic transformation. For this reason, we chose to include for analysis only those studies in which the median or logarithmic mean could be determined along with the logarithmic standard deviation. In some instances the standard deviation was estimated using reported centiles (e.g., inter-quartile range). If a study only reported the range, the standard deviation was computed assuming the range represented 6 standard deviations.122 For each study, the difference in marker levels in those with positive or negative biopsies was expressed as a z-score, using a study-specific pooled standard deviation.

It was possible to obtain a median and pooled log standard deviation for both markers using data from eight studies (Table 11). Studies were sorted by the difference in z-scores. The two studies that truncated results above 10 ng/mL31 or 20 ng/mL98 are shown in grey. One study65 incorrectly reported the median PCA3 score in men with a negative biopsy; the corrected value of 19.4 is shown. Two additional studies91,95 had partial data, and were also summarized at the bottom of Table 11 to allow for comparison of median levels only. This analysis would have been more robust had the authors actually reported the median and logarithmic standard deviations for their populations, provided raw data (in the form of a scatterplot) or fitted the data to some other distribution.

Figure 9 shows the overlapping distributions from the eight studies shown in Table 11. The overlapping curves were drawn based on the log Gaussian parameters described there. The individual figures show each set of paired distributions. Given the fact that only eight studies were analyzed, it was not possible to stratify results by race, region or test methodology. Note that the very tight distributions for tPSA can be seen for the two “grey zone” studies.31,98

Figure 9 Distributions of PCA3 and tPSA in men with positive and negative prostate biopsies from four studies that reported such information in the same cohort

PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

Note: The logarithmic means and pooled standard deviations were obtained from Table 11. The solid line indicates the distribution for those with a negative biopsy, while the dashed line represents the distribution in those with a positive biopsy. For each study (indicated by the first author), these distributions were obtained in the same group of men. The figures are sorted by the relative performance of PCA3 over tPSA (from left to right, top to bottom).

Figure 9 compares the logarithmic means and standard deviations drawn as modified bell curves between PCA and tPSA in each of eight studies. For each study on the left hand side (left sided column) are two curves plotted against a horizontal axis ranging from 1 to 1000 ng/ml. In all studies dotted lines represent biopsy positive patients and solid lines represent biopsy negative patients. On the right hand side (right column) the same results are seen with the vertical axis ranging from 1 to 100 ng/ml. Dotted lines always fall to the right of the solid line.

#### PCA3 and tPSA: Performance at a PCA3 Cutoff Score of 35

Nine studies (Table 12) reported the sensitivity and specificity of PCA3 score at a cutoff of 35 among men with positive initial screening results (elevated tPSA with or without positive DRE) who subsequently had positive or negative biopsy results. Table 12 shows the sensitivity and false positive rates (1 – specificity) for PCA3 with the corresponding sensitivity of tPSA at the same specificity found for the PCA3 cutoff level. The table was sorted by effect size. The difference in the two sensitivities (with the specificity held constant) provided a comparison of the ability to distinguish prostate cancer between the two markers. In some instances, the tPSA results were estimated from a published ROC curve. In one study, the specificity/1-specificity was incorrectly reported, as evidenced by the additive inverse found on the accompanying ROC curve. In another study102, the reported sensitivity/specificity did not match the corresponding ROC curve, and the reason for the discrepancy could not be identified. Those data were excluded from analysis. The most appropriate analysis that compared two tests on the same population was to use a matched analysis of the 2×2 table. However, all nine studies reported only independent evaluations of each marker.

Among the nine studies (Table 12), the PCA3 score cutoff level of 35 was associated with false-positive rates (1-specificity) ranging between 20 and 50 percent, with corresponding sensitivities (detection rates) between 38 and 77 percent. For each study, the corresponding sensitivity for tPSA (at the same false positive rate) was subtracted from the PCA3 sensitivity. For one study90, the difference was negative, while the eight remaining studies showed PCA3 having higher sensitivities with increases ranging from 3 to 35 percent. The median increase in sensitivity was 16.3 percent.

Given that only nine studies were analyzed, it was not possible to stratify results by race, region or test methodology. Of interest, however, is that the one study90 that found PCA3 to be least useful was performed in a largely black population and was quite small (45 positive biopsies), leading to a wide confidence interval on the sensitivity estimate.

As a way of estimating whether the nine studies were reasonably consistent in their estimates of sensitivity and specificity, a summary analysis was performed for PCA3 (Figure 10). There was high and significant heterogeneity (I^2^=100 percent. p<0.001). This can be seen in the figure and the table with the two studies90,93 having much higher false positive rates, but only modestly higher sensitivities. Thus, a better summary of the data is the fitted ROC curve shown in Figure 10 [Spearman correlation between the logit (sensitivity) and logit (1-specificity) = 0.76, p=0.01]. This presentation is not subject to the usual strong bias introduced by the tPSA upper cutoff of 10 ng/mL used in two of the studies,91,95 as PCA3 is essentially independent of tPSA measurements (Table 15), and Figure 10 focuses only on the PCA3 results.

Figure 10 The performance of PCA3 score to identify subsequent positive prostate cancer biopsies from nine studies

Note: The sensitivity (y-axis) versus the false positive rate (1-specificity, x-axis) of PCA3 testing is shown for the nine studies. Filled circles indicate the study that focus on the “grey zone” of tPSA (2.5-10 ng/mL) when enrolling patients. The thin solid lines indicate the 95% confidence intervals of the sensitivity estimates. The solid line is the fitted ROC curve to the provided data. For reference, the dashed line indicates where the sensitivity and 1 - specificity are equal, indicating a useless test.

Figure 10 examines the performance of PCA3 score to identify subsequent positive prostate cancer biopsies for nine studies. The X axis represents the false positive rate (1-specificity) and is scaled from 0 to 1. The Y axis represents sensitivity of testing and is also scaled from 0 to 1. A dotted vertical line runs across the figure at a 45 degree angle to show the point at which sensitivity equals 1-specificity and a test would be noninformative. The sensitivity versus the specificity is shown with the points representing all 9 studies falling above the dotted line. Filled circles indicate the studies that focus on the “grey zone” of tPSA.

Table 15 Measures of independence of PCA3 and tPSA in identifying men with a positive biopsy

Study Author^a^, Year | Number | Correlation Coefficient for PCA3 & tPSA in Positive Bx | Correlation Coefficient for PCA3 & tPSA in Negative Bx | PCA3 OR (raw, adj) | tPSA OR (raw, adj) | Other Relevant findings
Ochiai103, 2011 | 105 | - | - | p<0.001/<0.001 | p<0.001/0.52 | -
Cao94, 2011 | 131 | 0.079 | 0.372 | 1.075/1.055 | - | -
Perdona31, 2011 | 218 | “low” | “low” | 1.030/1.030 | 1.258/1.239 | Accuracy improves 3%
de la Taille95, 2011 | 516 | 0.042^b^ | 0.042^b^ | 1.020/1.010 | 1.120/1.150 | Accuracy improves 5.5%
Aubin91, 2011 | 1,072 | - | - | 1.019/1.015 | 1.106/1.087 | AUC improves; 69 - 75%

adj = after adjustment for other markers; Bx = prostate biopsy; OR = odds ratio, raw = as observed; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

a Studies ordered by increasing size; rows 3-5 are shaded, indicating studies focusing on the “grey zone” of tPSA.

b Correlation coefficient of 0.042 for all biopsy results.

#### PCA3 and tPSA: ROC Curves-Sensitivity/Specificity

Fourteen studies (Table 13) provided ROC curves for both PCA3 scores and tPSA elevations among men with positive initial screening test results (elevated tPSA with or without positive DRE) who subsequently had positive or negative biopsy results. Two of these studies93,99 reported ROC curves separately for initial and repeat biopsies and, therefore, there are 16 rows/datasets. The performance of PCA3 and tPSA testing are presented in Table 13, sorted from smallest to largest number of enrolled men. For each study, the sensitivities of each marker at preselected false positive (1-specificity) rates were estimated from published ROC curves. These values were recorded to the nearest percent (e.g., sensitivity of 55 percent). The table entries showing test performance are the PCA3 sensitivity, followed, in parentheses, by the incremental increase, or decrease, of tPSA sensitivity. For example, at a false-positive rate (1-specificity) of 20 percent, the first study found a PCA3 sensitivity of 57 percent, which was 19 percent higher than tPSA sensitivity, (i.e., 57 - 19 = 38 percent). Negative numbers indicated that tPSA is performing better; positive numbers indicated PCA3 is performing better.

The last three lines in Table 13 are the median results ignoring matching. That is, the median PCA3 sensitivity is provided along with the median difference computed separately. The first of the three lines summarizes all 13 studies. The next summarizes the four tPSA “grey zone” studies, while the last summarizes the nine remaining studies (non-shaded rows) after the one study90 performed in a mainly black population was removed.

Figure 11 displays the summary ROC curves computed using the PCA3 median sensitivities and median differences provided in the last row of Table 13. This can be taken as a simple summary of performance for the two tests, under similar circumstances in a general population of men with elevated tPSA.

Figure 11 Summary ROC curves for PCA3 and tPSA based on studies applying the tests to the same population

Note: The open circles (solid line) indicates performance of PCA3 scores, while the filled circles (solid line) indicated tPSA performance. The thick dashed line indicated where the sensitivity equals 1-specificity, indicating a test with no predictive ability. Data are presented in Table 13.

Figure 11 examines the summary ROC curves for PCA3 and tPSA based on studies applying the tests to the same population. The X axis represents false positives (1-specificity) and is scored from 0 to 100%. The Y axis represents sensitivity (true positives) and is also scored from 1 to 100%. A dashed line running at 45 degrees through the graph represents the line at which sensitivity equals 1-specificity and the test is noninformative. PCA3 scores are shown in open circles and t PSA lines in solid black circles. Both lines fall in the upper left half of the curve above the dotted line and exhibit values ranging from 1-specificity of 20 to 80%. At each point present, PCA3 is above the curve for tPSA suggesting superior performance.

#### PCA3 and tPSA: Regression Analysis

Two studies31,95 reported sufficient results of regression analysis separately for PCA3 and for tPSA elevations in the same population of men to be included in these analyses. Both studies included in this analysis restricted tPSA levels to less than 10 ng/mL (“grey zone”). Each of the studies reported the odds ratio (OR) for each marker when that marker was assumed to be a continuous variable. That is, the antilog of the OR will be the regression coefficient per unit increase of the marker (e.g., increase of PCA3 score from 30 to 31). This makes comparison of PCA3 and tPSA difficult, as the range of results for the two markers differs. To account for this, the coefficients will be used to compute the ratio of the ORs at the 25^th^ and 75^th^ centiles for each marker. This is a measure of the change in odds over the inter-quartile range. This ratio of ORs for PCA3 will then be divided by the corresponding ratio for tPSA. Values greater than 1 indicates that PCA3 provided more discrimination than tPSA. This normalization also allows for comparisons between studies, where the coefficient is dependent on the range of tPSA values studied.

Only one of the included studies31 provided the inter-quartile ranges for both markers. It was necessary to estimate those ranges for the second study.95 For PCA3, this was done by extrapolating the log mean and SD from two centiles provided as part of the sensitivity/ specificity results. For tPSA, this was done by using the inter-quartile range from the first study31 and adjusting for a minor difference in the mean values reported.

Two additional studies provide some further insight. One91 showed similar coefficients for PCA3 and tPSA, but it was not possible to compute the ratio of the ORs for tPSA because no data were provided to estimate the 25^th^ and 75^th^ centiles. However, given that the inter-quartile range of PCA3 scores were generally larger than the corresponding range of tPSA results, these coefficients were likely to have shown an overall finding of PCA3 being more discriminatory. Another study94 provided only the continuous OR estimates. The PCA3 OR was the highest reported among the four studies in Table 14, and the corresponding OR for tPSA was slightly under 1.0. This would have to be associated with PCA3 being more discriminatory, but estimates of effect size could not be provided because information about the distributions were not provided.

Table 14 Comparison of modeled univariate continuous odds ratios (OR) for PCA3 and tPSA in matched studies

Study Author, Year^a^ | N | PCA3 Regression Coefficients | PCA3 OR @25^th^ Centile | PCA3 OR @75^th^ Centile | Ratio A | tPSA Regression Coefficients | tPSA OR @25^th^ Centile | tPSA OR @75^th^ Centile | Ratio B | Ratio (A/B)
Perdona31, 2011^c^ | 218 | 0.02956 | 1.77 | 8.75 | 4.93 | 0.22952 | 3.48 | 9.0 | 2.50 | 1.97
de la Taille95, 2011^c^ | 516 | 0.01980 | 1.43 | 3.09 | 2.16 | 0.11333 | 1.74^b^ | 8.0^b^ | 1.57 | 1.38
Aubin91, 2010 c | 1,072 | 0.01882 | 1.31 | 2.14 | 1.63 | 0.01882 | - | - | - | -
Cao94, 2011 c | 131 | 0.07232 | - | - | - | 0.07232 | - | - | - | -

N = number; OR = odds ratio; PCA3 = prostate cancer antigen 3 gene; tPSA = total prostate specific antigen

a Both studies used in the analysis only included patients in the tPSA “grey zone.” Rows 1-3 are shaded.

b Ratios A and B are ratios of ORs at 25^th^ and 75^th^ centiles.

c These studies reported insufficient information to compute and/or compare Ratios A and B.

Five studies31,91,94,95,103 provided some information on the independence of PCA3 and tPSA as markers for prostate biopsy status (Table 15). Two specific measures were sought. Thought to be most useful were the bivariate correlations (parametric or non-parametric) between the two markers for those with positive, and for those with negative, prostate biopsies. Alternatively, logistic regression coefficients (or the corresponding ORs) reported with, and without, adjustment for tPSA were evaluated. In many of the studies reporting logistic regression models, additional factors such as history and prostate volume were also included. If both PCA3 and tPSA coefficients remained essentially constant after adjusting for the other marker (and possibly additional markers), this was taken as evidence that the two markers together were more predictive than either alone (independent).

Three studies31,94,95 reported information on correlation coefficients (Table 15). One reported the two correlation coefficients (non-parametric estimates),94 two reported a single merged correlation (parametric)95, and the third just reported that the correlations were “low” for both groups.31 One potential problem with these estimates is that reliable correlation estimates for both PCA3 and tPSA would require a logarithm transformation prior to computing a parameter estimate such as the Pearson's correlation coefficient. None reported that the data were transformed. Overall, the two markers were not highly correlated in either of the groups of interest.

Five studies31,91,94,95,103 provided information on coefficients for PCA3 and/or tPSA from univariate and multivariate logistic regression modeling (Table 15). Four of the five31,91,95,103 found the PCA3 coefficients unchanged after accounting for tPSA (and often other variables as well). The remaining study94 found a reduction in the coefficient, but it was still the most significant predictor. In addition, this study did not include tPSA in the multivariate model, as it was not statistically significant in the univariate logistic regression (p=0.08).

The results were less consistent for tPSA. Three studies31,91,95 found tPSA essentially unchanged after accounting for PCA3. Interestingly, these three studies all restricted tPSA levels to under 10 ng/mL. This may reduce the correlation between the two markers, if PCA3 and tPSA are concordant when tPSA elevations are relatively high. A fourth study103 did not report the coefficients but did report that the p-value was reduced from being highly significant (p<0.001) to no significance (p=0.52). The fifth94 did not report results for tPSA after adjustment, as it only included variables found to be significant in univariate modeling.

#### PCA3 and tPSA Elevations: Diagnostic Accuracy

##### PCA3 and tPSA GRADE Strength of Evidence: LOW

The rationale for “low” follows the GRADE assumption that the high risk of bias in observational studies correlates with a starting strength of evidence of low. The results were deemed to be Consistent, but Indirect. Precision was supported by the ability to observe the expected selection bias of “grey zone” studies and the differences in PCA3 and tPSA performance, but could not be directly measured (e.g., confidence intervals). Strength of association was weak. The results for these domains do not warrant either downgrading to Insufficient or upgrading to moderate.

- Risk of Bias: HIGH
  The quality of individual studies was poor. Three biases were identified that could potentially impact this analysis: partial verification bias, spectrum bias and a sampling bias. Partial verification bias was clearly present for tPSA elevation, but our analyses and a review of the literature indicated that in this setting, the ROC curve was unlikely to be biased (Appendix J). Thus, the focus was towards the ROC and related measurements. Monte Carlo modeling was used to account for the verification bias related to the specific cutoff level at which a certain performance was obtained (Appendix J). Sampling bias was accounted for by stratifying the analyses, when possible. Although there was a relatively high potential for bias to affect select measurements and their interpretation, the measures taken as part of the analyses result in a low risk of those biases influencing the final interpretation. Spectrum bias needs to be considered in addition to the performance estimates (sensitivity, specificity). For example, even though PCA3 has a higher sensitivity at any given specificity, the included studies provided no evidence that those identified as positive with either test had similar or different distribution of disease severity. Although PCA3 appears to be statistically better, it does not necessarily follow that it is clinically superior. Publication bias was informally evaluated and not considered to be an important source of potential bias. However, given the poor quality of all the individual included studies, there is potential for unidentified biases to have occurred.
- Consistency: CONSISTENT
  Overall, analysis showed that PCA3 measurements had higher sensitivity at any specificity compared with tPSA, and higher specificity at any sensitivity. However, it was not possible to formally test for heterogeneity, as original data were not available. No study reported a matched analysis.
- Directness: INDIRECT
  The intermediate outcome of diagnostic accuracy (PCA3 and tPSA) shows both types of indirectness: (1) one body of evidence links the test to the intermediate outcome of diagnostic accuracy and another body of evidence is needed to link the test-related intervention(s) to health outcomes; and (2) based on the lack of matched analyses, it is not possible to determine the extent to which PCA3 and tPSA (or other comparators) are identifying cancer with the same or different characteristics (e.g., aggressiveness) within the spectrum of the disease, and yet another body of evidence is needed to resolve this question.
- Precision: PRECISE
  A formal analysis of precision (e.g., confidence intervals) was not able to be computed due to the matched nature of our analyses and the lack of original data. In one analysis that included 20 studies (AUC difference), it was possible to see the reduction in performance for tPSA in a subset of four “grey zone” studies where the AUC difference expanded to a median of 16 percent, compared with the 8.7 percent found in the 16 studies with no sampling bias.
- Strength of Association: WEAK
  Although there is evidence that PCA3 will be slightly better at identifying high risk individuals with a prostate cancer, both PCA3 and tPSA are relatively weak predictors with low sensitivity and low specificity.

#### PCA3 and tPSA Elevations—Other Intermediate and Long-Term Outcomes

No studies were identified that reported PCA3 and tPSA levels along with specific information on intermediate (impact on decisionmaking about initial or repeat biopsy, biopsy-related harms) or long-term (morbidity/mortality, quality of life, harms) outcomes.

Strength of Evidence: Insufficient

#### Summary of the Remaining KQs 1 and 2 “Combined” Analyses

Table 16 provides a summary of the numbers of available studies available for each comparator and outcome, as well as the domains (see footnotes) and strength of evidence for each. More detailed descriptions of the data and limited findings for all outcomes and all PCA3 comparators can be found in Appendix K.

Table 16 KQs: Summary of available studies and strength of evidence for four outcomes and all PCA3 comparators

Table 16a Available studies, analyses and strength of evidence for the KQ 1 and KQ 2 intermediate outcome of diagnostic accuracy

Comparators | tPSA^a^ | %fPSA^a^ | PSAD^a^ | EVN^a^ | Multivariate Models Including tPSA^a^ | cPSA^a^ | tPSA DT and tPSA Velocity^a^
GRADE: Risk of Bias | High | High | High | High | High | --- | ---
GRADE: Consistency | Consistent, with 22 studies | Inconsistent^b^, with 7 studies | Unknown^b^, with 3 studies | Unknown^b^, with 4 studies | Unknown^b^, with 3 studies | --- | ---
GRADE: Directness | Indirect | Indirect | Indirect | Indirect | Indirect | --- | ---
GRADE: Precision | Precise | Imprecise | Imprecise | Imprecise | Imprecise | --- | ---
GRADE: Strength of Association | Weak | --- | --- | --- | --- | --- | ---
Strength of Evidence (GRADE)^c^ | Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
KQ 1 and KQ 2 Area Under the Curve | n=20^22,24-28,31-40,42-45^ | n=5^23,25-27,32^ | n=3^22,28,36^ | n=3^24,30,37^ | 0 | 0 | 0
Reported Mean/SD | n=8^23,24,26,32,35-37,43^ | n=4^22,26,32,37^ | n=2^22,36^ | 0 | 0 | 0 | 0
Performance at a PCA3 cutoff of 35 | n=9^22,25,28,31-34,36,41^ | n=1^22^ | n=2^22,38^ | n=1^37^ | 0 | 0 | 0
ROC Curves- Sensitivity/ Specificity | n=14^22,24,25-28,31-38,40^ | n=4^23,25,27,32^ | n=3^22,28,36^ | n=2^36,37^ | 0 | 0 | 0
Regression Analysis | n=2^22,37^ | n=3^22,25,37^ | 0 | n=2^24,30^ | n=3^22,25,37^ | 0 | 0

%fPSA = percent free prostate specific antigen; cPSA = complexed prostate specific antigen; DT = doubling time; EVN = externally validated nomograms; PSAD = prostate specific antigen density; tPSA = total prostate specific antigen;

a Corresponds to KQ 1 and KQ 2.

b Consistency could not be assessed due to insufficient data from comparable studies, or because studies did not report results in a consistent manner.

c GRADE assessment of strength of evidence for each outcome for each comparator is based on assessment of the evidence for four domains: [underlined: risk of bias; consistency] of effect size/direction, [underlined: directness] of the evidence-health outcome link; and [underlined: precision] (degree of certainty) of effect estimate. Based on the domains, GRADE strength of evidence categories are Insufficient, Low, Moderate and High.

Table 16b Available studies and strength of evidence for other KQ 1, KQ 2, and KQ 3 intermediate and long-term outcomes

PCA3 Comparators | tPSA Elevations SOE^a^ (N^b^) | % fPSA SOE^a^ (N^b^) | PSA Density SOE^a^ (N^b^) | Externally Validated Nomogram SOE^a^ (N^b^) | tPSA Velocity/Doubling Time SOE^a^ (N^b^) | cPSA SOE^a^ (N^b^)
KQ 1 & 2 intermediate outcome:Impact on biopsy decisionmaking | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 1 & 2 intermediate outcome: Biopsy-related harms | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 1 & 2 long-term outcome: Morbidity, mortality, function, quality of life | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 1 & 2 long-term outcome: Treatment-related harms | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 3 intermediate outcome: Diagnostic accuracy^c^ | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 3 intermediate outcome: Impact on decisionmaking | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 3 intermediate and long-term outcomes: Treatment-related harms | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)
KQ 3 intermediate and long-term outcomes: Health outcomes and surrogates (e.g., biochemical recurrence) | Insufficient^c^ (2) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0) | Insufficient (0)

%fPSA = percent free prostate specific antigen; cPSA = complexed prostate specific antigen; EVN = externally validated nomograms; PSAD = prostate specific antigen density; SOE = GRADE strength of evidence; tPSA = total prostate specific antigen

a GRADE assessment of strength of evidence for each outcome for each comparator is based on assessment of the evidence for four domains: [underlined: risk of bias; consistency] of effect size/direction, [underlined: directness] of the evidence-health outcome link; and [underlined: precision] (degree of certainty) of effect estimate. Based on the domains, GRADE strength of evidence categories are Insufficient, Low, Moderate and High.

b N=Number of studies.

c [underlined: Risk of bias]: High; [underlined: Consistency]: Unknown; [underlined: Directness]: Direct; [underlined: Precision]: Imprecise.

### KQ 3 Testing for PCA3 and Comparators To Identify Patients with Insignificant Cancer Who May Be Candidates for Active Surveillance

KQ 3 presented a complex clinical scenario. Based on the implementation of tPSA screening and followup, many more prostate cancers are being diagnosed early in the natural history of the disease. The result is the diagnosis of a proportion of cancers that would otherwise not have been diagnosed clinically during the men's lifetimes. Effective risk stratification could inform decisions about whether/when treatment is warranted for such cancers. Alternatively, if risk stratification provides sufficient certainty that the tumor poses little risk to life and health, the patient might benefit from active surveillance and delayed treatment if the disease progresses. The importance of effective schemes for risk stratification was reemphasized by the recent Prostate Cancer Intervention versus Observation Trial (PIVOT)123 report on 12 year followup of men with histologically confirmed localized prostate cancer (mean age 67 years, stage T1-T2, any grade, tPSA <50 ng/mL). They found no difference in all-cause or prostate cancer-specific mortality between men assigned to observation (watchful waiting) versus those randomly assigned to radical prostatectomy treatment.

The identified studies for KQ 3 investigated the performance of PCA3 and comparators in placing men with biopsy confirmed prostate cancer into categories of clinical risk or significance. Reviewing these studies was complicated by variability in terminology and definitions. Low risk tumors were variably referred to as “low risk,”94 “indolent,”89,95,100,117 “insignificant,”100,112 or “low volume/low grade.”115,118 High risk tumors were referred to as “intermediate or high risk,”29,94 “significant,”95,100,115,118 “unfavorable,”89 and “aggressive.”118

Ploussard provides a conceptual definition of insignificant disease as “…a low-grade, small-volume, and organ-confined PCa that is unlikely to progress to clinical and biologic significance without treatment,” and that is diagnosed in clinical practice “...in the absence of cancer-related symptoms that would not have caused disease-specific mortality during the patient's life if untreated.” 67 Indolent cancers have been characterized as those identified early in the natural history of prostate cancer, possibly prospectively detected by pathologic criteria using tools such as nomograms, and having a good chance of positive outcome with active/aggressive treatment.14,67 However, these terms have been used interchangeably. We have chosen to use the term “insignificant” to denote the cancers for which active surveillance may be considered.

The first challenge is identifying individuals with insignificant disease who are eligible for active surveillance.20 The most commonly used criteria used to define insignificant cancer are the Epstein criteria (and modifications).66 The key prognostic factors are Gleason score ≤6 without Gleason pattern 4 or 5, organ-confined disease (no extraprostatic extension, seminal vesicle invasion or lymph node involvement) and tumor volume less than 0.5 cubic centimeters (cc) (sometimes less than 0.2 cc).14,66,116 Other criteria may include clinical stage T1c, PSA density less than 0.15 ng/mL/gram, fewer than three positive cores, and less than 50 percent cancer per core.124 NCCN and others suggests a similar definition for “very low risk.”16 D'Amico low risk criteria are tPSA ≤10 ng/mL, clinical stage T1-T2a, and Gleason score ≤6.^125^ This review addresses the potential performance of PCA3 score as a criterion for insignificant disease, but also as a potential marker for an aggressive form of cancer.

The second challenge is determining how to effectively identify progression of disease, to get to a measurable clinical endpoint.20 How effective is the risk classification system in identifying men with insignificant cancer (clinical sensitivity and specificity)? What are the harms related to misclassification? Answering these questions requires for each risk classification (e.g., insignificant/very low risk, low risk, intermediate risk, high risk) specified measures of progression over time, with and without treatment, as well as assessment of harms and all-cause and prostate-cancer-specific mortality rates.

A validation study of Epstein criteria for insignificant disease in European men found that classification by biopsy criteria “may underestimate the true nature of prostate cancer.” At radical prostatectomy, 24 percent of patients with “insignificant” disease had Gleason sum 7-10 scores and 34 percent had non-organ-confined disease.126 A recent systematic review reported on the accuracy of the Epstein criteria in predicting insignificant prostate cancer.127 Five of six studies defined insignificance by biopsy criteria and used concordance with prostatectomy pathology to determine accuracy; one study followed biochemical recurrence-free survival for six years. They found significant heterogeneity among the validation studies that was attributed in part to different criteria, variable application of criteria, and changes in the Gleason scoring system. Lack of clinical followup may also be a factor. They concluded that Epstein criteria have suboptimal accuracy for predicting insignificant prostate cancer and require additional, better quality validation studies127 So, in addition to finding new and most effective markers, better designed validation studies are also needed.

#### Description of Included Studies

The inclusion criteria for KQ 3 were also set to select only matched studies. These are defined as studies that provide estimates of test performance or other outcomes for PCA3 and at least one other comparator using the same sample set. Studies of PCA3 alone, or of other comparators without PCA3, were, therefore, excluded. Thirteen studies were identified that addressed KQ 3 and reported on PCA3 and other preoperative/pretreatment markers for stratifying tumors by risk (Table 17).88,89,94,95,100,112-119 Two studies based analyses on biopsy markers without prostatectomy94,95 and eight reported prostatectomy results as an endpoint.88,100,112,114-116,118,119 Two studies were conducted on subjects with longitudinal data including short-term followup.88,89Tables 1 through Table 4 include descriptive information about these studies. Table 17 provides information and results. Table 18 provides detailed information about the wide variety of markers investigated in these studies for association with low and high risk disease.

Prostatectomy is not useful as an endpoint for determining diagnostic accuracy because it is not a clinical outcome, but rather an intermediate step. Pathological testing of prostatectomy specimens adds data to further assess the tumor as high or low risk, including tumor volume, prostatectomy Gleason score and stage, possible upgrading from biopsy, and other pathological findings (e.g., extracapsular extension, perineural invasion, positive surgical margins). However, the association of PCA3 with these markers, or the ability of PCA3 to predict them at prostatectomy, relates to the determination of risk category, but does not provide the formal evidentiary link between the risk assigned and specific intermediate and long-term clinical outcomes. Without even short-term specified clinical endpoints or validated surrogates, these data cannot be used to provide estimates of diagnostic accuracy.

The included articles address a wide range of comparators (Table 18), many different combinations of criteria defining individuals with “low” or “high” risk prostate cancers, and varying presentations and analyses of the data. However, one result was most consistently reported, and that was an association between PCA3 score and tumor volume (Table 17). Most studied PCA3 and comparators as potential predictors of insignificant cancer, while others reported possible use for identifying aggressive cancer.116,117 Three studies reported that PCA3 was an independent predictor of tumor volume, though cutoffs and endpoints (greater than or less than the 0.5cm^3^ tumor volume cutoff) differed.113,116,119 Five studies113,115,116,118,119 reported higher correlations between PCA3 and tumor volume (r = 0.27 to 0.41; p ≤ 0.04) than for other comparators (e.g., tPSA, %fPSA, PSA density, clinical stage, biopsy Gleason score). Unfortunately, those correlations may be suspect. Most studies did not provide scatterplots of the data. The two that did89,116 clearly show that the data for both PCA3 and tumor volume should be subject to transformation prior to computing the correlation. Figure 12a redisplays data published by Ploussard.116 These data were digitized from a provided figure and should be considered reasonably accurate, but not as reliable as original raw data. This analysis is aimed at demonstrating a more appropriate analytic methodology. The correlation is lower after transformation (but still significant). However, examining the data (Figure 12b), it appears that most of the “prediction” is confined to very high PCA3 scores (>120) associated with very large tumors (>2 cm^3^).

Figure 12a Scatterplot illustrating the correlation between PCA3 scores and tumor volume in prostatectomy specimens on a linear scale (data from Ploussard et al., 2011^116^)

PCA3 = prostate cancer antigen 3 gene

Note: For each subject, PCA3 score is shown on the x-axis and tumor volume in cubic centimeters (cm3) on the y-axis. The highly significant r-squared value (p<0.001) indicates that about 17% of the variability in tumor volume can be accounted for by the range of PCA3 values. However, both measurements (tumor volume and PCA3 score) are highly right-skewed, violating the assumption of being a Gaussian distribution required for the computation of reliable correlation coefficients.

Figure 12a is a scatterplot illustrating the correlation between PCA3 scores and tumor volume in prostatectomy specimens on a linear scale. For each subject, PCA3 score is shown on the x-axis and tumor volume in cubic cemtimeters on the y-axis. The highly significant r-squared value (0.001) indicates thta bout 17% of the variability in tumor volume can be accounted for by the range of PCA3 values. However, both measuremetns (tumor volume and PCA3 score) are highly right-skewed, violating the assumption of being a Gaussian distribution required from the computation of reliable correlation coefficients.

Figure 12b Scatterplot illustrating the correlation between PCA3 scores and tumor volumes in prostatectomy specimens after logarithmic transformation (reanalysis of data from Ploussard et al., 2011^116^)

PCA3 = prostate cancer antigen 3 gene

Note: For each subject, PCA3 score is shown on the logarithmic y-axis and log tumor volume in cubic centimeters (cm3) on the logarithmic x-axis. Both distributions are now reasonably Gaussian and the corresponding r-squared value is reduced to just under 8% of the total variability. This is about half of the value found prior to transformation. In addition, the corresponding p-value is reduced to 0.004; still highly significant.

Figure 12b is a scatterplot illustrating the correclation between PCA3 scores and tumor volumes in prostatectomy specimens after logarithmic transformation. For each subject, PCA3 score is shown on the logarithmic y-axis and log tumor volume in cubic centimeters on the logarithmic x-axis. Both distributions are now reasonably Gaussian and the corresponding r-squared value is reduced to just under 8% of the total variability. This is about half of the value found prior to transformation. In addition the corresponding p=value is reduced to 0.004; still highly significant.

Only two of the studies reviewed for this report had a longitudinal component and described a clinical outcome other than pathological results of prostatectomy.88,89

- Lymph node involvement in a prostate cancer patient is an indicator of poor clinical outcome. One study88 attempted to identify “micrometastases,” based on identifying tumor cells within the lymph nodes that are producing the prostate cancer markers tPSA and PCA3. The method used to quantify these markers in lymph node extracts was real time reverse transcriptase PCR (RT-PCR) for both PCA3 and PSA mRNA. The study followed 120 patients with localized prostate cancer for 4 to 6 years and used biochemical recurrence (any serum tPSA greater than 0.2 ng/mL) as the surrogate outcome of interest. As expected, they found significantly decreased biochemical recurrence free survival among the 11 subjects with histologically confirmed lymph node metastases, compared with 77 subjects with no lymph node involvement. Among the remaining 32 patients with biochemical recurrence, many were identified as having micrometastases based on either tPSA or PCA3 (or both) testing. tPSA had a sensitivity for biochemical recurrence of 73 percent and a false positive rate of 22 percent (p<0.001). PCA3 had a lower detection (42 percent) and a comparable false positive rate (23 percent), but the effect was not significant (p=0.095). While this appears to indicate that PSA testing is more predictive, the use of PSA mRNA as the test, and a rise in serum tPSA levels as the outcome suggests an important risk of bias. The authors provided no information on validation of quantitative testing for these biomarkers in this sample type or on confirmation of the results using a published method.
- Based on no more than 2-year followup of patients in an active surveillance program, Tosoian et al. reported PCA3 and tPSA results (mean, standard deviation, median) for the 38 of 294 patients progressing to treatment based on yearly biopsy results.88,89 Epstein criteria were used for initial enrollment in the surveillance program. Progression to treatment was recommended for “unfavorable” findings, defined as any Gleason pattern 4 or 5, greater than 2 positive biopsy cores, or more than 50 percent involvement of any core with cancer. No difference in PCA3 and tPSA levels was observed between the 13 percent who progressed and those remaining in active surveillance (p=0.13). However, the authors state that only 140 of the 294 study subjects submitted a urine sample, and did not report how many of these 140 men had an unfavorable result on biopsy. This study did not provide matched results for all subjects (partially matched).

No studies were identified that reported on other intermediate outcomes (e.g., diagnostic accuracy, decisionmaking, harms) or long-term clinical outcomes (e.g., mortality/survival, morbidity, quality of life). All studies were judged to be poor quality, mainly due to lack of clinical followup, but also to lack of information on study subjects. Six studies were funded by GenProbe and six disclosed authors with potential conflicts of interest (Table 1); others did not report on source of funding or conflicts of interest (Table 1). The detailed results of assessment of quality of individual studies addressing KQ 3 are presented in Table F-2 in Appendix F.

#### PCA3 and Comparators—Intermediate Outcome: Diagnostic Accuracy

- Risk of Bias: HIGH
  The quality of individual studies was poor. All studies were observational, raising a high potential for biases to have occurred.
- Consistency: UNKNOWN
  No studies were identified that reported on matched data for PCA3 and comparator results, and also reported specific clinical outcomes of patients with tumors characterized as low risk and high risk, who:
  – opted for active surveillance and never progressed to treatment;
  – opted for active surveillance and progressed to treatment; or
  – opted for immediate treatment.
  No effect(s) could be measured.
- Directness: DIRECT
  This should be Direct, as the evidence would ideally determine diagnostic accuracy by linking the risk assignment based on testing/pathological results directly to health outcomes.
- Precision: IMPRECISE
  This cannot be assessed, as no comparisons were possible based on the two studies of different populations, using different assays, and reporting different surrogate outcomes.

Strength of Evidence: Insufficient

Strength of evidence could not be evaluated. Only two studies were identified, and they did not perform the studies in the same setting, have the same sample type or have comparable outcome measures.

#### PCA3 and Comparators—Intermediate Outcome: Impact on Decisionmaking

No studies were identified that reported PCA3 and comparator results and intermediate outcome data (e.g., physician or patient surveys, chart review) on the degree to which PCA3 or comparator test results and categorization of risk as high or low impacted decisions made with regard to selection of active surveillance versus aggressive treatment.

Strength of Evidence: Insufficient

#### PCA3 and Comparators—Intermediate and Long-Term Outcome: Treatment-Related Harms

Studies have been conducted that document treatment-related clinical harms such as incontinence and impotence. Based on general studies on potential psychosocial harms of diagnostic testing, it is possible to generalize that patients facing treatments such as radical prostatectomy might also experience anxiety or perceive a reduction in quality of life. However, no studies were identified that reported PCA3 and comparator test results and intermediate outcome data (e.g., physician or patient-reported adverse events, biochemical recurrence, progression to treatment) on the degree to which categorization of risk as high or low and choice of active surveillance or treatment related to the occurrence of adverse clinical events.

Strength of Evidence: Insufficient

#### PCA3 and Comparators—Intermediate and Long-Term Health Outcomes

No studies were identified that reported PCA3 and comparator results and the association of low and high risk categorization with long-term outcomes such as mortality/survival and morbidity (e.g., function, quality of life) of the selected course of management or treatment. However, two poor quality studies reported on relatively short-term health outcomes, biochemical recurrence and progression from surveillance to treatment in an active surveillance program.

Strength of Evidence: Insufficient