# References

1 Jemal A, Siegel R, Xu J, et al. Cancer statistics, 2010. CA Cancer J Clin. Sep-Oct. 2010;60(5):277-300. [pmid: 20610543].
2 Brawley OW. Prostate cancer epidemiology in the United States. World J Urol. Apr. 2012;30(2):195-200. [pmid: 22476558].
3 Sutcliffe P, Hummel S, Simpson E, Young T, Rees A, Wilkinson A, Hamdy F, Clarke N, Staffurth J. Use of classical and novel biomarkers as prognostic risk factors for localised prostate cancer: a systematic review. Health Technol Assess. 2009;13:1-260. [pmid: 19128541].
4 Arcangeli S, Pinzi V, Arcangeli G. Epidemiology of prostate cancer and treatment remarks. World J Radiol. Jun. 28. 2012;4(6):241-6. [pmid: 22778875].
5 National Comprehensive Cancer Network. Guidelines - Prostate Cancer Early Detection, Version I. 2011. www.NCCN.org.
6 Gronberg H. Prostate cancer epidemiology. Lancet. Mar. 8. 2003;361(9360):859-64. [pmid: 12642065].
7 Freedland SJ. Screening, risk assessment, and the approach to therapy in patients with prostate cancer. Cancer. Mar. 15. 2011;117(6):1123-35. [pmid: 20960523].
8 Ilic D, O'Connor D, Green S, et al. Screening for prostate cancer: an updated Cochrane systematic review. BJU Int. 2011;107(6):882-91. [pmid: 21392207].
9 Yin M, Bastacky S, Chandran U, et al. Prevalence of incidental prostate cancer in the general population: a study of healthy organ donors. J Urol. Mar. 2008;179(3):892-5. discussion 95. [pmid: 18207193].
10 SEER Cancer Statistics Review, 1975-2005. 2008. National Cancer Institute. Bethesda, MD. seer.cancer.gov/csr/1975_2005/.
11 Draisma G, Boer R, Otto SJ, et al. Lead times and overdetection due to prostate-specific antigen screening: estimates from the European Randomized Study of Screening for Prostate Cancer. J Natl Cancer Inst. 2003;95(12):868-78. [pmid: 12813170].
12 Basch E, Oliver TK, Vickers A, et al. Screening for Prostate Cancer With Prostate-Specific Antigen Testing: American Society of Clinical Oncology Provisional Clinical Opinion. J Clin Oncol. 2012. Jul. 16. [pmid: 22802323].
13 Catalona WJ, Smith DS, Ratliff TL, et al. Measurement of prostate-specific antigen in serum as a screening test for prostate cancer. N Engl J Med. Apr. 25. 1991;324(17):1156-61. [pmid: 1707140].
14 Bastian PJ, Carter BH, Bjartell A, et al. Insignificant prostate cancer and active surveillance: from definition to clinical implications. European urology. Jun. 2009;55(6):1321-30. [pmid: 19286302].
15 Schroder F, Kattan MW. The comparability of models for predicting the risk of a positive prostate biopsy with prostate-specific antigen alone: a systematic review. European urology. Aug. 2008;54(2):274-90. [pmid: 18511177].
16 Carter HB. Management of low (favourable)-risk prostate cancer. BJU Int. Dec. 2011;108(11):1684-95. [pmid: 22077546].
17 Etzioni R, Tsodikov A, Mariotto A, et al. Quantifying the role of PSA screening in the US prostate cancer mortality decline. Cancer causes & control : CCC. Mar. 2008;19(2):175-81. [pmid: 18027095].
18 Boyle P. Screening for prostate cancer: have you had your cholesterol measured?. BJU Int. Aug. 2003;92(3):191-9. [pmid: 12887466].
19 Chou R, Croswell JM, Dana T, et al. Screening for prostate cancer: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 6. 2011;155(11):762-71. [pmid: 21984740].
20 Cooperberg MR, Carroll PR, Klotz L. Active surveillance for prostate cancer: progress and promise. J Clin Oncol. Sep. 20. 2011;29(27):3669-76. [pmid: 21825257].
21 Moyer VAon behalf of the USPSTF. Screening for Prostate Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. Jul. 17. 2012;157(2):120-34. [pmid: 22801674].
22 Wolf AMD, Wender RC, Etzioni RB, et al. American Cancer Society Guideline for the Early Detection of Prostate Cancer: Update 2010. CA Cancer J Clin. 2011;60:70-98. PMID:. [pmid: 20200110].
23 Prostate-Specific Antigen Best Practice Statement: 2009 Update. American Urological Association. www.auanet.org/content/media/psa09.pdf.
24 Rosenthal SA, Sandler HM. Treatment strategies for high-risk locally advanced prostate cancer. Nat Rev Urol. Jan. 2010;7(1):31-8. [pmid: 20062072].
25 Thompson IM, Ankerst DP, Chi C, et al. Assessing prostate cancer risk: results from the Prostate Cancer Prevention Trial. J Natl Cancer Inst. Apr. 19. 2006;98(8):529-34. [pmid: 16622122].
26 Amling CL, Catalona WJ, Klein EA. Deciding whom to biopsy. Urol Oncol. Sep-Oct. 2010;28(5):542-5. [pmid: 20816613].
27 Simmons MN, Berglund RK, Jones JS. A practical guide to prostate cancer diagnosis and management. Cleve Clin J Med. 2011;78(5):321-31. [pmid: 21536828].
28 Djavan B, Waldert M, Zlotta A, et al. Safety and morbidity of first and repeat transrectal ultrasound guided prostate needle biopsies: results of a prospective European prostate cancer detection study. J Urol. Sep. 2001;166(3):856-60. [pmid: 11490233].
29 D' Amico AV, Whittington R, Malkowicz SB, et al. Biochemical outcome after radical prostatectomy, external beam radiation therapy, or interstitial radiation therapy for clincally localized prostate cancer. JAMA. Sep. 16. 1998;280(11):969-74. [pmid: 9749478].
30 Epstein JI, Walsh PC, Carmichael M, et al. Pathologic and clinical findings to predict tumor extert of nonpalpable (stage T1c) prostate cancer. Jama. 1994;271:368-74. PMID:. [pmid: 7506797].
31 Perdona S, Cavadas V, Di Lorenzo G, et al. Prostate cancer detection in the “grey area” of prostate-specific antigen below 10 ng/ml: head-to-head comparison of the updated PCPT calculator and Chun's nomogram, two risk estimators incorporating prostate cancer antigen 3. Eur Urol. Jan. 2011;59(1):81-7. [pmid: 20947244].
32 Dahabreh IJ, Chung M, Balk EM, et al. Active surveillance in men with localized prostate cancer: a systematic review. Ann Intern Med. Apr. 17. 2012;156(8):582-90. [pmid: 22351515].
33 Cheng L, Montironi R, Bostwick DG, et al. Staging of prostate cancer. Histopathology. Jan. 2012;60(1):87-117. [pmid: 22212080].
34 Chun FK, de la Taille A, van Poppel H, et al. Prostate cancer gene 3 (PCA3): development and internal validation of a novel biopsy nomogram. Eur Urol. Oct. 2009;56(4):659-67. [pmid: 19304372].
35 Eastham JA, Scardino PT, Kattan MW. Predicting an optimal outcome after radical prostatectomy: the trifecta nomogram. J Urol. Jun. 2008;179(6):2207-10. discussion 10-1. [pmid: 18423693].
36 Huang Y, Isharwal S, Haese A, et al. Prediction of patient-specific risk and percentile cohort risk of pathological stage outcome using continuous prostate-specific antigen measurement, clinical stage and biopsy Gleason score. BJU Int. May. 2011;107(10):1562-9. [pmid: 20875091].
37 Boorjian SA, Karnes RJ, Viterbo R, et al. Long-term survival after radical prostatectomy versus external-beam radiotherapy for patients with high-risk prostate cancer. Cancer. Jul. 1. 2011;117(13):2883-91. [pmid: 21692049].
38 Hinnen KA, Roeloffzen EM, Battermann JJ, et al. Survival after prostate brachytherapy in patients aged 60 years and younger. BJU Int. June. 2011;107(12):1906-11. [pmid: 21062393].
39 Bussemakers MJ, van Bokhoven A, Verhaegh GW, et al. DD3: a new prostate-specific gene, highly overexpressed in prostate cancer. Cancer Res. Dec. 1. 1999;59(23):5975-9. [pmid: 10606244].
40 Durand X, Moutereau S, Xylinas E, et al. Progensa PCA3 test for prostate cancer. Expert Rev Mol Diagn. Mar. 2011;11(2):137-44. [pmid: 21405964].
41 Makarov DV, Loeb S, Getzenberg RH, et al. Biomarkers for prostate cancer. Ann Rev Medicine. 2009;60:139-51. [pmid: 18947298].
42 de Kok JB, Verhaegh GW, Roelofs RW, et al. DD3(PCA3), a very sensitive and specific marker to detect prostate tumors. Cancer Res. May. 1. 2002;62(9):2695-8. [pmid: 11980670].
43 Meng FJ, Shan A, Jin L, et al. The expression of a variant prostate-specific antigen in human prostate. Cancer Epidemiol Biomarkers Prev. Mar. 2002;11(3):305-9. [pmid: 11895882].
44 Day JR, Jost M, Reynolds MA, et al. PCA3: from basic molecular science to the clinical lab. Cancer Lett. Feb. 1. 2011;301(1):1-6. [pmid: 21093148].
45 de la Taille A. Progensa PCA3 test for prostate cancer detection. Expert Rev Mol Diagn. Sep. 2007;7(5):491-7. [pmid: 17892357].
46 Hessels D, Klein Gunnewiek JM, van Oort I, et al. DD3(PCA3)-based molecular urine analysis for the diagnosis of prostate cancer. Eur Urol. Jul. 2003;44(1):8-15. discussion 15-6. [pmid: 12814669].
47 Groskopf J, Aubin SM, Deras IL, et al. APTIMA PCA3 molecular urine test: development of a method to aid in the diagnosis of prostate cancer. Clin Chem. Jun. 2006;52(6):1089-95. [pmid: 16627561].
48 Sokoll LJ, Ellis W, Lange P, et al. A multicenter evaluation of the PCA3 molecular urine test: pre-analytical effects, analytical performance, and diagnostic accuracy. Clin Chim Acta. Mar. 2008;389(1-2):1-6. [pmid: 18061575].
49 Thompson IM, Ankerst DP, Chi C, et al. Operating characteristics of prostate-specific antigen in men with an initial PSA level of 3.0 ng/ml or lower. JAMA. Jul. 6. 2005;294(1):66-70. [pmid: 15998892].
50 Oesterling JE, Jacobsen SJ, Chute CG, et al. Serum prostate-specific antigen in a community-based population of healthy men. Establishment of age-specific reference ranges. JAMA. Aug. 18. 1993;270(7):860-4. [pmid: 7688054].
51 Sokoll LJ, Witte DL, Klee GG, et al. Redesigned proficiency testing materials improve survey outcomes for prostate-specific antigen. Arch Pathol Lab Med. 2000;124:1608-13. PMID:. [pmid: 11079010].
52 Schreiber WE, Endres DB, McDowell GA, et al. Comparison of fresh frozen serum to proficiency testing material in College of American Pathologists surveys: alpha-fetoprotein, carcinoembryonic antigen, human chorionic gonadotropin, and prostate-specific antigen. Arch Pathol Lab Med. 2005;129:331-337. PMID:. [pmid: 15737027].
53 Garg UC, Howanitz JH, Nakamura RM, et al. Production, analysis, and characterization of reference materials for prostate-specific antigen. Arch Pathol Lab Med. 1995;119:1104-08. PMID:. [pmid: 7503657].
54 Klee GG, Schryver PG, Kisabith RM. Analytic bias specifications based on the analysis of effects on performance of medical guidelines. Scand J Clin Lab Invest. 1999;59:509-12. PMID:. [pmid: 10667688].
55 Westgard JO, Westgard SA. An assessment of metrics for analytic quality using σ performance data from proficiency testing surveys and the CLIA criteria for acceptable performance. Am J Clin Pathol. 2006;125:343-54. PMID:. [pmid: 16613337].
56 Tosoian J, Loeb S. PSA and beyond: the past, present, and future of investigative biomarkers for prostate cancer. Sci World J. 2010;10:1919-31. [pmid: 20890581].
57 Roddam AW, Duffy MJ, Hamdy FC, et al. Use of prostate-specific antigen (PSA) isoforms for the detection of prostate cancer in men with a PSA level of 2-10 ng/ml: systematic review and meta-analysis. Eur Urol. Sep. 2005;48(3):386-99. discussion 98-9. [pmid: 15982797].
58 Lee R, Localio AR, Armstrong K, et al. A meta-analysis of the performance characteristics of the free prostate-specific antigen test. Urology. Apr. 2006;67(4):762-8. [pmid: 16600352].
59 Benson MC, Whang IS, Pantuck A, et al. Prostate specific antigen densivity; a means of distinguishing benigh prostatic hypertrophy and prostate cancer. J Urol. 1992;147:815-16. PMID:. [pmid: 1371554].
60 Giannarini G, Scott CA, Moro U, et al. Are PSA density and PSA density of the transition zone more accurate than PSA in predicting the pathological stage of clinically localized prostate cancer?. Urol Oncol. Jul-Aug. 2008;26(4):353-60. [pmid: 18367100].
61 Kundu SD, Roehl KA, Yu X, et al. Prostate specific antigen density correlates with features of prostate cancer aggressiveness. J Urol. Feb. 2007;177(2):505-09. [pmid: 17222621].
62 Thanigasalam R, Mancuso P, Tsao K, et al. Prostate-specific antigen velocity (PSAV): a practical role for PSA?. ANZ journal of surgery. Oct. 2009;79(10):703-6. [pmid: 19878164].
63 Vickers AJ, Savage C, O'Brien MF, et al. Systematic review of pretreatment prostate-specific antigen velocity and doubling time as predictors for prostate cancer. J Clin Oncol. Jan. 20. 2009;27(3):398-403. [pmid: 19064972].
64 Vickers AJ, Brewster SF. PSA Velocity and Doubling Time in Diagnosis and Prognosis of Prostate Cancer. Br J Med Surg Urol. Jul. 1. 2012;5(4):162-68. [pmid: 22712027].
65 Ankerst DP, Groskopf J, Day JR, et al. Predicting prostate cancer risk through incorporation of prostate cancer gene 3. J Urol. Oct. 2008;180(4):1303-8. discussion 08. [pmid: 18707724].
66 Epstein JI, Chan DW, Sokoll LJ, et al. Nonpalpable stage T1c prostate cancer: prediction of insignificant disease using free/total prostate specific antigen levels and needle biopsy findings. J Urol. Dec. 1998;160(6 Pt 2):2407-11. [pmid: 9817393].
67 Ploussard G, Epstein JI, Montironi R, et al. The contemporary concept of significant versus insignificant prostate cancer. Eur Urol. Aug. 2011;60(2):291-303. [pmid: 21601982].
68 D'Amico AV, Cote K, Loffredo M, et al. Determinants of prostate cancer-specific survival after radiation therapy for patients with clinically localized prostate cancer. J Clin Oncol. Dec. 1. 2002;20(23):4567-73. [pmid: 12454114].
69 Schroder FH, Hugosson J, Roobol MJ, et al. Prostate-cancer mortality at 11 years of follow-up. N Engl J Med. Mar. 15. 2012;366(11):981-90. [pmid: 22417251].
70 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. AHRQ Publication No. 10(11)-EHC063-EF. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.
71 Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. effectivehealthcare.ahrq.gov/ehc/products/246/558/Methods-Guide-for-Medical-Test-Reviews_Full-Guide_20120530.pdf.
72 Jüni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 1. 2002;31(1):115-23. [pmid: 11914306].
73 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
74 U.S. Preventive Services Task Force Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. July. 2008. AHRQ Publication No. 08-051180-EF.
75 Higgins JPT, Deeks JJ, Altman DG, on behalf of the Cochrane Statistical Methods Group. Special topics in statistics. Cochrane Handbook for Systematic Reviews of Interventions. Higgins JPT, Green S, editors. West Sussex, England. Wiley-Blackwell. 2010:481-529.
76 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6(Mar 6):529-36. [pmid: 16519814].
77 Begg CB, Greenes RA. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. Mar. 1983;39(1):207-13. [pmid: 6871349].
78 Punglia RS, D'Amico AV, Catalona WJ, et al. Effect of verification bias on screening for prostate cancer by measurement of prostate-specific antigen. N Engl J Med. Jul. 24. 2003;349(4):335-42. [pmid: 12878740].
79 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
80 Ruiz-Aragon J, Marquez-Pelaez S. Assessment of the PCA3 test for prostate cancer diagnosis: a systematic review and meta-analysis. Actas urologicas espanolas. Apr. 2010;34(4):346-55. [pmid: 20470697].
81 Auprich M, Haese A, Walz J, et al. External validation of urinary PCA3-based nomograms to individually predict prostate biopsy outcome. Eur Urol. Nov. 2010;58(5):727-32. [pmid: 20619529].
82 Haese A, de la Taille A, van Poppel H, et al. Clinical utility of the PCA3 urine assay in European men scheduled for repeat biopsy. Eur Urol. Nov. 2008;54(5):1081-8. [pmid: 18602209].
83 Marks LS, Fradet Y, Deras IL, et al. PCA3 molecular urine assay for prostate cancer in men undergoing repeat biopsy. Urology. Mar. 2007;69(3):532-5. [pmid: 17382159].
84 van Gils MP, Hessels D, van Hooij O, et al. The time-resolved fluorescence-based PCA3 test on urinary sediments after digital rectal examination; a Dutch multicenter validation of the diagnostic performance. Clin Cancer Res. Feb. 1. 2007;13(3):939-43. [pmid: 17289888].
85 Fradet Y, Saad F, Aprikian A, et al. uPM3, a new molecular urine test for the detection of prostate cancer. Urology. Aug. 2004;64(2):311-5. discussion 15-6. [pmid: 15302485].
86 Tinzl M, Marberger M, Horvath S, et al. DD3PCA3 RNA analysis in urine--a new perspective for detecting prostate cancer. Eur Uroly. Aug. 2004;46(2):182-6. discussion 87. [pmid: 15245811].
87 van Gils MP, Hessels D, Hulsbergen-van de Kaa CA, et al. Detailed analysis of histopathological parameters in radical prostatectomy specimens and PCA3 urine test results. Prostate. Aug. 1. 2008;68(11):1215-22. [pmid: 18500693].
88 Kusuda Y, Miyake H, Kurahashi T, et al. Assessment of optimal target genes for detecting micrometastases in pelvic lymph nodes in patients with prostate cancer undergoing radical prostatectomy by real-time reverse transcriptase-polymerase chain reaction. Urol Oncol. 2011. May. 18. [pmid: 21600799].
89 Tosoian JJ, Loeb S, Kettermann A, et al. Accuracy of PCA3 measurement in predicting short-term biopsy progression in an active surveillance program. J Urol. Feb. 2010;183(2):534-8. [pmid: 20006883].
90 Adam A, Engelbrecht MJ, Bornman MS, et al. The role of the PCA3 assay in predicting prostate biopsy outcome in a South African setting. BJU Intl. 2011. Apr. 20. [pmid: 21507188].
91 Aubin SM, Reid J, Sarno MJ, et al. PCA3 molecular urine test for predicting repeat prostate biopsy outcome in populations at risk: validation in the placebo arm of the dutasteride REDUCE trial. J Urol. Nov. 2010;184(5):1947-52. [pmid: 20850153].
92 Auprich M, Augustin H, Budaus L, et al. A comparative performance analysis of total prostate-specific antigen, percentage free prostate-specific antigen, prostate-specific antigen velocity and urinary prostate cancer gene 3 in the first, second and third repeat prostate biopsy. BJU Int. Jun. 2012;109(11):1627-35. [pmid: 21939492].
93 Bollito E, De Luca S, Cicilano M, et al. Prostate cancer gene 3 urine assay cutoff in diagnosis of prostate cancer: a validation study on an Italian patient population undergoing first and repeat biopsy. Anal Quant Cytol Histol. Apr. 2012;34(2):96-104. [pmid: 22611765].
94 Cao DL, Ye DW, Zhang HL, et al. A multiplex model of combining gene-based, protein-based, and metabolite-based with positive and negative markers in urine for the early diagnosis of prostate cancer. Prostate. May. 15. 2011;71(7):700-10. [pmid: 20957673].
95 de la Taille A, Irani J, Graefen M, et al. Clinical evaluation of the PCA3 assay in guiding initial biopsy decisions. J Urol. Jun. 2011;185(6):2119-25. [pmid: 21496856].
96 Deras IL, Aubin SM, Blase A, et al. PCA3: a molecular urine assay for predicting prostate biopsy outcome. J Urol. Apr. 2008;179(4):1587-92. [pmid: 18295257].
97 U.S. Food and Drug Administration. Summary of Safety and Effectiveness Data: PROGENSA PCA3 Assay. 2012. www.accessdata.fda.gov/cdrh_docs/pdf10/P100033b.pdf.
98 Ferro M, Bruzzese D, Perdona S, et al. Predicting prostate biopsy outcome: prostate health index (phi) and prostate cancer antigen 3 (PCA3) are useful biomarkers. Clin Chim Acta. Aug. 16. 2012;413(15-16):1274-8. [pmid: 22542564].
99 Goode RR, Marshall SJ, Duff M, et al. Use of PCA3 in detecting prostate cancer in initial and repeat prostate biopsy patients. Prostate. 2012. May. 14. [pmid: 22585386].
100 Hessels D, van Gils MP, van Hooij O, et al. Predictive value of PCA3 in urinary sediments in determining clinico-pathological characteristics of prostate cancer. Prostate. Jan. 1. 2010;70(1):10-6. [pmid: 19708043].
101 Mearini E, Antognelli C, Del Buono C, et al. The combination of urine DD3(PCA3) mRNA and PSA mRNA as molecular markers of prostate cancer. Biomarkers. Jun. 2009;14(4):235-43. [pmid: 19489685].
102 Nyberg M, Ulmert D, Lindgren A, et al. PCA3 as a diagnostic marker for prostate cancer: a validation study on a Swedish patient population. Scand J Urol Nephrol. Dec. 2010;44(6):378-83. [pmid: 20961267].
103 Ochiai A, Okihara K, Kamoi K, et al. Prostate cancer gene 3 urine assay for prostate cancer in Japanese men undergoing prostate biopsy. Int J Urol. Mar. 2011;18(3):200-5. [pmid: 21332814].
104 Ouyang B, Bracken B, Burke B, et al. A duplex quantitative polymerase chain reaction assay based on quantification of alpha-methylacyl-CoA racemase transcripts and prostate cancer antigen 3 in urine sediments improved diagnostic accuracy for prostate cancer. J Urol. Jun. 2009;181(6):2508-13. discussion 13-4. [pmid: 19371911].
105 Pepe P, Aragona F. PCA3 score vs PSA free/total accuracy in prostate cancer diagnosis at repeat saturation biopsy. Anticancer Res. Dec. 2011;31(12):4445-9. [pmid: 22199313].
106 Ploussard G, Haese A, Van Poppel H, et al. The prostate cancer gene 3 (PCA3) urine test in men with previous negative biopsies: does free-to-total prostate-specific antigen ratio influence the performance of the PCA3 score in predicting positive biopsies?. BJU Int. Oct. 2010;106(8):1143-7. [pmid: 20230386].
107 Rigau M, Morote J, Mir MC, et al. PSGR and PCA3 as biomarkers for the detection of prostate cancer in urine. Prostate. Dec. 1. 2010;70(16):1760-7. [pmid: 20672322].
108 Roobol MJ, Schroder FH, van Leeuwen P, et al. Performance of the prostate cancer antigen 3 (PCA3) gene and prostate-specific antigen in prescreened men: exploring the value of PCA3 for a first-line diagnostic test. European urology. Oct. 2010;58(6):475-81. [pmid: 20637539].
109 Schilling D, Hennenlotter J, Munz M, et al. Interpretation of the prostate cancer gene 3 in reference to the individual clinical background: implications for daily practice. Urol Int. 2010;85(2):159-65. [pmid: 20424427].
110 Wang R, Chinnaiyan AM, Dunn RL, et al. Rational approach to implementation of prostate cancer antigen 3 into clinical care. Cancer. Sep. 1. 2009;115(17):3879-86. [pmid: 19517474].
111 Wu AK, Reese AC, Cooperberg MR, et al. Utility of PCA3 in patients undergoing repeat biopsy for prostate cancer. Prostate Cancer Prostatic Dis. Mar. 2012;15(1):100-5. [pmid: 22042252].
112 Auprich M, Chun FK, Ward JF, et al. Critical assessment of preoperative urinary prostate cancer antigen 3 on the accuracy of prostate cancer staging. Euro Urol. Jan. 2011;59(1):96-105. [pmid: 20980098].
113 Durand X, Xylinas E, Radulescu C, et al. The value of urinary prostate cancer gene 3 (PCA3) scores in predicting pathological features at radical prostatectomy. BJU Int. Jul. 2012;110(1):43-49. [pmid: 22221521].
114 Liss MA, Santos R, Osann K, et al. PCA3 molecular urine assay for prostate cancer: association with pathologic features and impact of collection protocols. World J Urol. Oct. 2011;29(5):683-8. [pmid: 21152924].
115 Nakanishi H, Groskopf J, Fritsche HA, et al. PCA3 molecular urine assay correlates with prostate cancer tumor volume: implication in selecting candidates for active surveillance. J Urol. May. 2008;179(5):1804-9. discussion 09-10. [pmid: 18353398].
116 Ploussard G, Durand X, Xylinas E, et al. Prostate cancer antigen 3 score accurately predicts tumour volume and might help in selecting prostate cancer patients for active surveillance. European urology. Mar. 2011;59(3):422-9. [pmid: 21156337].
117 van Poppel H, Haese A, Graefen M, et al. The relationship between Prostate CAncer gene 3 (PCA3) and prostate cancer significance. BJU Int. Feb. 2012;109(3):360-6. [pmid: 21883822].
118 Vlaeminck-Guillem V, Devonec M, Colombel M, et al. Urinary PCA3 score predicts prostate cancer multifocality. J Urol. Apr. 2011;185(4):1234-9. [pmid: 21334023].
119 Whitman EJ, Groskopf J, Ali A, et al. PCA3 score before radical prostatectomy predicts extracapsular extension and tumor volume. J Urol. Nov. 2008;180(5):1975-8. discussion 78-9. [pmid: 18801539].
120 Roddam AW, Hamdy FC, Allen NE, et al. The impact of reducing the prostate-specific antigen threshold and including isoform reflex tests on the performance characteristics of a prostate-cancer detection programme. BJU Int. Sep. 2007;100(3):514-7. [pmid: 17542987].
121 Otto SJ, Moss SM, Maattanen L, et al. PSA levels and cancer detection rate by centre in the European Randomized Study of Screening for Prostate Cancer. Eur J Cancer. Nov. 2010;46(17):3053-60. [pmid: 21047586].
122 Hozo SP, Djulbegovic B, Hozo I. Estimating the mean and variance from the median, range, and the size of a sample. BMC Med Res Methodol. 2005;5:17. [pmid: 15882470].
123 Wilt TJ, Brawer MK, Jones KM, et al. Radical prostatectomy versus observation for localized prostate cancer. N Engl J Med. Jul. 19. 2012;367(3):203-13. [pmid: 22808955].
124 Epstein JI, Walsh PC, Carmichael M, et al. Pathologic and clinical findings to predict tumor extent of nonpalpable (stage T1c) prostate cancer. JAMA. Feb. 2. 1994;271(5):368-74. [pmid: 7506797].
125 Boorjian SA, Karnes RJ, Rangel LJ, et al. Mayo Clinic validation of the D'amico risk group classification for predicting survival following radical prostatectomy. J Urol. Apr. 2008;179(4):1354-60. discussion 60-1. [pmid: 18289596].
126 Jeldres C, Suardi N, Walz J, et al. Validation of the contemporary epstein criteria for insignificant prostate cancer in European men. Eur Urol. Dec. 2008;54(6):1306-13. [pmid: 18083294].
127 Oon SF, Watson RW, O'Leary JJ, et al. Epstein criteria for insignificant prostate cancer. BJU Int. Aug. 2011;108(4):518-25. [pmid: 21320276].
128 Laxman B, Morris DS, Yu J, et al. A first-generation multiplex biomarker analysis of urine for the early detection of prostate cancer. Cancer Res. Feb. 1. 2008;68(3):645-9. [pmid: 18245462].
129 Shappell SB, Fulmer J, Arguello D, et al. PCA3 urine mRNA testing for prostate carcinoma: patterns of use by community urologists and assay performance in reference laboratory setting. Urology. Feb. 2009;73(2):363-8. [pmid: 18995890].
130 Wang Y, Sun G, Pan JG, et al. Performance of tPSA and f/tPSA for prostate cancer in Chinese. A systematic review and meta-analysis. Prostate Cancer Prostatic Dis. 2006;9(4):374-8. [pmid: 16926855].