# Introduction

## Background

### Burden of Illness

Prostate cancer is the most commonly diagnosed non-skin cancer and the second leading cause of cancer death in the United States.1,2 In 2010, there were 217,730 new cases of prostate cancer in the U.S. and about 32,000 prostate cancer-related deaths.1 More than 60 percent of cases occur in men 70 years of age or older.2,3 Established risk factors for prostate cancer are increasing age, family history and race/ethnicity.2-4 Family history in an affected brother, father or multiple family members, significantly increases the risk of developing prostate cancer.2,5 Black/African American men are 1.6 times more likely to be diagnosed with prostate cancer and have a 2.5 times higher risk of prostate cancer-related death.2,5 Asian American and Native American men have significantly lower risk.2,5 Other risk factors (e.g., dietary factors, increased hormone levels, familial disposition) have been proposed but not clearly established.2-4,6

The disease is unpredictable, with the rate of tumor growth varying from very slow to moderately fast.5,7 Most patients have slow-growing tumors, and may live for years with no or minimal effects, ultimately dying of other causes.5,7,8 Although the lifetime risk of being diagnosed with prostate cancer is 16 percent, the lifetime risk of dying from the disease is only 3 percent.2,5,9 Even more striking is the prevalence of occult disease. About one-third of men older than age 60, and half of men older than age 70, were found to have prostate cancer at autopsy.5,10

However, some patients have aggressive tumors that spread beyond the prostate, resulting in significant morbidity and death. Therefore, the key diagnostic challenge in dealing with prostate cancer is deciding which patients to biopsy and when. The most pressing challenge in managing clinically localized disease is distinguishing between men who have aggressive disease and need aggressive therapy and men who have less aggressive disease and can be safely managed by active surveillance.

### Screening for Prostate Cancer

Production of serum total PSA (tPSA) was found to be increased in men with prostate cancer, with elevation of tPSA preceding clinical disease by as much as 5 to 10 years.11 Screening programs that used the tPSA test have been in place since the early 1990s, with the rationale of reducing the prevalence of advanced prostate cancer and prostate cancer-related mortality through early detection, and improving quality of life.5,12,13 Over time, concerns have been raised about both false-positive tPSA screening results (overdiagnosis) and false-negative results (missed diagnosis). Overdiagnosis has been defined as detection by screening of disease that would not have become symptomatic or clinically significant.14 Men with false-positive screening results may undergo one or more biopsies with negative results, raising the potential for adverse events.

It has been estimated that as many as 75 percent of eligible men in the U.S. have undergone at least one tPSA test.15 However, the balance of benefits and harms of tPSA screening remains controversial. Prostate cancer-related mortality has decreased by about 40 percent after screening implementation (1991 to 2007).1,2,16,17 It is not known how much this drop in mortality can be attributed to screening, and how much part aggressive and improved treatment, or to other factors such as increased risk of death being attributed to other chronic illnesses (e.g., heart disease).2,18-20 Wider availability of screening has also resulted in a notable rise in prostate cancer incidence, and in men being diagnosed at an earlier age and cancer stage (i.e., localized disease).2,4,10 False positives related to the poor specificity of the test, and treatment of increased numbers of men with early stage disease, have contributed to concerns about the health benefits of tPSA screening. Based on an updated systematic review of the available evidence19, the U.S. Preventive Services Taskforce recently released a draft recommendation against tPSA screening in asymptomatic men in the general U.S. population.21 They concluded with “…moderate certainty that the harms of PSA-based screening for prostate cancer outweigh the benefits.”21

Several professional associations guidelines have supported tPSA screening in asymptomatic men age 50 years of age or older, and in younger men in higher-risk populations.5,12,22,23 Potential harms have been acknowledged, and “routine” screening not necessarily proposed, but it has been recommended that men be provided with information on the potential risks and benefits of tPSA screening, and then allowed to make a decision about screening in consultation with their physician.

### Diagnosis and Management of Prostate Cancer

Clinical action points for tPSA screening results have ranged from 2.5 to 10 ng/mL, with 4 ng/mL commonly used as defined in the initial FDA approval for this intended use. Criteria for immediate consideration of biopsy in screen positive men have varied, but have almost always included men with tPSA results greater than10 ng/mL, and may include men with tPSA results between four and 10 ng/mL, with or without suspicious digital rectal examination findings.5,24 Decisions about biopsy in patients with elevated (greater than 4 ng/mL) or intermediate (also referred to as “grey zone”) tPSA results (e.g., 2.5 to 4 ng/mL) may also be impacted by other considerations, such as age, family history, race and results of followup testing with tPSA and/or other biomarkers (e.g., %fPSA, PSA density, PSA velocity) and/or use of individualized risk assessment tools or nomograms (e.g., PCPT Risk Calculator25).7,15,26 However, the most effective approaches for use of biomarkers and risk assessment tools/nomograms remain controversial, and evidence of impact on decisionmaking and subsequent short- and long-term improvement in clinical outcomes (e.g., function, morbidity, mortality) are lacking. Decisions about biopsy may also be impacted by other risk factors, comorbidities, or patient and physician preferences.

#### Biopsy

Performance of needle biopsy leads to pathologic examination of tissue cores (minimally 6 cores, 12 are recommended) to identify the presence or absence of cancer, the percent of the tissue core that is cancer and the Gleason score (an assessment of tissue differentiation).3,24,27 In addition to anxiety and discomfort, identified risks of biopsy have included infection (with increase in cases of antimicrobial resistance), fever, rectal bleeding, hematuria, vasovagal episodes, hematospermia and dysuria.5,28

Classification systems have been developed to designate biopsy-positive men as high risk or low risk relative to the likelihood of disease progression without treatment. Such risk classification can inform decisions about management, such as treatment versus active surveillance,29,30 and multiple treatment options (e.g., surgery vs. radiation).5,27 There is considerable interest in the identification of new biomarkers, or effective combinations of biomarkers and/or other risk factors, to better inform prebiopsy decisionmaking.31

#### Treatment Options

For patients with insignificant disease (i.e., low grade, low volume tumors with specific pathologic characteristics, one option is active surveillance.14,20,27,32 Instead of working to eradicate the tumor, the patient defers treatment and begins ongoing surveillance that minimally includes serial tPSA and PSA velocity testing and repeated biopsies. If there is evidence of conversion to more aggressive disease (i.e., increasing tPSA levels or PSA velocity, upgrading in tumor stage or volume), surgery and other options can be considered.

For patients with “high-risk prostate cancer” of varying risk strata (i.e., high grade, high volume, multifocal tumor or other characteristics believed to be associated with aggressive disease), or those unwilling to accept the risk associated with active surveillance, there are well-established treatment options.7,27 As examples:

- Prostatectomy involves complete excision of the prostate. Prostate tissue from radical prostatectomy undergoes clinical staging and gross and histopathological examination.3,24,27,33 Quantitative tools for risk stratification are available to estimate the likelihood of prostate cancer recurrence post-prostatectomy or other treatment.25,34-36 Complications of prostatectomy include urinary incontinence and erectile dysfunction. The 10-year rate of prostate cancer-related death ranged from one to eight percent, depending on classification of the tumor as high or low risk.37
- Interstitial brachytherapy is a choice for patients with low to moderate risk disease, and involves implanting high-dose radioactive seeds into the prostate. Adverse effects include lower urinary tract symptoms, obstructive or irritative prostatitis, and later onset of erectile dysfunction. Ten-year disease free survival is reported to be about 85 percent.38
- External-beam radiotherapy is commonly used in combination with androgen therapy to treat high-risk disease. Adverse effects include irritative voiding symptoms, hemorrhagic cystitis or proctitis, and risk of a second malignancy of the bladder and rectum. Reported 10-year disease-free survival is about 88 percent.37
- Other techniques for whole prostate treatment include cryotherapy and high-intensity focused ultrasound (HIFU).

While biomarkers and risk assessment tools/nomograms are being used to identify men with high- and low-risk cancers, evidence of their effectiveness based on long-term clinical outcomes is needed.

### Development of a New Biomarker: PCA3

In 1999, researchers reported identification of the differential display 3 gene (DD3), highly overexpressed in prostate cancer tissue but having little or no expression in normal prostate tissue or benign prostatic hyperplasia tissue.39 Subsequently renamed the prostate cancer antigen 3 gene (PCA3), PCA3 is a noncoding mRNA mapped to chromosome 9q21-22.^40,41^ Since 2002, quantitative methods to measure PCA3 mRNA in urine samples have been developed and improved40,42 (see Table 4 in Results). Early investigators found that prostate manipulation led to a general release of mRNA. Therefore, expression of another prostate-specific gene needed to be quantified to correct for the number of prostate cells present in the urine. One study43 had investigated the expression of the gene that encodes PSA, KLK3, in prostate tissue. They reported that PSA mRNA expression had been shown to be relatively constant in normal prostate cells, with only a weak (∼1.5-fold) down-regulation of PSA expression in prostate cancer cells. They further noted the other studies that had shown that levels of protein and mRNA expression were not necessarily parallel. Therefore, PSA mRNA was chosen as the “housekeeping” gene against which PCA3 mRNA results were normalized.40,44-46 In most assays, the ratio of PCA3 mRNA copies per mL and PSA mRNA copies per mL is multiplied by 1,000 to provide a PCA3 “score.”40,44-46

Stability of mRNA has been shown to be a source of variability for some tests, but use of a detergent based stabilization buffer47 and shipping frozen samples have improved sample quality. Sokoll et al.48 reported the first multicenter study of PCA3 analytical performance in 2008 using the Gen-Probe assay and concluded that the assay performs well and is insensitive to preanalytical factors.

On February 17, 2012, Gen-Probe reported that they had received U.S. Food and Drug Administration (FDA) approval for the PROGENSA^®^ PCA3 assay. The FDA specified that the test's intended use was for men 50 years of age or older who had one or more previous negative biopsies (and no finding of atypical small acinar proliferation in the most recent biopsy) and are being considered for a repeat biopsy. A negative PROGENSA PCA3 assay is noted to be associated with decreased likelihood of a positive biopsy. However, the label specifies that “…the performance of the assay has not been established in men for whom a repeat biopsy was not already recommended.” PCA3 testing is also offered by reference laboratories as laboratory-developed tests (i.e., tests developed by and used at a single laboratory testing site). With FDA approval, it is reasonable to anticipate that the PCA3 test could become more widely available throughout the U.S.

In summary, the upregulation of PCA3 mRNA expression in prostate cancer tissue provided a rationale for detecting a small number of cancer cells within the background of a large number of normal or benign prostatic hypertrophy cells.40,44 Three potential intended uses for the PCA3 test have been proposed: 1) to inform decisions about when to biopsy patients at-risk and when to wait; 2) to inform decisions about when to rebiopsy patients at-risk and when to wait (the claim currently approved by FDA for the PROGENSA^®^ PCA test); and 3) to determine, in patients with positive biopsies, whether the disease is insignificant/indolent or aggressive, so that an optimal treatment plan can be developed.

### Selected PCA3 Comparators

#### Total PSA (tPSA)

In 1989, Catalona et al.13 initiated a multicenter population-based study examining the use of tPSA and digital rectal exam (DRE) for prostate cancer screening. Based on the findings of enhanced early prostate cancer detection, the FDA approved a PSA assay for prostate cancer screening in 1994, and defined the upper limit of normal as 4 ng/mL.41 Numerous studies have followed, and the test is widely available as a screening and monitoring test. A subsequent meta-analysis of studies on PSA as a screening test showed that a significant number of prostate cancers would be missed using 4 ng/mL as a cutoff.49 As a result, some laboratories subsequently offered testing at lower cutoffs (e.g., 2.5 or 3.0 ng/mL). Lower cutoffs increased the yield of positive cancers, but also increased the false-positive rate and lead to negative biopsies and the potential for subsequent followup with associated risk of clinical harms.8,19 Others have used age-specific tPSA cutoffs to improve sensitivity in younger men and improve specificity in older men (e.g., cutoffs of 2.5, 3.5, 4.5, and 6.5 for men 40-49, 50-59, 60-69, and 70-79 years of age, respectively). 5,50 However, NCCN Prostate Cancer Early Detection guidelines note that investigations of tPSA age-specific ranges have resulted in “equivocal results,”5 and clinical utility remains uncertain.

In spite of its importance in health care, serum tPSA is not a standardized analyte, meaning that there is not a national requirement for quality specifications defined by either the Clinical Laboratory Improvement Act (CLIA) regulations or by the FDA. Assay-specific and site-specific differences in serum tPSA test performance in proficiency testing have been reported for more than 15 years.51-53 In 1999, Klee et al. reported that plus or minus 10 percent bias ranges for PSA correspond to -19.9 percent to +20.4 percent variation in patient classification.54 Redesign of proficiency testing (PT) materials was reported to improve College of American Pathology survey outcomes,51 and these specimens are likely to be the best available for monitoring testing in U.S. laboratories.55 However, a 2006 review of PT data for tPSA found that available methods could be assumed correct less than 40 percent of the time at 6.5 ng/mL, and only 30 to 40 percent of the time at 19 ng/mL.55 They concluded that test results were insufficiently reliable when applying uniform national cutoffs, and could cause many false-positive results.

In summary, for KQ 1 and KQ 2, nearly all study subjects have tPSA levels of at least 2 to 4 ng/mL or higher (i.e., screen positive). Therefore, the actual comparator for PCA3 is not a positive or negative tPSA but, among those with positive results, the extent of the tPSA elevation. For example, risk of a prostate cancer being identified among men with levels between 4 and 6 ng/mL is lower than among men with tPSA levels greater than 10 ng/mL.

#### Free PSA (%fPSA)

Serum PSA circulates in blood as different isoforms, mainly as unbound or free PSA (fPSA) and a form that complexes with serum antiproteases (complexed PSA or cPSA).37 The ratio of fPSA to tPSA levels is reported as percent fPSA. High levels of %fPSA are associated with benign prostatic disease, while low levels are associated with cancer.56 Percent fPSA increases with age and prostate volume, and decreases as total PSA increases.41 In addition, %fPSA is less stable than tPSA, and requires processing with 24 hours of collection.

One meta-analysis of %fPSA studies57 reported that, in the tPSA diagnostic grey zone of 2 to 10 ng/mL, addition of %fPSA testing can reduce the number of negative biopsies while maintaining a high cancer detection rate, but a second meta-analysis reported that %fPSA is a useful addition to tPSA testing in only one part of the grey zone.58 However, FDA has approved fPSA testing for men with tPSA levels in the 4-10 ng/mL range. The NCCN Prostate Cancer Early Detection guidelines includes %fPSA in its diagnostic algorithm for early detection of prostate cancer, as part of decisionmaking about biopsy or rebiopsy.5 They suggest that patients with “grey zone” tPSA levels and %fPSA of 10 percent or less are candidates for biopsy or repeat biopsy; patients with %fPSA greater than 25 percent be should be followed closely (e.g., DRE, tPSA, %fPSA, PSA velocity), and that patients with intermediate values be informed of choices.5

#### PSA Density

Benson et al.59 described the concept of PSA density (PSAD) as the ratio of tPSA concentration to prostate volume, but requires transrectal ultrasound or magnetic resonance imaging to assess prostate volume. They identified differences in mean PSAD between men with prostate cancer and men with BPH. Subsequent studies suggested a modest improvement in diagnostic accuracy when PSAD was added to tPSA values, but more recent studies failed to confirm the value of PSAD. Consequently, its current clinical use appears limited.41,60 One recent report has suggested this measurement could be used to predict clinical pathological features of disease.61

#### PSA Velocity and Doubling Time

PSA velocity and PSA doubling time are measures of longitudinal increases in tPSA. PSA velocity is defined as the rate of change of tPSA levels in a specified period, typically reported as ng/mL per year.41,62,63 PSA doubling time is defined as the time it takes (e.g., months) for the tPSA level to increase by a factor of two. Both can pose challenges in practice, as they have been defined in many ways, with variability in number of tPSA measures needed to calculate a dynamics metric, the time between measures, and the statistical method for estimating change.62,63,64

Guidelines for early detection of prostate recommend that PSA velocity be considered in both consideration of biopsy and followup.5 However, systematic reviews of pretreatment use of PSA velocity found evidence that this biomarker is not useful in informing decisionmaking about biopsy, eligibility for active surveillance or post-treatment prognosis.62-64 Studies have shown that PSA doubling time has prognostic value for metastasis-free and prostate cancer-related survival in monitoring of patients with advanced or recurrent prostate cancer.64

#### Complexed PSA

Another PSA isoform considered in early detection of prostate cancer is measurement of the PSA bound to serum antiproteases, termed complexed PSA (cPSA). A recent systematic review57 concluded that cPSA and %fPSA showed equivalent effects. The authors cautioned that a lack of detail on study methodology and the relatively small number of studies warranted caution in the interpretation of the findings.

#### Externally Validated Nomograms

Current decisionmaking about risk of prostate cancer and whether to biopsy or rebiopsy has not been standardized, but depends on consideration of a variety of clinical factors (e.g., age, family history, race) and laboratory test results.26 Recently, attention has been directed at development of risk algorithms, nomograms or artificial neural networks that combine multiple clinical and laboratory risk factors to create a cumulative risk score that informs clinical decisionmaking.15,26,34,65 These risk assessment tools are intended to exploit the incremental value of running multiple tests, each with independent contributions to the estimation of the risks of biopsy or treatment outcomes for patients. Risk factors often included were tPSA level, age, race and family history, and other biomarkers that vary by study. A systematic review concluded that these tools produced improvements in area under the receiver operator characteristics (ROC) curve (AUC), when compared with tPSA levels alone, but noted that many nomograms were not externally validated. When external validation was taken into account, benefits of nomogram use were decreased, although still statistically significant.15 Despite variation in development and validation, a recent systematic review suggested that these tools tend to provide more accurate diagnostic predictions for cancer-positive biopsies than the use of tPSA testing or other factors alone.

#### Criteria for Distinguishing Insignificant Prostate Cancer

Three criteria have been commonly recognized to identify candidates for active surveillance: low-grade disease, low-volume disease, and low tPSA levels. However, eligibility criteria vary from study to study and site to site.20 The most established criteria for identifying patients with “insignificant” disease are those proposed by Epstein.16,30,66 Epstein includes prostate biopsy criteria (clinical stage T1c; PSA density <0.15 ng/mL; no biopsy Gleason pattern 4 or 5; fewer than three positive cores; and <50 percent cancer per core), as well as criteria predicting pathologic characteristics of radical prostatectomy tissue (organ-confined disease; tumor volume less than 0.5 cm^3^; Gleason score of 6 or less without Gleason pattern 4 or 5).14,67 Original and modified Epstein criteria are common inclusion measures for studies of active surveillance.20

Comparison of criteria for identifying low- to high-risk tumors has been complicated by the development of multiple predictive and prognostic nomograms/risk assessment tools, with little or no comparison and standardization of underlying assumptions. Commonly used tools include the D'Amico risk classification, the Kattan nomogram, the Partin tables, the Prostate Cancer Prevention Trial risk calculator and the Nakanishi and Chun nomograms.14,15,25,66,68 Understanding the relative performance of measurements to identify candidates for active surveillance or treatment is complicated by the use of varying criteria to identify risk progression, including changes in tPSA levels, histological grade, extent of biopsy core involvement, and/or clinical stage.20 Longitudinal studies are needed to determine long-term clinical outcomes of patients classified as low and high risk, including those who immediately entered treatment or initially chose active surveillance (possibly progressing to treatment).

## Key Questions

In patients with elevated PSA and/or an This comparative effectiveness review addresses three Key Questions (KQs). The first two relate to the use of the urine PCA3 test and other biomarker tests to predict detection of prostate tumor at biopsy or rebiopsy of men at risk based primarily on elevated tPSA and/or suspicious DRE. A recognized problem in tPSA screening-based diagnosis of prostate cancer is the high rate of false-positive results that can lead to a relatively high number of negative biopsies. The third KQ concerns the use of the urine PCA3 test and other biomarker tests and pathological markers to classify the patient as low or high risk. This review will not address the merits or limitations of prostate cancer screening.

The KQs relate to three proposed scenarios in which this testing may be used:

KQ 1. In patients with elevated PSA and/or an abnormal DRE who are candidates for initial prostate biopsy, what is the comparative effectiveness of PCA3 testing as a replacement for, or supplement to, standard tests, including diagnostic accuracy (clinical validity) for prostate cancer, intermediate outcomes (e.g., improved decision making about biopsy), and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life and potential harms?

KQ 2. In patients with elevated PSA and/or an abnormal DRE who are candidates for repeat prostate biopsy (when all previous biopsies were negative), what is the comparative effectiveness of PCA3 testing as a replacement for, or supplement to, standard tests, including diagnostic accuracy (clinical validity) for prostate cancer, intermediate outcomes (e.g., improved decisionmaking about biopsy), and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life and potential harms?

KQ 3. In patients with a positive biopsy for prostate cancer who are being evaluated to distinguish between indolent and aggressive disease, what is the effectiveness of using PCA3 testing alone, or in combination with the standard prognostic workup (e.g., tumor volume, Gleason score, clinical staging) or monitoring tests (e.g., PSA, PSA velocity), with regard to diagnostic accuracy (clinical validity) for aggressive (high risk) prostate cancer, intermediate outcomes (e.g., improved decisionmaking about prognosis and triage for active surveillance and/or aggressive treatment) and long-term health outcomes (clinical utility), including mortality/morbidity, quality of life, and potential harms?

The proposed KQs were posted for public comment on the Effective Health Care Program Web site (www.effectivehealthcare.ahrq.gov) from May 4, 2011, to June 1, 2011. A total of eight comments were received. No respondent suggested a specific change in the questions, although several noted that data concerning the use of PCA3 testing were currently most compelling for decisionmaking about repeat biopsy in patients screened with a PSA test and a DRE. At least two comments were directed at the likelihood that our review would not be able to address the long-term outcomes of interest (e.g., mortality, morbidity, quality of life). One commentator addressed the value of PCA3 test results in multispecialty team decisionmaking and noted that this test should be evaluated in patients receiving treatment to aid decisions about management changes. Based on the public comments received, no changes were made to the KQs.

## Analytic Frameworks

Two analytical frameworks (AFs) were developed for this review, one for KQ 1 and KQ 2, and a second for KQ 3. The first AF (Figure 1) addresses KQ 1 and KQ 2, and applies to men who are at risk for prostate cancer based on elevated tPSA results and/or abnormal DRE, and are having either an initial (KQ 1) or repeat (KQ 2) biopsy. The AF in Figure 1 depicts the comparative effectiveness of using PCA3 testing (alone or in combination with other biomarkers) and other standard tests (e.g., tPSA, %fPSA) to predict intermediate and long-term health outcomes of interest. In Figure 1, direct evidence of the impact of testing on health outcomes (e.g., mortality/ morbidity, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses an intermediate outcome, the diagnostic accuracy (clinical validity) of the PCA3 and its designated comparators in predicting positive biopsies. Link C addresses the impact of test results on the decision to proceed to an initial prostate biopsy, which, in turn, impacts other intermediate outcomes (Link D) and leads to long-term health outcomes (Link E) that determine the utility of the tests. Link F on the left addresses potential harms related to the effect testing has on the biopsy decision; Link F on the right focuses on clinical (e.g., bleeding, infection) and psychosocial (e.g., anxiety, quality of life) harms related to the biopsy procedure and/or repeated biopsy.

Figure 1 Analytic framework for PCA3 as a diagnostic indicator for biopsy or rebiopsy in patients with elevated PSA and/or abnormal digital rectal examination (KQ 1 and KQ 2)

* Patients may be evaluated for initial biopsy or rebiopsy after one or more negatives.

PSA = prostate specific antigen; PCA3 = prostate cancer antigen 3 gene

Figure 1 depicts the framework for KQ1 with the patient population of male patients with an elevated PSA level and/or abnormal digital rectal exam (DRE). This figure depicts the comparative effectiveness of using PCA3 testing versus other tests (e.g., PSA) for intermediate outcomes and long-term health outcomes. Direct evidence of testing impact on health outcomes (e.g. reduced mortality/morbidity, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses the diagnostic accuracy (clinical validity) of the PCA3 test and designated comparators. Link C addresses the impact of test results on the decision to proceed to the initial prostate biopsy, which, in turn, impacts the intermediate outcomes (Link D). Intermediate outcomes may have an association with long term health outcomes (Link E). Link F on the on the left focuses on adverse events/personal harms related to biopsy left addresses potential personal and clinical harms related to the effect of testing on the decision about biopsy, and on the right focuses on adverse events/personal harms related to biopsy. The framework for KQ2 is essentially the same, except the population is male patients with elevated PSA and/or DRE, as well as one or more previous negative prostate biopsies. Link C in this case addresses the impact of test results on the decision to proceed to repeat prostate biopsy.

The second analytic framework (Figure 2) addresses KQ 3, and applies to men who have had a biopsy result that is positive for prostate cancer. Figure 2 depicts the comparative effectiveness of using PCA3 testing (alone or in combination with other biomarkers) and other commonly used tests (e.g., Gleason score and other pathological markers, percent positive cores) on intermediate and long-term health outcomes of interest. Direct evidence of the impact of testing on health outcomes (e.g., mortality, morbidity, function, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses the diagnostic accuracy (clinical validity) of the test's categorization of tumors as aggressive or insignificant/indolent in predicting health outcomes. Link C addresses the impact of test results on decisionmaking related to prognosis and triage for active surveillance versus aggressive treatment. This link, in turn, impacts other intermediate outcomes (Link D) and leads to the long-term health outcomes (Link E) that determine both the clinical validity of tests in accurately categorizing risk and the utility of treatment based on risk categorization. Link F on the left addresses potential harms related to the effect testing has on treatment decisions (e.g., incorrect therapy); Link F on the right focuses on clinical (e.g., incontinence, impotence, bowel dysfunction) and psychosocial (e.g., anxiety, self-image, quality of life) harms related to management and treatment.

Figure 2 Analytic framework for PCA3 used to distinguish insignificant/indolent versus aggressive prostate cancer (KQ 3)

* Diagnostic accuracy

PCA3 = prostate cancer antigen 3 gene

Figure 2 depicts the framework for KQ3 with the patient population of male patients with positive biopsies for prostate cancer. This figure depicts the comparative effectiveness of using PCA3 testing versus other tests (e.g., PSA) for intermediate outcomes and long-term health outcomes. Direct evidence of testing impact on health outcomes (e.g. reduced mortality/morbidity, quality of life) is shown by Link A. In the indirect chain of evidence, Link B addresses the diagnostic accuracy (clinical validity) of the PCA3 test and designated comparators. Link C addresses the impact of test results on the decision to proceed to the initial prostate biopsy, which, in turn, impacts the intermediate outcomes (Link D). Intermediate outcomes may have an association with long term health outcomes (Link E). Link F on the on the left focuses on adverse events/personal harms related to biopsy left addresses potential personal and clinical harms related to the effect of testing on the decision about biopsy, and on the right focuses on adverse events/personal harms related to biopsy. The framework for KQ2 is essentially the same, except the population is male patients with elevated PSA and/or DRE, as well as one or more previous negative prostate biopsies. Link C in this case addresses the impact of test results on the decision to proceed to repeat prostate biopsy.

### PICOTS Framework

The PICOTS (Population, Intervention, Comparator, Outcome, Timing, and Setting) for the KQs follow:

#### Population(s)

KQ 1: Adult male patients who are candidates for initial prostate biopsy based on elevated prostate-specific antigen (tPSA) and/or abnormal digital rectal examination (DRE).

KQ 2: Adult male patients with one or more previous negative prostate biopsies who are candidates for repeat biopsy based on elevated tPSA and/or abnormal DRE.

KQ 3: Adult male patients with a positive prostate biopsy.

#### Interventions

- Testing for the prostate cancer antigen 3 gene (PCA3) mRNA alone or in conjunction with comparator tests
- Prostate biopsy
- Prostatectomy

#### Comparators

- KQs 1 and 2
  – Total PSA
  – Percent free PSA
  – PSA velocity or doubling time
  – PSA density
  – Complexed PSA
  – Externally validated nomograms
- KQ 3
  – Total PSA
  – Percent free PSA
  – PSA velocity or doubling time
  – Externally validated nomograms
  – Gleason score
  – Stage
  – Prostate volume
  – Epstein and other risk criteria
  – Other pathological markers

#### Outcomes

KQs 1 and 2
- Long-term health outcomes: Prostate cancer-related mortality, morbidity, function, quality of life (measured with validated instruments), and harms related to PCA3 testing and subsequent interventions (e.g., biopsy, surveillance, treatment).
- Intermediate outcomes: Diagnostic accuracy; impact on decisionmaking that leads to reduction in the number of negative biopsies and increase in the identification of prostate tumors.

KQ 3
- Long-term outcomes: Prostate cancer-related mortality, morbidity, function, quality of life (measured with validated instruments) and harms related to PCA3 testing and subsequent interventions (e.g., repeat biopsy, active surveillance, and treatment).
- Intermediate outcomes: Diagnostic accuracy; impact on decisionmaking that provides information on prognosis and informs treatment decisions.

#### Timing

- Any duration of followup will be evaluated.
- Timing of studies related to successive generations of PCA3 and PSA assays will be considered as part of quality assessment and as a potential source of heterogeneity.

#### Setting

All settings.

## Scope of the Review

Despite the large body of published literature on prostate cancer screening with tPSA, the value of early intervention remains controversial.19,21,69 However, the burden of prostate cancer and the efforts to effectively diagnose and treat the disease are substantial. Consequently, there is continuing interest in identifying and validating biomarkers that can improve the clinical specificity and sensitivity of the prostate cancer diagnostic pathway (i.e., predicting prostate cancer in at risk men) or prognosis (i.e., classifying prostate tumors as high or low risk, informing treatment decisions). Introduction of such a biomarker, alone or in combination with other biomarkers or risk factors, has the potential to reduce the current uncertainty in decisionmaking, which may lead to improved health outcomes with lower risk of associated harms. However, systematic review of the evidence supporting the diagnostic accuracy and utility of each intended use is needed to ensure an overall net balance of benefits over harms, and reduce the risk of introducing new unanticipated harms.

This is a comparative effectiveness review of testing with prostate cancer antigen 3 (PCA3), alone or in combination with other markers (comparators), in three proposed intended uses. The KQs addressed how PCA3 testing effectiveness compares with other markers: (1) alone or in combination with other risk factors (e.g., age, family history, race) or biomarkers in making decisions about which at risk patients to biopsy (KQ 1); (2) alone or in combination with other risk factors or biomarkers in making decisions about which at risk patients should consider repeat biopsy (KQ 2); and (3) alone or in combination with other biomarkers, risk factors or pathological markers in biopsy positive patients, in making decisions about aggressive treatment (e.g., radical surgery or radiation therapy) versus active surveillance (KQ 3). KQ 1 and KQ 2 reflect important clinical decision points. However, they are narrowly focused on a specific subset of patients (i.e., only initial or only repeat biopsy). Studies may not be limited to these two groups, or may not distinguish between the groups in their presentation of results in mixed populations. Therefore, it may be necessary to consider an alternative analytic approach to assess performance of the biomarkers in the two groups.

For prostate cancer prediction at biopsy or rebiopsy, the selected serum biomarker comparators were total prostate specific antigen (tPSA) elevations, free PSA (%fPSA), PSA density, PSA velocity or doubling time, and complexed PSA. Externally validated nomograms (EVNs), a type of risk assessment tool, were also reviewed. For classification as high or low risk, initially selected comparators included Gleason score, tumor stage, other pathological tumor markers, prostate volume, and biomarkers used for risk classification (e.g., tPSA, fPSA, PSA density) and monitoring disease progression (e.g., tPSA, PSA velocity). The selected outcomes of interest for all KQs included both interediate (diagnostic accuracy, impact on decisionmaking, harms of biopsy or treatment) and long-term (mortality, morbidity, quality of life) outcomes.