# Peer Reviewers

- Daniel Barocas, M.D., M.P.H.
  Assistant Professor Medicine
  Vanderbilt University
  Nashville, TN
- Carl Gjertson, M.D.
  Assistant Professor, Surgery
  University of Connecticut
  Farmington, CT
- Andrzej Kosinski, Ph.D.
  Associate Professor
  Biostatistics/Bioinformatics
  Duke University
  Durham, NC
- Timothy O'Leary, M.D., Ph.D.
  Director, Clinical Science Research and Development
  Veterans Affairs
  Washington, DC
- Estelle Russek-Cohen, Ph.D.
  Deputy Director
  Division of Biostatistics
  U.S. Food and Drug Administration
  Rockville, MD