# Technical Expert Panel

- Peter Albertsen, M.D.
  Chief, Director of Urology
  University of Connecticut Health Center
  Farmington, CT
- Todd Alonzo, Ph.D.
  Associate Professor of Research
  Department of Preventive Medicine
  University of Southern California
  Arcadia, CA
- William Dotson, Ph.D.
  Senior Coordinating Scientist
  Public Health Genomics
  Centers for Disease Control and Prevention
  Atlanta, GA
- Peter Gann, M.D., Sc.D.
  Professor of Pathology
  College of Medicine
  University of Illinois at Chicago
  Chicago, IL
- Roger Klein, M.D., J.D.
  Affiliate Associate Professor
  Center of Evidence-Based Medicine & Health Outcomes Research
  Clinical and Translational Science Institute
  University of South Florida
  Morsani College of Medicine
  Tampa, FL
- Stephen Spann, M.D., M.B.A.
  Professor and Chair
  Family/Community Medicine
  Baylor College of Medicine
  Houston, TX
- Thomas Trikalinos, M.D., Ph.D.
  Professor of Medicine
  Co-Director, Tufts Evidence-based Practice Center
  Institute for Clinical Research and Health Policy Studies
  Boston, MA