# Key Informants

- Peter Albertsen, M.D.
  Chief, Director of Urology
  University of Connecticut Health Center
  Farmington, CT
- Robert Carey
  RPC Associates/Consulting Services
  John's Creek, GA
- Janet Colli, M.D.
  Fellow, Laparoscopic Surgery
  Tulane University
  New Orleans, LA
- John Concato, M.D.
  Professor of Medicine (General Medicine)
  Yale University
  New Haven, CT
- William Dotson, Ph.D.
  Senior Coordinating Scientist
  Public Health Genomics
  Centers for Disease Control and Prevention
  Atlanta, GA
- Peter Gann, M.D., Sc.D.
  Professor of Pathology
  College of Medicine
  University of Illinois at Chicago
  Chicago, IL
- John L. Gore, M.D., M.S.
  Assistant Professor of Urology
  University of Washington
  Seattle, WA
- Roger Klein, M.D., J.D.
  Affiliate Associate Professor
  Center of Evidence-Based Medicine & Health Outcomes Research
  Clinical and Translational Science Institute
  University of South Florida
  Morsani College of Medicine
  Tampa, FL
- Michael LeFevre, M.D., M.S.P.H.
  Chief Medical Information Officer
  University of Missouri School of Medicine
  Columbia, MO