# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia J. Bonnell, M.L.S., B.S.N.; Jennifer Brock, M.P.H.; Ryan Chopra, M.P.H.; Michael Douglas, M.S.; Lisa Garofalo, B.A.; Denise Oliansky, M.A., M.L.I.S.; Lisa Sarsany, M.A.; Kathleen M. Ziegler, Pharm.D.