# Discussion

## KQ 1 and KQ 2: Findings and Strength of Evidence

This Comparative Effectiveness Review investigated three Key Questions (KQs). The first two KQs addressed the performance of PCA3 testing in comparison with six individual serum biomarkers, or combinations of such biomarkers, to predict risk of prostate cancer at biopsy among men identified as being at risk through tPSA screening. These men were candidates for initial biopsy (KQ 1) or repeat biopsy after one or more previous negative biopsies (KQ 2). Findings were limited by several factors, including the relatively small number of matched studies, that no studies reported raw data or a true matched analysis, that clinical follow-up was not performed in essentially all studies identified for either of the KQs, and that the individual studies were of poor quality.

The only comparator with sufficient data for analysis was tPSA. However, this analysis was subject to three important biases: (1) sampling bias, due to some studies limiting enrollment to men in the “grey zone” of tPSA elevations (e.g., 2.5 ng/mL to less than 10 ng/mL); (2) verification bias, due to the use of tPSA elevations in the decision-making process to accept (or reject) prostate biopsy; and spectrum bias; and (3) spectrum bias. Sampling bias was addressed by separately reporting, when possible, studies in the “grey zone” from those without tPSA level restriction. Verification bias was addressed by reviewing relevant publications and performing in-house modeling. The spectrum effect of most concern could only be described. It relates to the range of severity of disease identified by PCA3 and comparators. In order to estimate true clinical validity, it is necessary to examine both concordant and discordant test results (those positive by one test but negative by the other) in men with positive biopsies. If the men with discordant results showed similar severity of disease, the sensitivity/specificity estimates would be both statistically and clinically equivalent. However, if one test identifies more severe cases that the other misses, the estimates may be statistically equivalent but clinically different.

The main findings included: PCA3 consistently has higher sensitivity than tPSA elevations at a given specificity, PCA3 and tPSA elevations provide essentially independent information about prostate cancer risk, and the performance of PCA3 relative to tPSA is not dependent on the biopsy status (i.e., the relative performances are not significantly different between men having initial and men having repeat biopsy). However, the overall strength of evidence for these findings is Low. This information could be of potential use to researchers designing future studies and may also be of interest to policy-makers with regards to future testing strategies for better stratification of prostate cancer risk in men.

## Potential To Combine Studies Addressing KQs 1 and 2

Given the limited data available for KQ 1 and KQ 2, we examined the pool of studies that provided comparison data, but were not limited to only men having an initial biopsy or men with no previous positive biopsy having a repeat biopsy. An additional 16 studies provided usable comparative data for PCA3 and tPSA, but the enrolled population consisted of a mixture of men in both categories or did not report this proportion. The proportion of enrolled men having an initial biopsy (100 percent would indicate a study suitable for KQ 1, while 0 percent would indicate a study suitable for KQ 2) was then plotted against two separate measures of relative effect size (difference in AUC and sensitivity at selected specificities). In both analyses, the correlation was essentially zero, indicating that neither of the two relative effect size measures was dependent on the mixture of initial versus repeat biopsies. This provided sufficient evidence to perform a series of “combined” KQ 1/KQ 2 analyses.

## KQ 3: Findings and Strength of Evidence

The third question addressed the performance of PCA3 testing in comparison with serum biomarkers and, other risk factors (e.g., family history, age) and pathological tumor markers (e.g., Gleason score, staging) to identify men with high risk (i.e., aggressive) and low risk (i.e., insignificant/indolent) prostate cancers. KQ 3 focused on matched studies of men with a positive prostate biopsy. In order to inform decisions about management and treatment options (i.e., active surveillance vs. treatment). KQ 3 investigated risk assessment and the potential to categorize patients based on specific biomarker results and pathological markers from biopsy and, mainly, prostatectomy.

However, the reference standard for diagnostic accuracy must be a longer term clinical endpoint, in order to investigate outcomes in the context of categorization of risk. These endpoints might include measures of progression, metastasis, and prostate cancer related morbidity (e.g., function, quality of life) or mortality. Only two studies provided information on progression related to PCA3 and comparators, but in different populations with poorly described surrogate clinical endpoints. More time will be needed for assessment of progression free survival, mortality and other long-term outcomes.20 Given the relatively recent advent of PCA3 testing, it is not surprising that no studies were identified that provided intermediate or long term outcomes based on PCA3 and one or more comparators.

## Findings in Relationship to What Is Already Known

### Systematic Review of PCA3

One prior structured systematic literature review of PCA3 testing and prostate cancer was identified.80 That review covered the time period 2000 to 2009 and included only studies of diagnostic accuracy, with prostate biopsy as the gold standard. No comparisons were made to other biomarkers. Included were studies reporting on cohorts of adult men undergoing prostate cancer screening; mean tPSA levels were provided for each study, but elevated tPSA was not an inclusion criterion. Fourteen studies were included in the Ruiz-Aragon review46,47,82-86,96,104,115,128-130 The four studies from our literature search that were also reviewed by Ruiz-Aragon were excluded from our review due to high likelihood of data duplication with other included studies.47,82-84

Summary estimates of clinical sensitivity and specificity from the previously published meta-analysis (random effects model) were 63 percent (95% CI: 60-66 percent) and 75 percent (95% CI: 73 to 76 percent), respectively. Heterogeneity was high and significant (p < 0.001). The SROC AUC was 0.783. The authors acknowledged that no consensus existed on the most appropriate PCA3 cutoff for clinical decisionmaking. Based on QUADAS criteria, the authors reported the studies to be of moderate to high quality, in spite of the acknowledged lack of blinding. However, the review did not compare PCA3 performance with any other biomarkers, used reported sensitivity/specificity results from studies with varying PCA3 cutoffs (range, scores of 19 to 66), included studies using probability cutoffs, and included a study of prostatic fluid samples. These inclusion criteria may account for a portion of the observed heterogeneity.

## Applicability

### KQs 1 and 2: Biopsy Decisionmaking

To determine the effectiveness of PCA3 and comparator tests in predicting risk of prostate cancer at initial or repeat biopsy, or in risk categorization to inform decisions about treatment, it is useful to assess the applicability of the findings in this review.

#### Population and Settings of Care

The populations studied in these studies were largely drawn from convenience samples at academic medical centers where patients with elevated tPSA results and/or other risk factors (e.g., positive DRE, family history, African American) seek referral or specialty care. Such observational cohort studies are subject to spectrum and verification biases. For example, these studies may represent a group of men at higher risk of prostate cancer, or risk of men with a difference in severity of disease, than the total cohort of men with elevated tPSA and/or other risk factors. If a study reports results in which biopsy is tPSA-related, verification bias can impact the accuracy of the sensitivity and specificity estimates at select tPSA cutoffs. If those not accepting biopsy are considered missing, this is considered “partial verification” bias. However, no studies addressed these potential biases.

The positive biopsy rate in such referral populations will depend on multiple factors, including the tPSA cutoff, the number of men with elevated tPSA who opt out of biopsy (e.g., men with lower tPSA levels and lower risk), and/or the proportions of men with other important risk factors. In 17 included studies, biopsy positive rates ranged from 16.9 to 72.9 percent, with a median of 36 percent. It is unlikely that the clinical sensitivity and specificity estimates derived from these studies will be affected. However, positive and negative predictive values do depend on disease prevalence, and the reported predictive values will vary. Total PSA is currently the standard initial screening test for the identification of men at increased of prostate cancer. However, studies of proficiency testing data have shown that tPSA test kits provide variable results that could result in significant differences in proportion of identified cancers at recommended tPSA cutoffs. Therefore, an inherent limitation or source of heterogeneity for the PCA3 test may be the use of PSA for first order screening.

The observation that the relative performance of PCA3 versus tPSA elevations does not appear to be dependent on the biopsy history is a new finding. The current FDA approval for PCA3 restricts it use to decision-making regarding a repeat biopsy in men with a specific clinical history that includes one or more negative prostate biopsies. This review suggests that PCA3 might also have use in men making decisions about an initial biopsy. This would greatly broaden the settings in which PCA3 might be offered. However, the data supporting the FDA approval have not been published and were not available for this evidence review. The data provided in the FDA summary were specific to repeats and could not be included in key analyses because it was not a matched study design.

Whether or not further utilization of PCA3 occurs will also involve other important dynamics, such as acceptability and costs. Further studies will also be needed to validate models incorporating PCA3 testing with other markers in the setting of the initially positive patient. Uptake of PCA3 testing by physicians could be affected by other factors. The FDA approval of the PCA3 test and the Prostate Health Index test may be seen as sources of additional information that could improve tPSA performance. The current controversy around the utility of tPSA screening has become more vocal since the recent U.S. Preventive Services Task Force concluded that evidence of harms to men outweighed the evidence of benefits and recommended against screening men in the general population, regardless of age, until there is a better test. In addition, it is unclear how acceptable the PCA3 test is to men, since it involves prostate massage and urine collection, as opposed to a simple blood draw.

#### Interventions

No publications were identified that addressed the impact of adding PCA3 scores to the process of making decisions about proceeding to initial or repeat biopsies. Therefore, uncertainty remained about how the test would, or should, impact practice (e.g., all screen positive men, men in the “grey zone,” only for repeat biopsy decisions). For example, some may argue that clinicians could intervene based solely on a very elevated tPSA, but use additional markers to evaluate the remaining “grey zone” patients. This assumes that very elevated tPSA results are, by themselves, sufficiently informative for decisionmaking, and performance would not benefit from adding a second useful and independent marker like PCA3. Should PCA3 come into routine practice, it is not clear that use only in the “grey zone” would be an effective approach. Other issues that need clarification include: how the testing would be integrated into protocols for management of men with elevated tPSA or other risk factors, and whether physicians and patients would be receptive to using PCA3 results in the biopsy decision.

#### Comparisons

For this intended use, analysis of matched studies showed that PCA3 had slightly higher performance compared with the extent of tPSA elevations. This result is based on a summary analysis of matched within-study differences. Some studies reported the sensitivity and specificity for PCA3 and tPSA, but no studies actually reported a full matched analysis. A full matched analysis might provide 2×2 tables (or raw data for analysis) that allowed for direct comparison of PCA3 and a comparator in biopsy positive and biopsy negative samples (i.e., identifying those that both tests called positive, those both called negative, and those on which results were inconsistently called).

Studies of PCA3 and comparators other than tPSA (e.g., %fPSA, PSA density, PSA velocity or doubling time, complexed PSA, and externally validated nomograms) were inadequate or completely lacking. Even if PCA3 were a better secondary test than tPSA elevations (i.e., detected the same number of cancers, but with fewer biopsies in men without cancer), no data have shown that the identified men have the same type of prostate cancer (e.g., aggressive, insignificant/indolent). Fully matched analyses of existing raw data could help answer this question.

Although the focus is generally on comparing PCA3 with other prostate cancer markers, neither PCA3 nor tPSA would generally be considered to have high screening performance. To improve overall performance, both biomarkers as well as demographic information have been combined to predict the risk of prostate cancer. A multivariate patient-specific risk could be derived to be used in personalized decisionmaking regarding the benefits and harms of prostate biopsy.

#### Outcomes

Applicability was limited by the lack of information on the impact that reporting PCA3 scores in a clinical setting might have on intermediate and long-term outcomes. Of primary interest is whether patient decision-making regarding prostate biopsy would be impacted by reporting PCA3 results (improved diagnostic accuracy), and whether those decisions might result in higher positive predictive values (fewer biopsies performed in men without prostate cancer). Future studies might consider routinely combining the tPSA elevations with PCA3 results according to one of several validated nomograms contained in this review and quantifying these effects.

The population could be randomized into those with PCA3 included versus those receiving equivalent routine care without PCA3 testing being performed for clinical use. Both groups would have urine samples collected; one group would be immediately tested, while the other is tested at a later time. Cutoffs levels could be selected such that the sensitivities are similar in both groups, but fewer biopsies would be expected with the use of PCA3. This would be expected to result in a higher positive predictive value. Once the study is complete, patients could receive additional results as if they were had been randomized to the other group. This would allow for a fully matched study in which cancers were detected by both, as well as comparing the cancer detected by one or the other.

The remaining intermediate and longer term outcomes are more challenging due to the difficulty of collecting this information and the lack of validated surrogate measurements.

### KQ 3: Management of Biopsy Positive Patients

To determine the effectiveness of PCA3 and comparator tests in identifying patients who are candidates for active surveillance versus therapy, it is useful to assess the applicability of the findings in this review in a systematic manner, reflecting both on the design and execution of the included studies. However, no studies reported clinical outcomes of patients classified as low risk and enrolled in active surveillance versus those of high risk patients for whom treatment was recommended or elected. Two poor quality longitudinal studies reported on PCA3 and tPSA, but data could not be compared or combined. Detection of micrometastases in lymph node tissue as a predictor of biochemical recurrence-free survival was outside the inclusion criteria because no tPSA serum testing or PCA3 urine testing was performed along with lymph node extracts. The study of two-year followup on progression of patients from active surveillance to treatment had design flaws (e.g., partially matched, incomplete data).

## Implications for Clinical and Policy Decisionmaking

The published literature on the use of PCA3 and comparators in the two intended uses described in KQ 1 and KQ 2 was found to be limited and of poor quality. However, the recent FDA approval of the Gen-Probe PCA3 test for the intended use addressed in KQ 2 will raise awareness of this test, and possibly accelerate its adoption into practice. Practice guidelines currently recommend that a decision to have tPSA testing should be based on discussion between the physician and patient on the balance of potential benefits and harms. An increase in the knowledge base on the comparative effectiveness of PCA3 and other biomarkers is needed to support more informed choices.

The pros and cons of prostate cancer screening are impacted by any diagnostic or demographic information that will help physicians and their patients at risk for prostate cancer to make more informed decisions about biopsy. In biopsy-positive men, the impact of additional prognostic information regarding treatment options is of equal importance. However, in order to achieve the potential improvement in outcomes, reliable information is needed on the diagnostic accuracy of a new test and its comparators for the outcomes of interest.

Ultimately, direct or indirect evidence is also needed to measure improvement in long-term health outcomes related to the use of the test or risk tools and subsequent decisionmaking. This is particularly true following the recent report of the results of the PIVOT trial. Twelve-year followup of men with localized prostate cancer revealed no difference in all-cause or prostate cancer-specific mortality between men assigned to observation (watchful waiting) versus those randomly assigned to radical prostatectomy treatment.

## Limitations of the Comparative Effectiveness Review Process

One limitation of the review process was our decision to craft two separate KQs on biopsy decisionmaking – one for initial biopsies and one for repeat biopsies. We were able to identify only a small number of studies specifically targeting use for these specific populations. A majority of studies included populations with mixed biopsy histories (some patients were candidates for initial and others for repeat biopsy). This was addressed in our analysis, but reflected a characteristic of studies that was not anticipated when we scoped the KQs.

A second limitation was the need to develop an expanded QUADAS framework to address the quality of studies for the three KQs. QUADAS asks if the reference standard results are interpreted without knowledge of the index test results (in this case PCA3). However, it was also important to know if this was also true for the tPSA comparator test, and if partial verification bias was identified. For KQ 3 we observed that the endpoint of interest (patient clinical outcomes) seldom had appropriate clinical information. Again we added an additional QUADAS item to ensure we accounted for this information.

Finally, a procedural limitation was the implementation of the DistillerSR application (and the associated learning curve) concurrently with the beginning of this review. This was balanced by strengths of DistillerSR, such as improved efficiency of abstract review.

## Limitations of the Evidence Base

### KQs 1 and 2

There were several important limitations of the evidence base identified during the review. First, our inclusion criteria required that PCA3 and the comparator both be measured in the same population. These studies were identified as being “matched.” The aim was to reduce the well-known variability in diagnostic test performance due to factors such as underlying population demographics and study entry criteria. By requiring matched comparisons, the analyses would be expected to have reduced heterogeneity, as all differences were computed “within study.” However, requiring this matching certainly reduced the number of included studies. It is possible that additional conclusions may have been reached, if unmatched data had been included. On the other hand, the associated increase in variability may have rendered those data unhelpful.

Another challenging aspect of this review was integrating and interpreting the information for diagnostic accuracy. We found data to support the conclusion that PCA3 had slightly higher performance compared with the extent of tPSA elevation. Based on limited data, the two markers seemed to be relatively independent. Better performance would be expected by combining the two. We could have extended our modeling to include both markers, but chose not to because that was beyond the scope of the report. Such modeling was identified as a gap in knowledge.

A weighting scheme could have been developed to address the more precise estimates of effect size associated with larger, multicenter studies compared with smaller studies. Theoretically, weighting could impact the overall strengths of evidence. However, given the uniformly poor quality of individual studies and lack of needed data and analyses (e.g., matched contingency tables), it seemed unlikely that results of the analyses would have been improved by the added complexity of weighting.

There were limited data available when focusing only on initial, or only on repeat, prostate biopsy studies. Several addition studies reported a mixture of initial and repeat biopsies and others did not report this information at all. Examining the most common comparison (difference in AUCs for PCA3 and tPSA) showed no evidence of a relationship between the proportion of initial biopsies and AUC difference. Based on this, we combined all relevant studies, regardless of the proportion of initial biopsies.

The issue of verification bias for tPSA (and related comparators) was raised early in discussion of the analytical framework and Key Questions, and discussed with members of the TEP. Although this bias was not acknowledged by any of the included studies, we still chose to proceed with review of this comparator. An internal modeling exercise was undertaken to investigate the magnitude of the effect, and whether it affected the overall estimate of performance (i.e., ROC curve), performance estimate at a given cutoff (i.e., sensitivity/specificity at a PCA3 cutoff of 35), or both. We concluded that the effect of verification bias, while present, was unlikely to influence the overall estimate of performance (e.g., sensitivity at a given specificity), but had a strong influence on the sensitivity/specificity occurring at a given cutoff. This latter issue was addressed by modeling (Appendix J).

### KQ 3

The review of the literature revealed a lack of clinical followup after patients were placed into risk categories defined by the results of PCA3, other biomarker and pathological tests. In 11 of 13 studies, a reference or gold standard clinical endpoint (or validated surrogate) was lacking; in one poor-quality short-term study, PCA3 levels were not associated with disease progression.

## Research Gaps

### Overview

The PCA3 test is the key marker of this comparative effectiveness review. Its performance has been evaluated against/with six comparators (tPSA, %fPSA, PSA density, PSA velocity and doubling time, complexed PSA and externally validated nomograms) in three clinical scenarios (diagnostic accuracy and other intermediate outcomes in initial and repeat biopsied patients, and long term outcomes). With the exception of analyses of PCA3 and tPSA for the intermediate outcome of diagnostic accuracy, evidence was insufficient to answer the Key Question(s). These then, remain as gaps in evidence. Even for the PCA3/tPSA comparison and diagnostic accuracy, the strength of evidence was low. Thus, virtually all comparisons for all outcomes in this review could be considered gaps in knowledge. As these comparisons have been extensively reviewed in the Results and Discussion, they will not be repeated here.

Instead, the following sections deal with gaps in knowledge and their associated research question/future study design for cross-cutting issues, statistical/methodological issue related to multiple comparisons, or clinical issues that are relevant to multiple comparisons. The first section focuses on gaps for KQ 1 and KQ 2, while the second section focuses on KQ 3. Within each section, the specific gaps are gathered into two general areas: gaps relating to clinical issues, and those relating to methodological and statistical issues. For each identified gap, a potential study is designed and discussed.

### Gaps in Knowledge for KQs 1 and 2

#### Clinical Gaps in Knowledge

1. Does the addition of PCA3, either alone, or in combination with other markers, change prostate cancer biopsy decisionmaking for the patient or physician? Several studies (and our review) provide evidence that PCA3 may improve individualized risk prediction among men with an initial positive tPSA and/or DRE. However, no information is available on whether the clinical use of PCA3 can be effectively used to change current practice and what educational materials for patients and providers would support this process.
  Future Studies: Researchers might consider routinely combining the tPSA elevations with PCA3 results according to one of several validated nomograms contained in this review. The population could be randomized into those with PCA3 included as part of care (intervention) versus those receiving current care (control). Both groups would have urine samples collected; with the intervention group being immediately tested, while the control group members are tested later. Cutoffs levels in the two groups could be selected separately, such that the sensitivities (proportion of cancers detected) are expected to be similar in both groups. However, fewer biopsies would be expected among the intervention group. This would be expected to result in a higher positive predictive value. Once the study is complete (perhaps one year later), patients could receive additional test results, as if they had been randomized to the other group. This would allow for a fully matched analysis of which cancers were detected by both, as well as comparing the cancer detected by protocol with the other. These data could provide the type of data that would allow PCA3 to become a routine test, or be rejected as a potential contributor to the testing process.
2. What improvement in diagnostic accuracy is needed for any new test (e.g., PCA3) to provide sufficient value to impact biopsy decisionmaking? Were there clear guidance on how much improvement in diagnostic accuracy would be required to impact clinical protocols, the methods required to assess and accept/reject prospective markers would be streamlined. The relative importance of other factors to be considered (e.g., convenience, cost) would also be useful.
  Future Studies: Models can be created for various types of markers (e.g., continuous, categorical) with varying performance characteristics (e.g., low sensitivity but high specificity, high sensitivity but low specificity) that utilize, when possible, existing prostate cancer markers. Health care providers could evaluate the relative improvement in test performance and also provide guidelines regarding other factors that assay developers need to bear in mind.
3. How does PCA3 compare with the two commonly used add on tests of %fPSA and tPSA velocity/doubling time? These comparisons have been singled out, because both comparators have been recommended for clinical implementation (NCCN guidelines) but their use has generated some controversy rather than bringing consensus. Special attention should be paid toward looking at the relative performance of PCA3 against these two comparators at outcomes of decisionmaking as a way to avoid even further fracturing of protocols based on limited evidence.
  Future Studies: Since our restriction to “matched” studies identified no suitable data, it may be necessary to move to a broader set of inclusion criteria that does not require PCA3 and fPSA/tPSA velocity to be measured in the same dataset. However, prior to this undertaking, it would be prudent to validate that such a methodology is likely to provide reliable information (see Methodological and Statistical Gaps in Knowledge, Number 4).
4. Is PCA3 affected by key demographic features known to change risk for prostate cancer (ethnicity, family history)? These features were not well reported in most studies. Their impact on performance of PCA3 (as well as for some of the comparators) is unknown, but may be important.
  Future Studies: It may be possible to create collaboration between groups studying PCA3 such that pooled raw data might be created. If funding is available, it may also be possible to collect some of the relevant data that might be missing. From this combined dataset, it might be possible to answer some of these important questions.
5. What is the population from which the convenience samples of biopsied men have been selected? Nearly all of the “matched” studies were convenience samples gathered by centers performing prostate biopsies. These sites should be encouraged to gather information regarding the catchment population as a way to estimate the potential for partial verification bias.
  Future Studies: Few, if any studies included in this review identified a well-defined cohort of consecutive men identified as being at risk for prostate cancer and then followed their subsequent screening/diagnostic decision-making. This may require external funding, as a relatively high proportion of men identified as being at high risk will not chose to have a biopsy, according to current guidelines. However, with the collection of data that could reduce partial verification bias, and longer followup, it may be possible to account for, or more clearly delineate the effect of this bias on tPSA and on other related biomarkers.

#### Methodological and Statistical Gaps in Knowledge

1. What modeling approach/algorithm would allow for the easiest inclusion of new markers while reducing the need for independent verification? Most reported multivariate modeling of prostate cancer risk relies on logistic regression. These models are difficult to compare across studies and do not allow for simple inclusion of new variables without re-computing all coefficients. Other models, such as multivariate overlapping Gaussian distributions, may fit the markers of interest and might allow for easier comparisons as well as the ability to easily add (or subtract) markers as knowledge increases. This could also allow for validation of partial models, if some markers have not been measured.
  Future Studies: A review of select literature might provide a model methodology to use in designing an approach to multivariate modeling. One that has been successful in the area of prenatal screening for select congenital abnormalities (e.g., Down syndrome) is based on multi-dimensional overlapping Gaussian distributions. Such testing began in the early 1980s with both a demographic (maternal age) and a second trimester biochemical marker (alpha-fetoprotein). Currently, the most advanced protocol relies on these and three more second trimester and two first trimester biochemical markers, and a first trimester ultrasound markers. All are successfully combined to produce one risk that has been extensively validated as part of routine screening. Other models to explore might include those used in testing for BRCA1/2 mutations and breast cancer.
2. What factors influence whether partial verification bias impacts the tPSA and/or the matched tPSA/PCA3 ROC curves? Factors that could be explored include the range of cancer rates, the range of verification rates, and the use of continuous versus categorical verification corrections. There have been only a handful of reports on tPSA use that address partial verification bias. A better understanding of this issue is needed if PCA3 is to be properly evaluated in the context of the widespread use of tPSA as triage test for treatment decisions.
  Future Studies: Both modeling and examining select datasets might help provide an answer to this question in the specific setting of interest. Our modeling suggests that verification bias introduced by decision-making relying on tPSA elevations has a strong impact on the sensitivity/specificity at a given tPSA cutoff. However, we found that it does not distort the ROC curve to any great extent. If this can be verified, it might result in the reexamination of previous studies where verification bias was thought to have made the reliable interpretation of results impossible.
3. What absolute cutoffs or continuous values can be assigned to the PCA3 assay across the ROC curve? While the analyses in this review provide an approximate ROC curve allowing interpolation of sensitivity and false positive rates across the range of values, the absolute PCA3 and tPSA cutoffs may not be appropriate in every setting.
  Future Studies: The modeling studies suggested for the previous gap could also help resolve this issue. Is it possible to account for verification bias to such an extent that reliable performance estimates can be computed?
4. Does our review's literature restriction to matched studies provide more consistent and reliable comparisons than had the review used independent summaries of each marker's performance? Given the increasing emphasis on comparative effectiveness analyses, a formal comparison of these two methods might provide useful guidance to future reviews.
  Future Studies: A structured evidence review between the performance of PCA3 and tPSA could be performed without restricting data to matched studies. That is, a summary review of PCA3 performance (via an ROC curve) could be compared with a similar independent summary of the performance of tPSA elevations to identify prostate cancer. The two independent ROC curves could then be compared and the difference compared with our matched differences. As a check on precision, one could examine the tPSA analysis and determine whether the “grey zone” studies differ from the studies having no restriction on the tPSA elevation. Our matched analyses clearly show this difference and are likely an indicator of reliability.
5. Does the reporting of matched analyses improve the usefulness of the dataset? Although our inclusion criteria required PCA3 and a comparator to be measured in the same population, it did not require a formal matched analysis to be reported. Thus, the reports did not allow for a comparison of how many men with cancer were identified by both markers, neither of the markers, or only one or the other marker. Requesting such analyses be performed using existing datasets would help answer this question.
  Future Studies: It may be possible to collaborate with authors of selected studies to obtain original data, in which a true matched analysis can be performed. The study (or studies) should be large, and have information available about the “aggressiveness” of the cancers identified. Then, two 2×2 tables could be created (one for positive biopsies, one for negative) comparing the results of the two tests at chosen cutoffs. A series of these tables could be created at fixed sensitivities or fixed false positive rates. One could imagine that the data examined this way will provide insights into the types of cancers identified by both, one, or neither of the tests.
6. How can researchers studying PCA3 and other comparators be encouraged to provide proper reporting of statistical details? Proper reporting of statistical information on studies of PCA3 and the comparators was often absent in articles evaluated for this review. These include: confidence intervals, standard errors, prediction limits and other measure of dispersion and precision for all effect measures as well as good summary parameters for their data (e.g., selected centiles, medians, geometric means and trimmed logarithmic standard deviations). All studies identified were of poor quality when rated by QUADAS.
  Future Studies: Statisticians, epidemiologists and others with experience in analyzing screening and diagnostic tests are in the process of setting guidelines for evaluation. Those guidelines should be reviewed with an eye towards ensuring that: (1) appropriate statistics are used (e.g., needed transformations performed), (2) methods to allow for raw data are available for additional analyses, (3) confidence intervals/standard errors are provided more consistently, when possible, and (4) suitable data are provided to allow for joint meta-analyses of multiple tests.
7. How can systematic differences in marker levels due to reagents/manufactures be minimized or accounted for by analysis? Systematic differences between reagents/manufacturers exist for at least some of the markers that can influence the tests performance at fixed mass unit cutoffs.
  Future Studies: Review of external proficiency testing results may provide guidance as to what steps may be needed. Attempting to harmonize results is one possibility, but this can take time and may not ever succeed. Mathematical methods that use a normalizing function (z-score, multiples of the median) could also be explored and tested against existing datasets to see whether more consistent patient-specific information can be provided from the test results.

### Gaps in Knowledge for KQ 3

#### Clinical Gaps in Knowledge

1. What should the gold standard be for defining intermediate outcomes for use in establishing the clinical validity of PCA3? Studies evaluating PCA3 as selection criteria for entering a program of active surveillance have focused on how well PCA3 compares with other selection criteria (tumor volume, tumor grade, clinical stage, Epstein criteria, etc.). These intermediate measures were not well described in most studies and vary considerably between studies.
  Future studies: A consensus conference or statement from a relevant professional organization might help harmonize the definitions of intermediate outcomes such that research studies can be combined. However, the only sure way to determine the appropriateness of intermediate outcomes is to engage in long-term followup of a select cohort of men with sufficient numbers that even relatively uncommon events (e.g., death due to prostate cancer) can be quantified.
2. How can PCA3 alone or when integrated with one or more comparators be used to improve decisionmaking about whether to choose active surveillance or aggressive treatment for biopsy positive men? No studies have yet examined the impact of PCA3 on decisionmaking when compared with existing criteria such as the Epstein Criteria. There have been no outcomes studies performed to determine how well PCA3 scores predict the behavior of a particular tumor over time.
  Future Studies: This is similar to question 1 (Clinical Gap in Knowledge for KQ 1/KQ 3), but studies would focus on other intermediate outcomes. Based on this review, and the recent FDA approval of PCA3, it should be possible to establish protocols that use PCA3 and begin developing studies that examine and validate intermediate health outcomes.

#### Methodological and Statistical Gaps in Knowledge

1. Can intermediate outcomes, such as cancer classifications of aggressive or insignificant/indolent tumors be properly validated? Given that current clinical practice guidelines employ unvalidated, or partially validated intermediate outcomes, it is difficult to design studies that would provide proper validation. Exploration of what study designs or re-analyses of existing dataset might provide stronger validation of select intermediate measures could be undertaken.
  Future Studies: To validate intermediate outcomes, they must be standardized (addressed earlier) and then associated with longer term health outcomes. This might require longitudinal studies with followup of five to ten years. Some of these studies are underway and preliminary results have been reported, but longer timeframes need to be utilized.
2. What is the impact of use of PCA3 on long-term health outcomes when used to help select patients for active surveillance versus aggressive treatment?
  Future Studies: Longitudinal studies that track patients under both active surveillance and aggressive treatment would be helpful in determining this impact. Many of the ongoing studies are focused on only the active surveillance group, and these should be expanded to at least include a subset of those undergoing treatment for comparison.