# DistillerSR Data Extraction Forms

Study Description

Participant Characteristics & Inclusion Criteria

Specimen/Assay Description

PCA3 by Cutoff

Total PSA by Cutoff (Identical format used for total PSA, percent free PSA, PSA density, PSAdoubling time, PSA velocity, complexed PSA, externally validated nomograms)

Prostate biopsy and prostatectomy

Gleason Score

Pathological Staging

Epstein Criteria

AUC

Matched Analysis Data

Quality - QUADAS