# Quality Assessment of Studies Addressing KQ 1/KQ 2 and KQ 3

Table F-1 PCA3 testing for the diagnosis and management of prostate cancer—quality of studies addressing KQs 1 and 2

QUADAS Criteria | Adam 2011^1^ | Ankerst 2010^2^ | Aubin 2010^3^ | Auprich 2011^4^ | Bollito 2012^5^ | Cao 2011^6^ | de la Taille 2011^7^ | Deras 2008^8^ | FDA Summary9 | Ferro 2012^10^ | Goode 2012^11^ | Hessels 2010^12^ | Mearini 2010^13^ | Nyberg 2010^14^ | Ochai 2011^15^ | Ouyang 2009^16^ | Pepe 2012^17^ | Perdona 2011^18^ | Ploussard 2010^19^ | Rigau 2008^20^ | Roobol 2010^21^ | Schilling 2011^22^ | Wang 2009^23^ | Wu 2012^24^
Representative study subjects | Yes | Yes | Yes | Yes | Uncertain^a,b^ | Uncertain^a^ | Yes | Yes | No | Uncertain^b^ | Yes | Yes | Uncertain^a^ | Yes | Yes | Uncertain^a^ | Uncertain | Yes | Yes | Yes | Yes | No | Yes | Yes
Selection criteria clear | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Uncertain
Reference standard correctly identifies PCa | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Acceptable period between index test and reference standard | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Uncertain | Uncertain | Yes
All or described subset diagnosed by reference standard | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
All patients received reference standard, regardless of index result | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference standard was independent of the index test | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Index test adequately described | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference standard adequately described | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Uncertain | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Index test results interpreted without knowledge of reference standard results^c^ | Yes | Uncertain | Yes | Uncertain | Uncertain | Uncertain | Yes | Uncertain | Uncertain | Uncertain | Yes | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain
Reference standard results interpreted without knowledge of index test^c^ | Yes | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Yes | Uncertain | Yes | Yes | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain
Clinical data for interpretation of test results were the same as those expected in practice | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Uninterpretable/intermediate test results were reported | No | No | No | No | Uncertain | No | No | No | No | No | No | No | Yes | No | No | No | No | No | No | No | No | No | No | No
Withdrawals from the study were explained | Yes | None reported | None reported | None reported | Yes | Yes | Uncertain for %fPSA | Yes | Yes | None reported | None reported | Yes | None reported | None reported | Yes | Yes | None reported | None reported | Yes | Yes | Yes | Yes | Yes | None reported
Added criteria:
Reference standard results interpreted without knowledge of the tPSA test | No | No | No | No | No | No | No | No | Uncertain | No | Uncertain | No | No | No | No | No | Uncertain | No | No | No | No | No | No | N
Partial verification bias d | Yes | Yes | Yes^e^ | Yes | Yes | Yes | Yes^e^ | Yes | Uncertain but likely | Yes^e^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^e^ | Yes^e^ | Yes | Yes | Yes | Yes | Yes
Score | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor

The index test is PCA3 except for the last three lines, which refer to the tPSA comparator. The reference standard is biopsy.

a ‘Uncertain’ indicates that information was not provided to determine the answer to the question; it does not mean that the answer to the question is ‘No’.

b Uncertain because these studies excluded men with positive DRE.

c Information on blinding is often not reported, so the category of Uncertain does not mean that blinding did not occur.

d Partial verification bias because men with elevated tPSA and/or positive digital rectal exam who did not accept biopsy are considered missing.

e There is an additional partial verification bias in this study due to a limitation on the range of tPSA values that are included (i.e., the so called ‘grey zone’ results in the range of 2.5 to 10 or 20 ng/mL).

Table F-2 PCA3 testing for the diagnosis and management of prostate cancer—quality of studies addressing KQ3

QUADAS Criteria | Auprich 2011^25^ | Durand 2012^26^ | Kasuda 2011^27^ | Liss 2011^28^ | Nakanishi 2008^29^ | Ploussard 2010^30^ | Tosian 2010^31^ | van Poppel 2011^32^ | Vlaeminck-Guillem 2011^33^ | Whitman 2008^34^
Representative study subjects | Yes | Yes | Uncertain^a^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Selection criteria clear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference standard correctly identifies PCa or other outcome | Yes | Yes | Uncertain | Yes | Yes | Yes | Uncertain | Yes | Yes | Yes
Acceptable period between index test and reference standard | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
All or described subset diagnosed by reference standard | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
All patients received reference standard, regardless of index result | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference standard was independent of the index test | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Index test adequately described | Yes | Yes | Uncertain | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Reference standard adequately described | Yes | Yes | No | Yes | Yes | Yes | No | Yes | Yes | Yes
Index test results interpreted without knowledge of reference standard results^b^ | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Yes | Uncertain | Uncertain
Reference standard results interpreted without knowledge of index test^b^ | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Uncertain | Yes | Uncertain
Clinical data for interpretation of test results were the same as those expected in practice | Yes | Yes | Yes | Yes | Yes | Yes | Uncertain | Yes | Yes | Yes
Uninterpretable/intermediate test results were reported | No | No | Yes | No | No | No | Yes | No | No | No
Withdrawals from the study were explained | Yes | None reported | Uncertain | Yes | None reported | None reported | No | None reported | Uncertain | None reported
Added criterion: Clinical followup | No | No | Yes | No | No | No | Yes | No | No | No
Score | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor | Poor

a ‘Uncertain’ indicates that information was not provided to determine the answer to the question; it does not mean that the answer to the question is ‘No’.

b Information on blinding is often not reported, so the category of ‘Uncertain’ does not mean that blinding did not occur.

## References

1 Adam A, Engelbrecht MJ, Bornman MS, et al. The role of the PCA3 assay in predicting prostate biopsy outcome in a South African setting. BJU Intl. 2011. Apr. 20. [pmid: 21507188].
2 Ankerst DP, Groskopf J, Day JR, et al. Predicting prostate cancer risk through incorporation of prostate cancer gene 3. J Urol. Oct. 2008;180(4):1303-8. discussion 08. [pmid: 18707724].
3 Aubin SM, Reid J, Sarno MJ, et al. PCA3 molecular urine test for predicting repeat prostate biopsy outcome in populations at risk: validation in the placebo arm of the dutasteride REDUCE trial. J Urol. Nov. 2010;184(5):1947-52. [pmid: 20850153].
4 Auprich M, Augustin H, Budaus L, et al. A comparative performance analysis of total prostate-specific antigen, percentage free prostate-specific antigen, prostate-specific antigen velocity and urinary prostate cancer gene 3 in the first, second and third repeat prostate biopsy. BJU Int. Jun. 2012;109(11):1627-35. [pmid: 21939492].
5 Bollito E, De Luca S, Cicilano M, et al. Prostate cancer gene 3 urine assay cutoff in diagnosis of prostate cancer: a validation study on an Italian patient population undergoing first and repeat biopsy. Analytical and quantitative cytology and histology / the International Academy of Cytology [and] American Society of Cytology. Apr. 2012;34(2):96-104. [pmid: 22611765].
6 Cao DL, Ye DW, Zhang HL, et al. A multiplex model of combining gene-based, protein-based, and metabolite-based with positive and negative markers in urine for the early diagnosis of prostate cancer. Prostate. May. 15. 2011;71(7):700-10. [pmid: 20957673].
7 de la Taille A, Irani J, Graefen M, et al. Clinical evaluation of the PCA3 assay in guiding initial biopsy decisions. J Urol. Jun. 2011;185(6):2119-25. [pmid: 21496856].
8 Deras IL, Aubin SM, Blase A, et al. PCA3: a molecular urine assay for predicting prostate biopsy outcome. J Urol. Apr. 2008;179(4):1587-92. [pmid: 18295257].
9 U.S. Food and Drug Administration. Summary of Safety and Effectiveness Data: PROGENSA PCA3 Assay. 2012. July 16, 2012. http://www.accessdata.fda.gov/cdrh_docs/pdf10/P100033b.pdf.
10 Ferro M, Bruzzese D, Perdona S, et al. Predicting prostate biopsy outcome: prostate health index (phi) and prostate cancer antigen 3 (PCA3) are useful biomarkers. Clin Chim Acta. Aug. 16. 2012;413(15-16):1274-8. [pmid: 22542564].
11 Goode RR, Marshall SJ, Duff M, et al. Use of PCA3 in detecting prostate cancer in initial and repeat prostate biopsy patients. Prostate. 2012. May. 14. [pmid: 22585386].
12 Hessels D, van Gils MP, van Hooij O, et al. Predictive value of PCA3 in urinary sediments in determining clinico-pathological characteristics of prostate cancer. Prostate. Jan. 1. 2010;70(1):10-6. [pmid: 19708043].
13 Mearini E, Antognelli C, Del Buono C, et al. The combination of urine DD3(PCA3) mRNA and PSA mRNA as molecular markers of prostate cancer. Biomarkers. Jun. 2009;14(4):235-43. [pmid: 19489685].
14 Nyberg M, Ulmert D, Lindgren A, et al. PCA3 as a diagnostic marker for prostate cancer: a validation study on a Swedish patient population. Scand J Urol Nephrol. Dec. 2010;44(6):378-83. [pmid: 20961267].
15 Ochiai A, Okihara K, Kamoi K, et al. Prostate cancer gene 3 urine assay for prostate cancer in Japanese men undergoing prostate biopsy. Int J Urol. Mar. 2011;18(3):200-5. [pmid: 21332814].
16 Ouyang B, Bracken B, Burke B, et al. A duplex quantitative polymerase chain reaction assay based on quantification of alpha-methylacyl-CoA racemase transcripts and prostate cancer antigen 3 in urine sediments improved diagnostic accuracy for prostate cancer. J Urol. Jun. 2009;181(6):2508-13. discussion 13-4. [pmid: 19371911].
17 Pepe P, Aragona F. PCA3 score vs PSA free/total accuracy in prostate cancer diagnosis at repeat saturation biopsy. Anticancer Res. Dec. 2011;31(12):4445-9. [pmid: 22199313].
18 Perdona S, Cavadas V, Di Lorenzo G, et al. Prostate cancer detection in the “grey area” of prostate-specific antigen below 10 ng/ml: head-to-head comparison of the updated PCPT calculator and Chun's nomogram, two risk estimators incorporating prostate cancer antigen 3. European urology. Jan. 2011;59(1):81-7. [pmid: 20947244].
19 Ploussard G, Haese A, Van Poppel H, et al. The prostate cancer gene 3 (PCA3) urine test in men with previous negative biopsies: does free-to-total prostate-specific antigen ratio influence the performance of the PCA3 score in predicting positive biopsies?. BJU Int. Oct. 2010;106(8):1143-7. [pmid: 20230386].
20 Rigau M, Morote J, Mir MC, et al. PSGR and PCA3 as biomarkers for the detection of prostate cancer in urine. Prostate. Dec. 1. 2010;70(16):1760-7. [pmid: 20672322].
21 Roobol MJ, Schroder FH, van Leeuwen P, et al. Performance of the prostate cancer antigen 3 (PCA3) gene and prostate-specific antigen in prescreened men: exploring the value of PCA3 for a first-line diagnostic test. European urology. Oct. 2010;58(6):475-81. [pmid: 20637539].
22 Schilling D, Hennenlotter J, Munz M, et al. Interpretation of the prostate cancer gene 3 in reference to the individual clinical background: implications for daily practice. Urol Int. 2010;85(2):159-65. [pmid: 20424427].
23 Wang R, Chinnaiyan AM, Dunn RL, et al. Rational approach to implementation of prostate cancer antigen 3 into clinical care. Cancer. Sep. 1. 2009;115(17):3879-86. [pmid: 19517474].
24 Wu AK, Reese AC, Cooperberg MR, et al. Utility of PCA3 in patients undergoing repeat biopsy for prostate cancer. Prostate Cancer Prostatic Dis. Mar. 2012;15(1):100-5. [pmid: 22042252].
25 Auprich M, Chun FK, Ward JF, et al. Critical assessment of preoperative urinary prostate cancer antigen 3 on the accuracy of prostate cancer staging. Euro Urol. Jan. 2011;59(1):96-105. [pmid: 20980098].
26 Durand X, Xylinas E, Radulescu C, et al. The value of urinary prostate cancer gene 3 (PCA3) scores in predicting pathological features at radical prostatectomy. BJU Int. Jul. 2012;110(1):43-49. [pmid: 22221521].
27 Kusuda Y, Miyake H, Kurahashi T, et al. Assessment of optimal target genes for detecting micrometastases in pelvic lymph nodes in patients with prostate cancer undergoing radical prostatectomy by real-time reverse transcriptase-polymerase chain reaction. Urol Oncol. 2011. May. 18. [pmid: 21600799].
28 Liss MA, Santos R, Osann K, et al. PCA3 molecular urine assay for prostate cancer: association with pathologic features and impact of collection protocols. World J Urol. Oct. 2011;29(5):683-8. [pmid: 21152924].
29 Nakanishi H, Groskopf J, Fritsche HA, et al. PCA3 molecular urine assay correlates with prostate cancer tumor volume: implication in selecting candidates for active surveillance. J Urol. May. 2008;179(5):1804-9. discussion 09-10. [pmid: 18353398].
30 Ploussard G, Durand X, Xylinas E, et al. Prostate cancer antigen 3 score accurately predicts tumour volume and might help in selecting prostate cancer patients for active surveillance. European urology. Mar. 2011;59(3):422-9. [pmid: 21156337].
31 Tosoian JJ, Loeb S, Kettermann A, et al. Accuracy of PCA3 measurement in predicting short-term biopsy progression in an active surveillance program. J Urol. Feb. 2010;183(2):534-8. [pmid: 20006883].
32 van Poppel H, Haese A, Graefen M, et al. The relationship between Prostate CAncer gene 3 (PCA3) and prostate cancer significance. BJU Int. Feb. 2012;109(3):360-6. [pmid: 21883822].
33 Vlaeminck-Guillem V, Devonec M, Colombel M, et al. Urinary PCA3 score predicts prostate cancer multifocality. J Urol. Apr. 2011;185(4):1234-9. [pmid: 21334023].
34 Whitman EJ, Groskopf J, Ali A, et al. PCA3 score before radical prostatectomy predicts extracapsular extension and tumor volume. J Urol. Nov. 2008;180(5):1975-8. discussion 78-9. [pmid: 18801539].