# Quality Assessment Criteria and Category Definitions for Nonrandomized Comparative Intervention Studies84,85

- Were the sample definition and selection prospective or retrospective?
- Were inclusion/exclusion criteria clearly described?
- Were participants selected to be representative?
- Was there an attempt to balance groups by design?
- Were baseline prognostic characteristics clearly described and groups shown to be comparable?
- Were interventions clearly specified?
- Were participants in treatment groups recruited within the same time period?
- Was there an attempt by investigators to allocate participants to treatment groups in an attempt to minimize bias?
- Were concurrent/concomitant treatments clearly specified and given equally to treatment groups?
- Were outcome measures clearly valid, reliable, and equally applied to treatment groups?
- Were outcome assessors blinded?
- Was the length of followup adequate?
- Was subject attrition below an overall high level (<20 percent)?
- Was the difference in attrition between groups below a high level (<15 percent)?
- Did the analysis of outcome data incorporate a method for handling confounders such as statistical adjustment?

The rating of intervention studies encompassed three quality categories:

- Good studies meet all criteria; comparable groups were assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions are spelled out clearly; all important outcomes were considered; appropriate attention was given to confounders in analyzing data.
- Fair studies had any or all of the following problems, but without the fatal flaws noted in the “poor” category below; comparable groups were assembled initially, but some questions remain about whether some (although not major) differences occurred with followup; measurement instruments were acceptable (although not the best) and were generally applied equally; some, but not all, important outcomes were considered; some, but not all, potential confounders were accounted for.
- Poor studies have any of the following fatal flaws; groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments were used or not applied at all equally among groups (including not masking outcome assessment); key confounders were given little or no attention.