# Search Strategy for Grey Literature

Regulatory Information
- FDA
  Source: http://www.fda.gov/default.htm
  Date searched: 5/15/2012
  Search strategy: key word “PCA3”
  Records: 219

Clinical trial registries
- NIH database
  Source: http://clinicaltrials.gov/
  Date searched: 5/15/2012
  Search strategy: PCA3 [ALL-FIELDS] AND “Completed” [OVERALL-STATUS]
  Records: 6
- BioMed central
  Source: http://www.controlled-trials.com/mrct/
  Date searched: 8/15/2011
  Search strategy: “PCA3” for completed trials
  Records: 0
- WHO International Clinical Trials Registry Platform Search Portal
  Source: http://apps.who.int/trialsearch/
  Date searched: 8/15/2011
  Search strategy: Search String = “PCA3” for ALL recruitment status trials
  Records: 0

Conference papers and abstracts
- American College of Medical Genetics (ACMG)
  Source: http://submissions.miracd.com/acmg/
  Date searched: 8/15/2011
  Search strategy: search string “PCA3 OR Prostate Cancer OR Prostate Cancer Screening”
  Records: 2
- American Society of Clinical Oncology (ASCO)
  Source: http://www.gucasym.org/PastSymposia.aspx
  Date searched: 8/15/2011
  Search strategy: search string “PCA3”
  Records: 6
- American Urological Association (AUA)
  Source: http://www.auanet.org/content/clinical-practice-guidelines/clinical-practice-guidelines.cfm
  Date searched: 8/15/2011
  Search strategy: search string “PCA3”
  Records: 26
- Association of Molecular Pathology (AMP)
  Source: http://www.amp.org/meetings/past_meetings.cfm
  Date searched: 8/15/2011
  Search strategy: not searchable without login
  Records: 0
- College of American Pathologists (CAP)
  Source: http://www.cap.org/apps/cap.portal?_nfpb=true&_pageLabel=reference
  Date searched: 8/15/2011
  Search strategy: search string “PCA3 OR Prostate Cancer OR Prostate Cancer Screening”
  Records: 240
- National Comprehensive Cancer Network (NCCN) Annual Congress
  Source: http://www.nccn.org/index.asp
  Date searched: 8/15/2011
  Search strategy: search string “PCA3”
  Records: 0
- Prostate Cancer Research Initiative (PCRI)
  Source: http://www.prostate-cancer.org/pcricms/
  Date searched: 8/15/2011
  Search strategy: search string “PCA3”
  Records: 0

Organizations publishing Guidance or Review Documents
- Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS)
  Source: http://www.aetmis.gouv.qc.ca/site/home.phtml
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 0
- Australia and New Zealand Horizon Scanning Network (ANZHSN)
  Source: http://www.horizonscanning.gov.au/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 0
- Canadian Agency for Drugs and Technologies in Health (CADTH)
  Source: http://cadth.ca/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 3 (all excluded; not relevant)
- The Cochrane Collaboration (Cochrane)
  Source: http://summaries.cochrane.org/
  Date searched: 8/15/2011
  Search strategy: search string string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR“differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 0
- European network for Health Technology Assessment (EUnetHTA)
  Source: http://www.eunethta.eu/Public/Search/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 0
- EuroGenTest
  Source: http://www.eurogentest.org/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 0
- National Guideline Clearinghouse (NGC)
  Source: http://www.guideline.gov/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”). – searches done in different combinations using the above combinations.
  Records: 4
- National Institute for Clinical Excellence (NICE)
  Source: http://www.nice.org.uk/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 1 (excluded; not relevant)
- United Kingdom Health Technology Assessment Programme (UK HTA)
  Source: http://www.hta.ac.uk/
  Date searched: 8/15/2011
  Search strategy: search string (“PCA3” OR “prostate cancer antigen 3” OR “DD3” OR “differential display code 3” OR “biomarkers”) AND (“prostate cancer” OR “prostatic cancer”).
  Records: 7

Government documents
- RePORTER
  Source: http://projectreporter.nih.gov/reporter.cfm
  Date searched: 8/15/2011
  Search strategy: key word “PCA3”
  Records: 26
- HSRPROJ
  Source: http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm
  Date searched: 8/15/2011
  Search strategy: key word “PCA3”
  Records: 0
- AHRQ GOLD
  Source: http://gold.ahrq.gov/projectsearch/
  Date searched: 8/15/2011
  Search strategy: key word “PCA3”
  Records: 0

Manufacturer database
- Source: GenProbe Response to the Request for Scientific Information
  Date posted: 12/7/2011
  Date searched: Not applicable
  Search strategy: Not applicable
  Records: 27

## References for Review and Abstraction from the Grey Literature Search

PUBMED ID: NA

Authors: Submitted by Gen-Probe, Inc.

Title: Summary of Safety and Effectiveness Data: PROGENSA PCA3 Assay.

Citation: U.S. Food and Drug Administration, http://www.accessdata.fda.gov/cdrh_docs/pdf10/P100033b.pdf, accessed June 1, 2012.

Selected Test Manufacturers for Contact

Manufacturer | Registered® / Trademark Name™ | Test Type | Comment
GenProbe | Gen-Probe PROGENSA PCA3 | FDA Approval announced 2/17/12 | Responded pre-FDA approval
Quest Diagnostics | PCA3 Diagnostic Test | LDT | Did not respond
Bostwick Laboratories | PCA3Plus^®^ | LDT | Did not respond
Laboratory Corporation of America | CaPDetect: PCA3 | LDT | Did not respond

Contact Information

Gen Probe Incorporated | 10210 Genetic Center Drive San Deigo, CA 92121 Phone: 858-410-8000 http://www.genprobe.com
Quest Diagnostics | 3 Giralda Farms Madison, NJ 07940 Phone: 800-222-0446 http://www.questdiagnostics.com
Bostwick Laboratories | 4355 Innslake Drive Glen Allen, VA 23060 Phone: 877-865-3262 http://www.bostwicklaboratories.com
Laboratory Corporation of America | 358 South Main Street Burlington, NC 27215 Phone: 336-584-5171 http://www.labcorp.com