# Data Elements

- Study description and design, including:
  ○ Country, institutions and enrollment period
  ○ Enrollment number and flow of subjects through PCA3 and comparator testing, prostate biopsy, treatment and followup
  ○ Source of funding and authors' disclosures of industry relationship(s)
  ○ Blinding of index and comparator test results to pathologists and of biopsy/prostatectomy results to laboratorians conducting tests
- Participant characteristics, including
  ○ Demographics of the study population
  ○ Criteria for study inclusion (e.g., age, race, elevated tPSA, abnormal DRE, previous negative or positive biopsy, family history)
  ○ Comorbidities or potential effect modifiers
- Prostate biopsy (KQ1-3) and radical prostatectomy (KQ3) findings, including:
  ○ Cores per biopsy, positive cores per biopsy
  ○ Gleason scores
  ○ Other biomarkers (e.g., PSA density)
  ○ Pathological markers
  ○ Percentage of ‘insignificant findings’ based on identified criteria
  ○ Clinical and pathological staging of tumor from prostatectomy
- PCA3 specimens and assay characteristics, including:
  ○ Method of collection
  ○ Handling/storage
  ○ PCA3 assay used (e.g., specific test or method, housekeeping gene used, reporting unit)
- PCA3 and comparator test results, including:
  ○ Specified comparators were total PSA, PSA velocity or doubling time, percent free PSA, PSA density, complexed PSA, externally validated nomograms or risk assessment programs
  ○ Cutoffs/thresholds/action points
  ○ Summary measures (e.g., mean or median values), stratified by negative or positive biopsy result, cutoff, or other variables
- Intermediate outcomes, including:
  ○ Diagnostic accuracy data, including area under the ROC (receiver operating characteristics) curve (AUC), diagnostic odds ratios, clinical sensitivity and specificity, positive and negative predictive values
  ○ Data on decisionmaking related to biopsy, with definition of study design, description of participants and instruments used, and outcome measures
  ○ Data on harms related to biopsy, with definition of study design, description of participants and instruments used, and findings
- Long-term outcomes, including:
  ○ Mortality, including overall and prostate cancer-specific mortality and 10-year survival
  ○ Morbidity, including local progression, distant metastases, pain, and biochemical failure
  ○ Treatment-related morbidity, including urinary incontinence, impotence, rectal incontinence and prostatitis
  ○ Quality-of-life measures
- Statistical analyses, including:
  ○ Statistical tests used
  ○ Confidence intervals for performance estimates
  ○ p values for comparisons
  ○ Assessment of potential biases
- Quality assessment:
  ○ Selection of participants to avoid bias
  ○ Adequate descriptions of study design and process and reasons for cases lost
  ○ Use of blinding
  ○ Methods are described below in the section entitle Assessment of Methodological Quality of Individual Studies