# Search Strategies for PCA3 Testing for the Diagnosis and Management of Prostate Cancer

## Search Strategies

### 02/09/11

((prostate cancer antigen 3, human [SUBSTANCE NAME] OR pca3 [TIAB] OR (prostate cancer antigen 3 [TIAB]) OR (prostatic cancer antigen 3 [TIAB]) OR DD3 antigen, human [SUBSTANCE NAME] OR (differential display code 3 [TIAB]) OR dd3 [TIAB]) OR (prostatic neoplasms [MH] AND ((clinical* [TIAB] AND (significan* [TIAB] OR importan* [TIAB])) OR aggressive [TIAB] OR biops* [TIAB]) AND (nomogram [TIAB] OR (neural [TIAB] AND network [TIAB])))) OR ((((((clinical* [TIAB] AND (significan* [TIAB] OR importan* [TIAB])) OR aggressive [TIAB] OR biops* [TIAB]) AND prostate-specific antigen [MH]) AND prostatic neoplasms [MH]) AND (predict* [TIAB] OR prognos* [TIAB])))

### Revised Searches (PubMed only)

“prostate cancer antigen 3, human” [Supplementary Concept] OR

(“differential display code 3 antigen” OR DD3) Field: Title/Abstract OR

(PCA3 OR “prostate cancer antigen 3”) Field: Title/Abstract

- This was the test-specific set= 208 in PubMed

Additionally -

“Prostatic Neoplasms”[Mesh] OR “prostatic neoplasms” OR “prostate neoplasms” OR “prostatic cancer” OR “prostate cancer”

AND

(nomogram OR (neural AND network) OR antigen OR antigens) Field: Title/Abstract

AND

((clinical* AND (significan* OR importan* OR aggressive OR biops*)) OR predict* OR prognos* OR (select* OR decid* OR decision* OR choos* OR choice*)) Field: Title/Abstract

NOT the test-specific set

AND Limits: Humans, Publication Date from 1/1/1990 to search date.

### PUBMED on 8/9/11

#### Test specific search

“prostate cancer antigen 3, human” [Supplementary Concept] OR PCA3 OR DD3 OR DD3PCA3 OR “DD3(PCA3)” OR “prostate cancer gene 3” OR “prostate cancer antigen 3” OR progensa OR (“differential display code 3” AND (prostate OR prostatic))

AND

Limits: Humans, English = 159

#### Comparators search

1. [underlined: PSA/total PSA]
  “Prostate-Specific Antigen”[Mesh] OR “total PSA” OR “total prostate specific antigen” OR “prostate specific antigen” OR (PSA AND (prostate OR prostatic))
  AND
  Publication type: meta-analysis OR Subset: systematic review OR “meta-analysis” OR metaanalysis OR “systematic review”
  AND
  Limits: Humans, English = 480
2. [underlined: PSA velocity/percent free PSA/complexed PSA/externally validated nomograms]
  “PSA velocity” OR “prostate specific antigen velocity” OR “percent free PSA” OR “free prostate specific antigen” OR “complexed PSA” OR “c-PSA” OR “complexed prostate specific antigen” OR (nomogram* AND (prostatic OR prostate))
  AND
  Publication Types: Clinical Trial, Meta-Analysis, Practice Guideline, Randomized Controlled Trial, Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV, Comparative Study, Controlled Clinical Trial, Multicenter Study OR Subset: systematic review
  AND
  Limits: Humans, English = 521

### EMBASE on 8/15/11

#### Test specific search

‘prostate cancer antigen 3, human’ OR pca3 OR dd3 OR dd3pca3 OR ‘dd3(pca3)’ OR ‘prostate cancer gene 3’ OR ‘prostate cancer antigen 3’ OR progensa OR (‘differential display code 3’ AND (‘prostate’/exp OR prostatic))

AND

‘prostate’/exp OR prostatic

AND

Limits: Humans, English = 64

#### Comparators search

1. [underlined: PSA/Total PSA]
  ‘total psa’ OR ‘total prostate specific antigen’ OR ‘prostate specific antigen’/exp OR (psa AND (‘prostate’/exp OR prostatic))
  AND
  ‘meta analysis’/exp OR ‘systematic review’/exp OR ‘metaanalysis’/exp
  AND
  Limits: Humans, English 258
2. [underlined: PSA velocity/percent free PSA/complexed PSA/externally validated nomograms]
  ‘psa velocity’ OR ‘prostate specific antigen velocity’ OR ‘percent free PSA’ OR ‘free prostate specific antigen’ OR ‘complexed psa’ OR ‘c-psa’ OR ‘complexed prostate specific antigen’ OR (nomogram* AND (prostatic OR ‘prostate’/exp))
  AND
  ‘meta analysis’/exp OR ‘systematic review’/exp OR ‘metaanalysis’ OR ‘randomized clinical trial’ OR ‘randomised clinical trial’ OR ‘comparative trial’ OR ‘controlled trial’/exp OR random OR ‘comparison’/exp
  AND
  ‘major clinical study’/de
  AND
  Limits: Humans, English =125

### Cochrane Central

Test names searched for anything that was not in the other two databases' results = 2 new records

Additional comparator searching in Cochrane = 160 new records

## Addendum

### Literature Search Update – 05/15/2012

A full update of the comprehensive search initially conducted on August 9, 2012 was not performed. Rather, the search was focused on PCA3, with the aim of identifying any subsequently published studies that could provide additional relevant data. Searches were conducted searches in PubMed®, EMBASE.COM, The Cochrane Library, and the Clinicaltrials.gov (NCT) database. The results included 40 unique citations for published articles not captured in the initial search, as well as 43 abstracts from scientific meetings (e.g., American Society for Clinical Oncology, Journal of Urology Annual Conference) and updated information on three relevant ongoing clinical trials.

### Search Strategies for Updating of Evidence

#### PUBMED on 5/15/2012

(“prostate cancer antigen 3, human” [Supplementary Concept] OR “PCA3” OR “DD3” OR “DD3PCA3” OR “DD3(PCA3)” OR “prostate cancer gene 3” OR “prostate cancer antigen 3” OR “progensa” OR “differential display code 3”) AND (“prostate” OR “prostatic”)

Limits: English, Dates 8/1/2011 to 5/15/2012

Results: 31 citations

#### EMBASE.COM on 5/15/2012

‘prostate cancer antigen 3, human’ OR pca3 OR dd3 OR dd3pca3 OR ‘dd3(pca3)’ OR ‘prostate cancer gene 3’ OR ‘prostate cancer antigen 3’ OR progensa OR ‘differential display code 3’ AND (‘prostate’/exp OR prostatic)

Limits: English, Dates 8/1/2011 to 5/15/2012

Results: 76 citations

#### Cochrane Central on 5/15/2012

prostate cancer antigen 3 OR pca3 OR dd3 OR dd3pca3 OR dd3(pca3) OR prostate cancer gene 3 OR prostate cancer antigen 3 OR progensa OR differential display code 3' AND (‘prostate’/exp OR prostatic)

Results: No new trials identified