# Abbreviations and Acronyms

ACMG: American College of Medical Genetics
ACS: American Cancer Society
AHRQ: Agency for Healthcare Research and Quality
AMP: Association for Molecular Pathology
AS: active surveillance
AUC: area under the receiver operating characteristics (ROC) curve
AUA: American Urological Association
ASAP: atypical small acinar proliferation
ASCO: American Society of Clinical Oncology
BPH: benign prostatic hyperplasia
CAP: College of American Pathologists
Cc: cubic centimeter (measure of volume)
CER: comparative effectiveness review
CI: confidence interval
CU: clinical utility
CV: clinical validity OR coefficient of variation
DA: diagnostic accuracy
DD3: differential display code 3
DOR: diagnostic odds ratio
DRE: digital rectal examination
ECE: extracapsular extension
EPICOT: evidence, population, intervention, comparison, outcome, timestamp
ERSPC: European Randomized Study of Screening for Prostate Cancer
EVN: externally validated nomogram
FDA: Food and Drug Administration
FPR: false positive rate
GRADE: grading of recommendations assessment, development and evaluation
GS: Gleason score
IQR: Inter-quartile range
LR: likelihood ratio
Mg: milligram
Ml: milliliter
mRNA: messenger RNA (ribonucleic acid)
Ng: nanogram
NICE: UK National Institute for Health and Clinical Excellence
NIH: National Institutes of Health
NCCN: National Cancer Consortium Network
NCI: National Cancer Institute
NPV: negative predictive value
NR: not reported
OAPR: odds of being affected given a positive result
OANR: odds of being affected given a negative result
OR: odds ratio
PCa: prostate cancer, prostatic cancer
PCA3: prostate cancer antigen 3
PCPT: Prostate Cancer Prevention Trial
PCRI: Prostate Cancer Research Institute
PICOTS: patient, intervention, comparator, outcome, timing, and setting
PIN: prostatic intraepithelial neoplasia
PPV: positive predictive value
PSA: prostate-specific antigen
cPSA: complexed prostate-specific antigen
%fPSA: free prostate-specific antigen
tPSA: total prostate-specific antigen
PSAD: prostate-specific antigen density
PSADT: prostate-specific antigen doubling time
PSAV: prostate-specific antigen velocity
RCT: randomized controlled trial
RP: radical prostatectomy
RT-PCR: real-time – polymerase chain reaction
SD: standard deviation
SER: systematic evidence review
TEP: technical expert panel
TMA: transcription-mediated amplification
TURP: transurethral resection of the prostate
TV: tumor volume
U.S.: United States