# References

1 HealthyPeople.gov. Normal Weight Status. www.healthypeople.gov/2020/topicsobjectives2020/objectiveslist.aspx?topicid=29.
2 Health Indicators Warehouse. Healthy Weight in Adults. www.healthindicators.gov/Indicators/Healthyweightinadults_1207/Profile/Data.
3 National Center for Health Statistics. Health, United States, 2010: With Special Feature on Death and Dying. Hyattsville, MD. 2011. Library of Congress Catalog Number 76641496. U.S. Government Printing Office. Washington, DC 20402.
4 Lovasi GS, Hutson MA, Guerra M, et al. Built environments and obesity in disadvantaged populations. Epidemiol Rev. 2009;31:7-20. [pmid: 19589839].
5 Williamson DF. Descriptive epidemiology of body weight and weight change in U.S. adults. Ann Intern Med. 1993;119(7 Pt 2):646-9. [pmid: 8363190].
6 Ogden CL, Carroll MD, Kit BK, et al. Prevalence of Obesity in the United States 2009-2010, NCHS Data Brief No. 82. U.S. Department of Health and Human Services. Janaury. 2012. www.cdc.gov/nchs/data/databriefs/db82.pdf.
7 Ogden CL, Carroll MD. Prevalence of Overweight, Obesity, and Extreme Obesity Among Adults United States, Trends 19761980 Through 20072008. CDC Health-E Stats.
8 Phelan ST. Obesity in minority women: calories, commerce, and culture. Obstet Gynecol Clin North Am. 2009;36(2):379-92. x. [pmid: 19501320].
9 Joshu CE, Mondul AM, Menke A, et al. Weight gain is associated with an increased risk of prostate cancer recurrence after prostatectomy in the PSA era. Cancer Prev Res (Phila). 2011;4(4):544-51. [pmid: 21325564].
10 Stroup SP, Cullen J, Auge BK, et al. Effect of obesity on prostate-specific antigen recurrence after radiation therapy for localized prostate cancer as measured by the 2006 Radiation Therapy Oncology Group-American Society for Therapeutic Radiation and Oncology (RTOG-ASTRO) Phoenix consensus definition. Cancer. 2007;110(5):1003-9. [pmid: 17614338].
11 Caan BJ, Emond JA, Natarajan L, et al. Post-diagnosis weight gain and breast cancer recurrence in women with early stage breast cancer. Breast Cancer Res Treat. 2006;99(1):47-57. [pmid: 16541317].
12 Rock CL, McEligot AJ, Flatt SW, et al. Eating pathology and obesity in women at risk for breast cancer recurrence. Int J Eat Disord. 2000;27(2):172-9. [pmid: 10657890].
13 McNee RK, Mason BH, Neave LM, et al. Influence of height, weight, and obesity on breast cancer incidence and recurrence in Auckland, New Zealand. Breast Cancer Res Treat. 1987;9(2):145-50. [pmid: 3620716].
14 Tartter PI, Slater G, Papatestas AE, et al. Cholesterol, weight, height, Quetelet's index, and colon cancer recurrence. J Surg Oncol. 1984;27(4):232-5. [pmid: 6503298].
15 Smith SC Jr. Multiple risk factors for cardiovascular disease and diabetes mellitus. Am J Med. 2007;120(3 Suppl 1):S3-S11. [pmid: 17320520].
16 Okoro CA, Hootman JM, Strine TW, et al. Disability, arthritis, and body weight among adults 45 years and older. Obes Res. 2004;12(5):854-61. [pmid: 15166307].
17 Gibson M, Carek PJ, Sullivan B. Treatment of co-morbid mental illness in primary care: how to minimize weight gain, diabetes, and metabolic syndrome. Int J Psychiatry Med. 2011;41(2):127-42. [pmid: 21675345].
18 Bennett WL, Wilson LM, Bolen S, et al. Oral diabeted medications for adults with type 2 diabetes: an update [internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2011. Mar. [pmid: 21735563].
19 Mitri J, Hamdy O. Diabetes medications and body weight. Expert Opin Drug Saf. 2009;8(5):573-84. [pmid: 19538102].
20 Sestak I, Harvie M, Howell A, et al. Weight change associated with anastrozole and tamoxifen treatment in postmenopausal women with or at high risk of developing breast cancer. Breast Cancer Res Treat. 2012;134(2):727-34. [pmid: 22588672].
21 Flegal KM, Graubard BI, Williamson DF, et al. Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA. 2007;298(17):2028-37. [pmid: 17986696].
22 Finkelstein EA, Trogdon JG, Cohen JW, et al. Annual medical spending attributable to obesity: payer-and service-specific estimates. Health Aff (Millwood). 2009;28(5):w822-31. [pmid: 19635784].
23 Gill JM, Cooper AR. Physical activity and prevention of type 2 diabetes mellitus. Sports Med. 2008;38(10):807-24. [pmid: 18803434].
24 Eiben G, Lissner L. Health Hunters—an intervention to prevent overweight and obesity in young high-risk women. Int J Obes (Lond). 2006;30(4):691-6. [pmid: 16276359].
25 Norris SL, Zhang X, Avenell A, et al. Long-term non-pharmacological weight loss interventions for adults with prediabetes. Cochrane Database Syst Rev. 2005;(2):CD005270. [pmid: 15846748].
26 Bray GA. Office Management of Obesity. Saunders. 2004. Philadelphia, PA. 336pp.
27 Lombard CB, Deeks AA, Teede HJ. A systematic review of interventions aimed at the prevention of weight gain in adults. Public Health Nutr. 2009;12(11):2236-46. [pmid: 19650959].
28 Hollis JF, Gullion CM, Stevens VJ, et al. Weight loss during the intensive intervention phase of the weight-loss maintenance trial. Am J Prev Med. 2008;35(2):118-26. [pmid: 18617080].
29 Sacks FM, Bray GA, Carey VJ, et al. Comparison of weight-loss diets with different compositions of fat, protein, and carbohydrates. The New England Journal of Medicine. 2009;360(9):859-73. [pmid: 19246357].
30 Shiroma EJ, Sesso HD, Lee IM. Physical activity and weight gain prevention in older men. Int J Obes (Lond). 2012. [pmid: 22234277].
31 Biddle SJH, Faulkner GE. Psychological and social benefits of physical activity. Chan KM, Chodzko-Zajko W, Frontera W, Parker A, editors. Active Aging. 2002:30-84. Hong Kong. Lippincott Williams & Wilkins.
32 Davidson MH, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235-42. [pmid: 9918478].
33 Bolen SD, Clark JM, Richards TM, et al. Trends in and patterns of obesity reduction medication use in an insured cohort. Obesity (Silver Spring). 2010;18(1):206-9. [pmid: 19498347].
34 Micromedex Consumer Medication Information. Orlistat (by mouth). Available at: http://www.ncbi.nlm.nih.gov/pubmedhealth/PMHT0011510/?report=details.
35 National Institute of Environmental Health Sciences, National Institutes of Health. Obesity and the built environment. www.niehs.nih.gov/news/events/pastmtg/2004/built/.
36 Lemmens VE, Oenema A, Klepp KI, et al. A systematic review of the evidence regarding efficacy of obesity prevention interventions among adults. Obes Rev. 2008;9(5):446-55. [pmid: 18298429].
37 Treuhaft CL, Karpyn A. The Grocery Gap: Who Has Access to Healthy Food and Why it Matters. www.policylink.org/site/c.lkIXLbMNJrE/b.5860321/k.A5BD/The_Grocery_Gap.htm.
38 Anderson LM, Quinn TA, Glanz K, et al. The effectiveness of worksite nutrition and physical activity interventions for controlling employee overweight and obesity: a systematic review. Am J Prev Med. 2009;37(4):340-57. [pmid: 19765507].
39 Loveman E, Frampton GK, Shepherd J, et al. The clinical effectiveness and cost-effectiveness of long-term weight management schemes for adults: a systematic review. Health Technol Assess. 2011;15(2):1-182. [pmid: 21247515].
40 American Dietetic Association. Adult weight management evidence based nutrition practice guideline. Chicago (IL). American Dietetic Association (ADA). 2006.
41 World Gastroenterology Organisation. Gastroenterology Organisation Global Guideline: Obesity. Munich (Germany). World Gastroenterology Organisation (WGO). 2009:29.
42 National Heart Lung, and Blood Institute. www.nhlbi.nih.gov/health/public/heart/obesity/lose_wt/patmats.htm.
43 Christie J, O'Halloran P, Caan W, et al. Workplace-based organisational interventions to prevent and control obesity by improving dietary intake and/or increasing physical activity. Cochrane Database of Systematic Reviews. 2010;(6). Art. No.: CD008546. [doi: 10.1002/14651858.CD008546].
44 Moher D, Altman DG, Liberati A, et al. PRISMA statement. Epidemiology. 2011;22(1):128. author reply 128. [pmid: 21150360].
45 Board on Health Care Services. Standards for Findings and Assessing Individual Studies. The National Academy Press. 2012. books.nap.edu/openbook.php?record_id=13059&page=81.
46 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
47 Katan MB, Ludwig DS. Extra calories cause weight gain—but how much?. JAMA. 2010;303(1):65-6. [pmid: 20051571].
48 Methods Guide for Effectiveness and Comparative Effectiveness Reviews [Internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2008. www.ncbi.nlm.nih.gov/books/NBK47095/.
49 Bhargava A, Guthrie JF. Unhealthy eating habits, physical exercise and macronutrient intakes are predictors of anthropometric indicators in the Women's Health Trial: Feasibility Study in Minority Populations. Br J Nutrition. 2002;88(6):719-28. [pmid: 12493094].
50 Fortmann SP, Williams PT, Hulley SB, et al. Effect of health education on dietary behavior: the Stanford Three Community Study. Am J Clin Nutr. 1981;34(10):2030-8. [pmid: 7293934].
51 Howard BV, Manson JE, Stefanick ML, et al. Low-fat dietary pattern and weight change over 7 years: the Women's Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39-49. [pmid: 16391215].
52 Design of the Women's Health Initiative clinical trial and observational study. The Women's Health Initiative Study Group. Control Clin Trials. 1998;19(1):61-109. [pmid: 9492970].
53 Schmitz KH, Hannan PJ, Stovitz SD, et al. Strength training and adiposity in premenopausal women: strong, healthy, and empowered study. Am J Clin Nutr. 2007;86(3):566-72. [pmid: 17823418].
54 Petrella RJ, Koval JJ, Cunningham DA, et al. Can primary care doctors prescribe exercise to improve fitness? The Step Test Exercise Prescription (STEP) project. Am J Prev Med. 2003;24(4):316-22. [pmid: 12726869].
55 Muscari A, Giannoni C, Pierpaoli L, et al. Chronic endurance exercise training prevents aging-related cognitive decline in healthy older adults: A randomized controlled trial. Int J Geriatr Psychiatry. 2010;25(10):1055-64. [pmid: 20033904].
56 Lamb SE, Bartlett HP, Ashley A, et al. Can lay-led walking programmes increase physical activity in middle aged adults? A randomised controlled trial. J Epidemiol Community Health. 2002;56(4):246-52. [pmid: 11896130].
57 French SA, Gerlach AF, Mitchell NR, Hannan PJ, Welsh EM. Household Obesity Prevention: Take Action-a Group-Randomized Trial. Obesity (Silver Spring). 2011. [pmid: 21212771].
58 Levine MD, Klem ML, Kalarchian MA, et al. Weight gain prevention among women. Obesity (Silver Spring). 2007;15(5):1267-77. [pmid: 17495203].
59 Burke V, Giangiulio N, Gillam HF, et al. Physical activity and nutrition programs for couples: a randomized controlled trial. J Clin Epidemiol. 2003;56(5):421-32. [pmid: 12812815].
60 Lombard C, Deeks A, Jolley D, et al. A low intensity, community based lifestyle programme to prevent weight gain in women with young children: cluster randomised controlled trial. Br Med J. 2010;341:c3215. [pmid: 20627974].
61 Mozaffarian D, Hao T, Rimm EB, et al. Changes in diet and lifestyle and long-term weight gain in women and men. N Engl J Med. 2011;364(25):2392-404. dx.doi.org/10.1056/NEJMoa1014296. [pmid: 21696306].
62 Berry TR, Spence JC, Blanchard C, et al. Changes in BMI over 6 years: the role of demographic and neighborhood characteristics. Int J Obes (Lond). 2010;34(8):1275-83. [pmid: 20157324].
63 Adair LS, Gultiano S, Suchindran C. 20-year trends in Filipino women's weight reflect substantial secular and age effects. J Nutr. 2011;141(4):667-73. [pmid: 21325475].
64 Lewis C, Smith D, Wallace D, et al. Seven-year trends in body weight and associations with lifestyle and behavioral characteristics in Black and White young adults: the CARDIA Study. Am J Pub Health. 4. 1997;87:635-42. www.ncbi.nlm.nih.gov/pmc/articles/PMC1380845/.
65 Pereira MA, Kartashav AI, Ebbeling CB, et al. Fast-food habits, weight gain, and insulin resistance (the CARDIA study): 15-year prospective analysis. The Lancet. 2005;365(9453):36-42. [pmid: 15639678].
66 Ballor DL, Harvey-Berino JR, Ades PA, et al. Contrasting effects of resistance and aerobic training on body composition and metabolism after diet-induced weight loss. Metabolism. 1996;45(2):179-83. [pmid: 8596486].
67 Bes-Rastrollo M, Basterra-Gortari F, Sánchez-Villegas A, et al. A prospective study of eating away-from-home meals and weight gain in a Mediterranean population: the SUN (Seguimiento Universidad de Navarra) cohort. Public Health Nutrition. 2010;13(9):1356-63. [pmid: 19954575].
68 Schulz M, Nothlings U, Hoffmann K, et al. Identification of a food pattern characterized by high-fiber and low-fat food choices associated with low prospective weight change in the EPIC-Potsdam cohort. J Nutr. 2005;135(5):1183-9. [pmid: 15867301].
69 Purslow LR, Sandhu MS, Forouhi N, et al. Energy intake at breakfast and weight change: prospective study of 6,764 middle-aged men and women. Am J Epidemiol. 2008;167(2):188-92. [pmid: 18079134].
70 Lee I, Djoussé L, Sesso H, et al. Physical activity and weight gain prevention. JAMA. 2010;303(12):1173-9. [pmid: 20332403].
71 Makrides L, Sawatzky C, Petrie J, et al. Modifiable health risks in Atlantic Canadian employees: A 5-year report. Health Promotion International. 2010;25(4):384-93. [pmid: 20605847].
72 Hemmingsson E, Uddén J, Neovius M, et al. Increased physical activity in abdominally obese women through support for changed commuting habits: a randomized clinical trial. International Journal of Obesity (2005). 2009;33(6):645-52. [pmid: 19417772].
73 Robbins AS, Chao SY, Baumgartner N, Runyan CN, Oordt MS, Fonseca VP. A low-intensity intervention to prevent annual weight gain in active duty Air Force members. Mil Med. 2006;171(6):556-61. [pmid: 16808141].
74 Kwak L, Kremers SP, Candel MJ, Visscher TL, Brug J, van Baak MA. Changes in skinfold thickness and waist circumference after 12 and 24 months resulting from the NHF-NRG In Balance-project. Int J Behav Nutr Phys Act. 2010;7:26. [pmid: 20370934].
75 Goetzel RZ, Roemer EC, Pei X, et al. Second-year results of an obesity prevention program at the Dow Chemical Company. Journal of Occupational and Environmental Medicine / American College of Occupational and Environmental Medicine. 2010;52(3):291-302. [pmid: 20190646].
76 Lemon SC, Zapka J, Li W, et al. Step ahead: A worksite obesity prevention trial among hospital employees. American Journal of Preventive Medicine. 2010;38(1):27-38. [pmid: 20117554].
77 Linde JA, Nygaard KE, MacLehose RF, et al. HealthWorks: results of a multi-component group-randomized worksite environmental intervention trial for weight gain prevention. Int J Behav Nutr Phys Act. 2012;9:14. [pmid: 22340088].
78 McEachan RR, Lawton RJ, Jackson C, Conner M, Meads DM, West RM. Testing a workplace physical activity intervention: a cluster randomized controlled trial. The International Journal of Behavioral Nutrition and Physical Activity. 2011;8:29. [pmid: 21481265].
79 Dekkers JC, van Wier MF, Ariëns GA, et al. Comparative effectiveness of lifestyle interventions on cardiovascular risk factors among a Dutch overweight working population: a randomized controlled trial. BMC Public Health. 2011;11(1):49. [pmid: 21261935].
80 Goetzel RZ, Baker KM, Short ME, et al. First-year results of an obesity prevention program at the Dow Chemical Company. Journal of Occupational and Environmental Medicine. 2009;51(2):125-38. [pmid: 19209033].
81 Holtrop J, Hickner J, Dosh S, Noel M, Ettenhofer T, et al. “Sticking to it—diabetes mellitus”: a pilot study of an innovative behavior change program for women with type 2 diabetes. American Journal of Health Education. 2002;33(3):161-6. www.epistemonikos.org/ar/documents/1a867607a3012d8768aa12ce334ab17bb182f454?doc_lang=en.
82 Chapman MJ, Craven MJ, Chadwick DD. Following up Fighting Fit: The long-term impact of health practitioner input on obesity and BMI amongst adults with intellectual disabilities. Journal of Intellectual Disabilities. 2008;12(4):309-23. [pmid: 19074936].
83 Hivert MF, Langlois MF, Bérard P, Cuerrier JP, Carpentier AC. Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes (Lond). 2007;31(8):1262-9. [pmid: 17356531].
84 Matvienko O, Lewis DS, Schafer E. A college nutrition science course as an intervention to prevent weight gain in female college freshmen. J Nutr Educ. 2001;33(2):95-101. [pmid: 12031189].
85 Anderssen SA, Haaland A, Hjermann I, et al. Oslo Diet and Exercise Study: a one year randomized intervention trial; effect on hemostatic variables and other risk factors. Nutr Metab Cardiovasc Dis. 1995;5:189-200.
86 Torjesen PA, Birkeland KI, Anderssen SA, Hjermann I, Holme I, Urdal P. Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. 1997;20(1):26-31. [pmid: 9028689].
87 Babazono A, Kame C, Ishihara R, Yamamoto E, Hillman AL. Patient-Motivated Prevention of Lifestyle-Related Disease in Japan: A Randomized, Controlled Clinical Trial. 2007;15(2). adisonline.com/diseasemanagement/Fulltext/2007/15020/Patient_Motivated_Prevention_of_Lifestyle_Related.7.aspx.
88 Clark M, Hampson SE, Avery L, Simpson R. Effects of a tailored lifestyle self-management intervention in patients with Type 2 diabetes. Br. J. Health Psychol. 2004;9(3):365-79. [pmid: 15296683].
89 Gram B, Christensen R, Christiansen C, Gram J. Effects of nordic walking and exercise in type 2 diabetes mellitus: A randomized controlled trial. Clin. J. Sport Med. 2010;20(5):355-61. [pmid: 20818193].
90 Kumanyika SK, Cook NR, Cutler JA, et al. Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. Journal of Human Hypertension. 2005;19(1):33-45. [pmid: 15372064].
91 Razquin C, Martinez JA, Martinez-Gonzalez MA, et al. A 3 years follow-up of a Mediterranean diet rich in virgin olive oil is associated with high plasma antioxidant capacity and reduced body weight gain. European Journal of Clinical Nutrition. 2009;63(12):1387-93. [pmid: 19707219].
92 Razquin C, Martinez JA, Martinez-Gonzalez MA, et al. A mediterranean diet rich in virgin olive oil may reverse the effects of the-174g/c il6 gene variant on 3-year body weight change. Mol. Nutr. Food Res. 2010;S54(SUPPL. 1):S75-S82. [pmid: 20352618].
93 Samaras K, Ashwell S, Mackintosh AM, Fleury AC, Campbell LV, Chisholm DJ. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37(2):121-8. [pmid: 9279482].
94 Zazpe I, Sanchez-Tainta A, Estruch R, et al. A large randomized individual and group intervention conducted by registered dietitians increased adherence to Mediterranean-type diets: the PREDIMED study. J Am Diet Assoc. 2008;108(7):1134-1144. discussion 1145. [pmid: 18589019].
95 Stefanick ML, Mackey S, Sheehan M, Ellsworth N, Haskell WL, Wood PD. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12-20. [pmid: 9647874].
96 Yates T, Davies MJ, Gorely T, et al. The effect of increased ambulatory activity on markers of chronic low-grade inflammation: evidence from the PREPARE programme randomized controlled trial. Diabetic Medicine : a Journal of the British Diabetic Association. 2010;27(11):1256-63. [pmid: 20950383].
97 Plotnikoff RC, Pickering MA, Glenn N, et al. The effects of a supplemental, theory-based physical activity counseling intervention for adults with type 2 diabetes. J Phys Act Health. 2011;8(7):944-54. [pmid: 21885885].
98 Toobert DJ, Strycker LA, King DK, et al. Long-term outcomes from a multiple-risk-factor diabetes trial for Latinas: ¡Viva Bien! Transl Behav Med 2011. 1(3):416-26. [pmid: 22022345].
99 Abraira C, de Bartolo M, Myscofski JW. Comparison of unmeasured versus exchange diabetic diets in lean adults. Body weight and feeding patterns in a 2-year prospective pilot study. Am J Clin Nutr. 1980;33(5):1064-70. [pmid: 6989227].
100 Schwartz AL, Winters-Stone K. Effects of a 12-month randomized controlled trial of aerobic or resistance exercise during and following cancer treatment in women. Phys Sportsmed. 2009;37(3):62-7. [pmid: 20048529].
101 Chlebowski RT, Blackburn GL, Thomson CA, et al. Dietary fat reduction and breast cancer outcome: Interim efficacy results from the women's intervention nutrition study. J. Natl. Cancer Inst. 2006;98(24):1767-76. [pmid: 17179478].
102 Chen G, Heilbrun LK, Venkatramanamoorthy R, et al. Effects of low-fat and/or high-fruit-and-vegetable diets on plasma levels of 8-isoprostane-F2alpha in the Nutrition and Breast Health study. Nutrition and Cancer. 2004;50(2):155-60. [pmid: 15623461].
103 Djuric Z, Poore KM, Depper JB, et al. Methods to increase fruit and vegetable intake with and without a decrease in fat intake: Compliance and effects on body weight in the nutrition and breast health study. Nutr. Cancer. 2002;43(2):141-51. [pmid: 12588694].
104 Wijndaele K, Lynch BM, Owen N, Dunstan DW, Sharp S, Aitken JF. Television viewing time and weight gain in colorectal cancer survivors: a prospective population-based study. Cancer Causes Control. 2009;20(8):1355-62. [pmid: 19449106].
105 McCreadie RG, Kelly C, Connolly M, et al. Dietary improvement in people with schizophrenia: Randomised controlled trial. Br J Psychiatry. 2005;187(4):346-51. bjp.rcpsych.org/content/187/4/346. [pmid: 16199794].
106 Alvarez-Jimenez M, Martinez-Garcia O, Perez-Iglesias R, Ramirez ML, Vazquez-Barquero JL, Crespo-Facorro B. Prevention of antipsychotic-induced weight gain with early behavioural intervention in first-episode psychosis: 2-year results of a randomized controlled trial. Schizophr. Res. 2010;116(1):16-9. [pmid: 19896336].
107 Jeffery RW, French SA. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21(6):457-64. [pmid: 9192229].
108 Khan LK, Sobush K, Keener D, et al. Recommended community strategies and measurements to prevent obesity in the United States. MMWR Recomm Rep. 2009;58(RR-7):1-26. [pmid: 19629029].
109 Yanovski SZ, Yanovski JA. Obesity prevalence in the United States--up, down, or sideways?. N Engl J Med. 2011;364(11):987-9. [pmid: 21410367].
110 Kassirer JP, Angell M. Losing weight--an ill-fated New Year's resolution. N Engl J Med. 1998;338(1):52-4. [pmid: 9414332].
111 WHO European Ministerial Conference on Counteracting Obesity: Diet and Physical Activity for Health. Istanbul Turkey. www.euro.who.int/__data/assets/pdf_file/0009/87462/E89567.pdf.
112 Nutrition and Weight Status. HealthyPeople.gov. April. www.healthypeople.gov/2020/topicsobjectives2020/objectiveslist.aspx?topicId=. 2012:29.
113 National Institutes of Health. Clinical Guidelines on the Identification, Evaluation, and Treatment of Ovwerweight and Obesity in Adults. NIH Publication No. 98-4083. 1998.
114 Gostin LO. Law as a tool to facilitate healthier lifestyles and prevent obesity. JAMA. 2007;297(1):87-90. [pmid: 17200479].
115 Hawkes N. Medical colleges and faculties unite to tackle obesity after "failure" of current strategies. Br Med J. 2012:344-e2775. [pmid: 22511215].
116 Lyznicki JM, Young DC, Riggs JA, et al. Obesity: assessment and management in primary care. Am Fam Physician. 2001;63(11):2185-96. [pmid: 11417771].
117 Centers for Medicare and Medicaid Services. CMS Manual System. Pub 100-04 Medicare claims Processing. March. 7. 2012. www.cms.gov/Regulations-and-Guidance/Guidance/Transmittals/Downloads/R2421CP-.pdf.
118 Hall KD, Sacks G, Chandramohan D, et al. Quantification of the effect of energy imbalance on bodyweight. Lancet. 2011;378(9793):826-37. www.thelancet.com/journals/lancet/article/PIIS0140-6736%2811%2960812-X/abstract. [pmid: 21872751].
119 Lindvall K, Larsson C, Weinehall L, et al. Weight maintenance as a tight rope walk—a Grounded Theory study. BMC Public Health. 2010;10:51. [pmid: 20122140].
120 Fogelholm M, Kukkonen-Harjula K. Does physical activity prevent weight gain—a systematic review. Obes Rev. 2000;1(2):95-111. [pmid: 12119991].
121 Ledoux TA, Hingle MD, Baranowski T. Relationship of fruit and vegetable intake with adiposity: a systematic review. Obes Rev. 2011;12(5):e143-50. [pmid: 20633234].
122 Hardeman W, Griffin S, Johnston M, et al. Interventions to prevent weight gain: a systematic review of psychological models and behaviour change methods. Int J Obes Relat Metab Disord. 2000;24(2):131-43. [pmid: 10702762].
123 IOM (Institue of medicine). 2011. Leveraging Food Technology for Obesity Prevention and Reduction Efforts: Workshop Summary. Washington, DC. The National Academies Press. books.nap.edu/openbook.php?record_id=13153&page=R2.
124 Bacon L, Aphramor L. Weight science: evaluating the evidence for a paradigm shift. Nutr J. 2011;10:9. [pmid: 21261939].
125 Haines J, Neumark-Sztainer D. Prevention of obesity and eating disorders: a consideration of shared risk factors. Health Education Research. 2006;21(6):770-82. her.oxfordjournals.org/content/21/6/770.abstract. [pmid: 16963727].