# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov/methods guide.cfm). The main sections of this chapter reflect the elements of the protocol established for the CER. Certain methods map to the PRISMA checklist.44

Our Evidence based Practice Center (EPC) established a team and a work plan to develop this evidence report. The project involved recruiting key informants and technical experts, formulating and refining the questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review and public comment.

## Topic Refinement and Review Protocol

The topic for this report was nominated in a public process. A physician and nurse suggested the topic based on the lack of evidence that they could identify in the literature to inform their practice.

At the beginning of the project, we recruited a panel of key informants to give input on key steps including the selection and refinement of the questions to be examined. The panel included experts in adult obesity, weight maintenance, prevention of weight gain, environmental interventions and individuals with perspectives from payors and companies that sell weight related products.

In preparation for this report, we reviewed existing systematic reviews on this topic as well as guidelines prepared by key professional societies. With input from the key informants, staff of AHRQ, and the Scientific Resource Center, we developed the key questions. Our draft key questions were posted on AHRQ)s Web site for public comment in November 2011. We then refined the key questions based on the feedback received.

The final key questions focus on the comparisons of interventions and approaches that prevent weight gain among adults. The key questions focus on the effectiveness of these interventions and approaches as well as harms. We drafted a protocol to address these key questions and then recruited a panel of technical experts, including experts on weight maintenance and weight gain prevention. With input from the technical expert panel and representatives from AHRQ, we finalized the protocol.

Amendments to the protocol were submitted to AHRQ and posted publicly on the Effective Healthcare website in November 2011 and March 2012. These amendments were added to focus the project's scope to weight and clinical outcomes, and to include high quality observational studies in addition to trials.

## Search Strategy

We searched the following databases for primary studies: MEDLINE^®^, Embase^®^, and the Cochrane Central Register of Controlled Trials through June 2012. We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on an analysis of the medical subject headings (MeSH), terms, and text words of key articles identified (Appendix B). We also reviewed the reference lists of each included article, relevant review articles and studies identified in clinicaltrials.gov.

The results of the searches were downloaded and imported into ProCite^®^version 5 (ISI Research Soft, Carlsbad, CA). We scanned for exact article duplicates; author/title duplicates, and title duplicates using the duplication check feature in ProCite. From ProCite, the articles were uploaded to DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web based software package developed for systematic review and data management. This database was used to track the search results at the levels of title review, abstract review, article inclusion/exclusion, and data abstraction.

## Gray Literature

We performed a gray literature search to identify complete and ongoing trials and studies related to our topic. We searched ClinicalTrials.gov on June 19, 2012 using the search string “adult AND weight AND (maintain OR maintenance OR “prevent weight gain”).” Two reviewers then examined the titles of each trial to determine if it was related to the topic. For studies that were considered related to the topic, we then went to the webpage in ClinicalTrials.gov and identified if the trial met our inclusion criteria. If the trial met the inclusion criteria, we collected information on the status of the trial (ongoing, terminated, completed, not yet recruiting), start and stop dates, whether there were publications related to the trial and if results were available in tables within ClinicalTrials.gov. We retrieved publications related to the study to determine if they had been previously identified in our search.

## Study Selection

We first screened titles for eligibility. All titles were screened by two screeners. This phase of screening was designed to be liberal. Only one screener needed to identify a title as potentially eligible for the associated publication to move to the next screening level (Appendix C). However, two screeners were required to agree that a title was not eligible for the publication to be removed from the potential pool of articles.

The abstract review phase was designed to identify trials or observational studies that addressed weight maintenance or prevention of weight gain among adults (Appendix C), and potentially applied to the inclusion criteria (Table 2). Abstracts were reviewed independently by two investigators and were excluded if both investigators agreed that the article met one or more of the exclusion criteria (see Table 1). Differences between investigators regarding abstract inclusion or exclusion were resolved through consensus adjudication.

Table 2 Study inclusion and exclusion criteria

Population and condition of interest | Adult participants for KQ1-5. If a study includes some participants under age 18 years and results are not reported separately for adults, the study will be included as long as 90percent of the total population is 18 years and older. Studies of obese patients were included if the study did not describe the goal of the intervention to be weight loss or maintenance of weight after weight loss. All ages are included for KQ6; strategies are implemented at the community level. Excluded studies if they included only pregnant women. Excluded studies that included only patients at risk of weight loss (e.g., wasting disease, eating disorders), or with a BMI <18.5
Interventions and approaches | Studies must have evaluated a strategy of interest as defined by the Key Questions. Included studies of orlistat. Included studies of caloric substitutes, such as olestra or artificial sweeteners. Included studies of lifestyle interventions for KQ5. Included studies implemented at a community level for KQ6. Excluded studies if the goal of the study was weight loss, a combination of weight loss and weight gain prevention (without a separate reporting of results), or weight maintenance after weight loss. Excluded studies of biological determinants (such as genes) as the exposure. Excluded studies of herbal supplements, vitamins, and minerals. Excluded studies that included a smoking cessation intervention or approach.
Comparisons of interest | No intervention, usual care, or comparison with other self management, dietary, physical activity, device, pharmaceutical or combination of strategies will be included. Included studies comparing different intensities of the same strategy (e.g., low fat versus high fat diet) Excluded studies if a study compares a strategy of interest with a strategy not of interest. Excluded studies if there was no comparison.
Outcomes and Timing | One year of observation of weight during adulthood was required. Weight change must have been reported relative to a strategy of interest. Measures of weight change included weight, BMI or waist circumference. Obesity related adverse effects, quality of life, cancer recurrence^*^, mortality and study adherence were abstracted only if the study also reported a qualifying measure of weight.
Type of study | Accepted studies with any sample size from any year that met all other criteria. Included all studies designs including prospective (randomized and nonrandomized), retrospective, crossover, and case control studies. Serial cross sectional studies of the same population were also eligible for KQ6. Observational studies had to account for confounding and losses to followup in the design or analysis to be eligible. Crossover studies must have reported at least 1 year of weight change in each phase of the crossover to be included. For KQ1-5 inclusion, the participants measured at the first time point must have been the same participants measured at the later time points. For KQ6 inclusion, the participants measured at the first time point were not required to be the same participants as those measured at the later time points. Excluded studies with no original data (reviews, editorials, comments, letters, modeling only studies). Excluded studies published only as abstracts. Excluded qualitative studies that did not provide quantitative information on a strategy of interest and weight, such as focus groups or directed interviews.

KQ = Key Question; RCT = randomized controlled trial

* In populations with cancer only.

Abstracts that were promoted to the next level, article screening, underwent another independent parallel review to determine if they should be included for data abstraction (Appendix C) (Table 2). Differences regarding article inclusion were resolved through consensus adjudication. We included only articles published in English due to volume of literature and lack of resources to translate all the languages encountered.

### Inclusion of Observational Studies

Observational studies that have a high risk of bias add little value to a systematic review of effectiveness.45 Therefore, only high quality observational studies were included. We used the Downs and Black tool to assess study quality with particular attention to control of confounding and losses to followup.46 For inclusion, we required that studies adjusted for the following confounders in their analysis: age, sex, race or socioeconomic status, and diet (for physical activity studies) or physical activity (for dietary studies). Included observational studies were required to account for losses to follow up in the analysis, state that the losses to followup were less than 20 percent, or state that the individuals included in the analysis were similar to those lost to followup or the original cohort. If the study met both the confounding and losses to follow up criteria and most or all of the other Downs and Black internal validity criteria, the observational study was considered eligible for the review.

To distinguish between strategies examined in observational studies from those in trials, we refer to strategies examined in observational studies as approaches. Strategies examined trials are referred to as interventions.

## Data Abstraction

Relevant data were abstracted from eligible articles with a focus on items related to the population, interventions and approaches, comparisons, outcomes, timing and setting. Each article was serially abstracted first by a junior reviewer then by a senior reviewer. Serial data abstraction involved a senior reviewer (faculty level project investigator) confirming the data abstracted by the first reviewer. Data were abstracted from the text, tables, figures, and supplemental materials. Differences in opinion were resolved through consensus adjudication and, in difficult cases, during team meetings.

The timepoints of interest for data abstraction of weight outcomes were 1 year, 2 years, 5 years and the last reported timepoint after 5 years. For the intermediate outcomes, safety and quality of life outcomes, we only abstracted data for the last reported timepoint after 1 year.

For each Key Question, we created a set of detailed evidence tables containing all information abstracted from eligible studies (Appendix C. Data Abstraction Forms). The text, tables, and figures in this report were based on the information in the evidence tables.

We reported on the effectiveness of interventions on populations with different risks of weight gain. These subgroups included baseline weight (healthy weight/overweight); age; life events (college, menopause, retirement); race, ethnicity or cultural group; gender; income, socioeconomic status or educational attainment; family history of obesity; persons with mental illness; cancer patients or survivors not at risk of weight loss; and persons with diabetes or cardiovascular disease or those at high risk of these conditions.

### Data Synthesis

When there were three or more studies with comparable interventions and comparable outcome measures, we considered quantitative pooling of the results. We examined the studies' designs for qualitative similarities. Because we found that no groups of studies were amenable to pooling with meta analyses, we calculated and displayed the mean differences, risk differences or relative risks with 95% confidence intervals (CI) for the individual studies grouped by study population and comparable interventions. Observational studies did not report categories of approaches consistently, prohibiting the use of summary figures.

We selected a meaningful between group difference threshold in addition to a statistically significant threshold (p<0.05) for reporting on the outcomes. A meaningful difference threshold was defined as 0.5 kg of weight,5,47 0.2 units of BMI (based on a 0.5 kg change for an individual with a BMI of 27), or 1 cm of waist circumference relative to the comparison group. The weight threshold was based on average annual weight gain in previous studies. The BMI threshold wasated to correspond to a weight gain for the average baseline weight of individuals in many of the studies. For waist circumference, a threshold of 1 cm was chosen because measurement error seemed likely below this threshold. The meaningful threshold was annualized to account for the different durations of the studies. For example, the weight difference threshold was 1 kg for outcomes reported at 2 years and 2.5 kg at 5 years.

## Quality Assessment

The risk of bias was assessed using the Downs and Black methodologic quality assessment checklist.46 This checklist was developed to assess the quality of reporting, internal validity and external validity for individual randomized and observational studies. Two reviewers independently assessed the risk of bias of each article and came to consensus regarding the bias rating for each item on the checklist.

## Data Entry and Quality Control

Each data element was reviewed by at least two reviewers. The second reviewers were generally more experienced members of the research team. In addition, at least one additional investigator audited a random sample of the reviews to identify any problems with data abstraction. If problems were recognized in a reviewer's data abstraction, the problems were discussed at a meeting with the reviewers. Throughout the review process we held weekly meetings to describe each phase of the review process, discuss identified discrepancies, and discuss any questions that arose about our process or specific content from the review. The goal of this part of the weekly meetings was to ensure consistency of article inclusion and data abstraction.

## Rating the Body of Evidence

At the completion of our review, we graded the quantity, quality and consistency of the evidence addressing the Key Questions by adapting an evidence grading scheme recommended by the Methods Guide for Conducting Comparative Effectiveness Reviews.48 We created evidence grades for each comparison and outcome. We used four domains to come up with a final evidence grade: Risk of Bias, Consistency, Directness and Precision.

Risk of bias in each individual study was assessed using the Downs and Black criteria focusing on reporting bias and internal validity.46 Randomized controlled trials were initially assigned to a low risk of bias category which could be altered to moderate risk for not blinding the outcome assessor to the intervention assignment, or not reporting on blinding of the outcome assessor. If the entire set of randomized controlled trials for a given intervention and outcome were blinded, the set could be changed from low risk of bias to moderate risk of bias if there were internal validity concerns or poor reporting. If a set of trials was mostly not blinded, the risk of bias was changed to moderate. This set of trials could then be assigned to a high risk of bias category if there were internal validity concerns or poor reporting. Observational studies were initially assigned a moderate risk of bias and could be changed to a high risk of bias if there were internal validity concerns or poor reporting. Because we had strict criteria and included only observational studies that minimized confounding and selection bias, the majority of studies were expected to have moderate risk of bias. When both trials and observational studies contributed to evidence, we weighted our assessment of the risk of bias towards the highest quality studies and sample size. Our strength of evidence tables include comments on the trials and observational studies to inform the final assessment (Appendix F).

Consistency was assessed based on the direction of the effect estimates. If all studies found no difference between the comparison groups, the body of evidence was graded as consistent. If the direction of effect was similar across studies, this was considered to be consistent evidence. If only one study was identified for a body of evidence, consistency was not graded.

Directness was assessed based on the design of the trial or original cohort study and generalizability to other populations. If most of the studies for a given comparison and outcome pair were not designed to measure weight maintenance, the evidence was considered indirect. If the studies were designed to measure weight maintenance, but the external validity criteria of Downs and Black were not met or poorly reported, the evidence was considered to be indirect.46

Precision could only be measured if the variability for the measure of association was reported. If there was no variability reported for most articles in the set, we graded the evidence imprecise. Otherwise, precision was determined by statistical significance (p<0.05 or confidence intervals [CI] excluding 0 for mean differences). For adherence outcomes, statistical comparisons of groups were infrequent, because adherence to a wait-list or information only control group is not possible. When grading precision for the outcome of adherence, if the total number of participant in all studies for a given comparison and outcome was fewer than 400, the set was considered to be imprecise. We chose 400 participants as the threshold with the idea that the evidence should contain at least 200 patients receiving an intervention, such as 2 trials of 100 participants receiving the intervention and 100 individuals receiving no intervention or an information packet.

We classified evidence pertaining to Key Questions 1 through 6 into four categories: (1) “high” grade (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of the effect); (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of the effect and may change the estimate); (3) “low” grade (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and (4) “insufficient” grade (no evidence identified). A comparison-outcome pair with high strength of evidence was one with low risk of bias, consistency (or not applicable if only one study contributed), directness and precision. Moderate strength of evidence indicated that one of the following was observed: a moderate risk of bias, inconsistency, indirectness or imprecision. Low strength of evidence indicated a high risk of bias or two or more of the following: a moderate risk of bias, inconsistency, indirectness and imprecision. Strength of evidence was graded by the senior reviewers and conflicts were resolved by discussion and consensus.

### Definition of Effectiveness

For an intervention or approach to be considered effective, it had to meet the meaningful between group difference and statistical thresholds. We selected a meaningful between group difference threshold in addition to a statistically significant threshold (p<0.05) for reporting on the outcomes. A meaningful difference threshold was defined as 0.5 kg of weight,5,47 0.2 units of BMI (based on a 0.5 kg change for an individual with a BMI of 27), or 1 cm of waist circumference relative to the comparison group. The meaningful threshold was annualized to account for the different durations of the studies. For example, the weight difference threshold was 1 kg for outcomes reported at 2 years and 2.5 kg at 5 years.

## Applicability

We describe the applicability of studies in terms of the degree to which the study population, interventions or approaches, outcomes, and settings were relevant to individuals at risk of weight gain and features that may affect the effectiveness of the strategy. The population that received the intervention or used the approach was the greatest driver of applicability. To clarify the population to whom the strategy was applicable, we describe strategies by select populations and settings in separate sections of the report.

## Peer Review and Public Commentary

Experts in behavior, policy, medications, nutrition, physical activity and individuals representing stakeholder and user communities were invited to provide external peer review of this CER. AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available three months after the agency posts the final CER on the AHRQ Web site.