# Peer Reviewers

- Alice Ammerman, Dr.P.H., M.P.H.
  University of North Carolina
  UNC Gillings School of Public Health
  Chapel Hill, NC
- Danielle Braxton, M.P.H., R.D., L.D.N.
  University of North Carolina
  Center for Health Promotion and Disease Prevention
  Chapel Hill, NC
- Tricia Leahey, Ph.D.
  Brown University
  Department of Psychiatry and Human Behavior
  Providence, RI
- Vasanti Malik, M.Sc.
  Harvard School of Public Health
  Depatment of Nutrition
  Boston, MA
- Dariush Mozaffarian, Dr.P.H., M.D., M.P.H.
  Harvard School of Public Health
  Depatment of Epidemiology
  Boston, MA
- Rena Wing, Ph.D.
  Brown University
  Division of Biology and Medicine
  Providence, RI