# Technical Expert Panel

- Gail L. Daumit, M.D., M.H.S.
  Welch Center for Prevention, Epidemiology and Clinical Research
  The Johns Hopkins Medical Institutions
  Baltimore, MD
- Tiffany L. Gary-Webb, Ph.D., M.H.S.
  Columbia Mailman School of Public Health
  New York, NY
- James O. Hill, Ph.D.
  Professor of Pediatrics and Medicine
  Director, Center for Human Nutrition
  University of Colorado School of Medicine
  Denver, CO
- Robert F. Kushner, M.D., M.S.
  Northwestern University FSM
  Chicago, IL
- Jessica G. LaRose, Ph.D.
  The Miriam Hospital
  Weight Control and Diabetes Research Center
  Providence, RI
- Katherine D. McManus, R.D., M.S.
  Brigham and Women's Hospital
  Department of Nutrition
  Boston, MA
- Antonio C. Wolff, M.D.
  Breast Cancer Program
  Department of Oncology
  The Johns Hopkins Kimmel Comprehensive Cancer Center
  Baltimore, MD