# Key Informants

- Caroline Apovian, M.D., FACP, FACN
  Boston Medical Center
  Nutrition and Weight Management Center
  Boston, MA
- James O. Hill, Ph.D.
  Professor of Pediatrics and Medicine
  Director, Center for Human Nutrition
  University of Colorado School of Medicine
  Denver, CO
- Katherine D. McManus, R.D., M.S.
  Brigham and Women's Hospital
  Department of Boston, MA
- Jeri L. Miller, M.S., M.Sc., Ph.D.
  National Institutes of Health, NINR
  Bethesda, MD
- Karen Miller-Kovach, M.B.A., M.S., R.D.
  Weight Watchers International
  New York, NY
- Soyal R. Momin, M.B.A.
  BlueCross BlueShield of Tennessee
  Chattanooga, TN