# Acknowledgments

The authors gratefully acknowledge the following individual for contributions to this project: Christine Chang, Eric Vohr and Ethan Balk.