# Discussion

## Key Findings and Implications

The evidence supports that prevention of weight gain among adults is challenging. Very few interventions or approaches led to meaningful between group changes in BMI, weight or waist circumference. When adherence was reported, it tended to be poor (less than 80 percent adherence). Poor adherence may have been one reason for the lack of effectiveness observed across interventions and populations. The strategies that prevented weight gain, or when no strategy was effective in a population the strategies that were examined, are described by population below.107 The strength of evidence for all observed comparisons is provided in Table 18. No comparison was graded as having a high strength of evidence. Two comparisons were graded as having a moderate strength of evidence. All others have low or insufficient evidence. The strength of evidence is low for many comparisons because the studies were not designed to measure weight maintenance and the study staff that measured weight in the intervention studies may have been aware of the participants' exposure groups.

Table 18 Summary of the strength of evidence^*^

Intervention | BMI^†^ | Weight Change^†^ | Waist Circumference^†^ | Progression to Overweight or Obese | Adherence | Quality of Life | Mortality | Adverse Events
General Population
Self-management | Insufficient | Low No strategy favored | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Low No diet favored | Low A healthy eating pattern was associated with less weight gain than an unhealthy eating pattern. Eating outside the home was associated with greater weight gain than consuming almost all meals at home. | Low Healthy eating scores 2 z-scores above the mean associated with 2 to 3cm smaller waistlines in Whites and Hispanics. | Low Eating food outside the home one or more times per week associated with a 20-30% increased risk of overweight or obesity compared with eating no meals outside the home. Healthy eating scores associated with a decreased odds of obesity. | Insufficient | Insufficient | Low Low-fat group had 0.1% less mortality than nutrition guidelines group. | Insufficient
Physical activity | Low Participants who were taught to monitor their heart rate by their primary care provider during exercise along with advice had a greater decrease in BMI than participants given advice by their doctor without being taught to monitor their heart rate. | Low Increasing physical activity over time is associated with less weight gain than maintaining or decreasing physical activity over time. | Low No strategy favored | Insufficient | Low Adherence with the interventions ranged from 33% to 71%. | Insufficient | Insufficient | Low No serious adverse events occurred.
Combination | Low No strategy favored | Low No strategy favored | Low No strategy favored | Low No strategy favored | Low Adherence ranged from 50% to 73%. | Insufficient | Insufficient | Insufficient
Built environment or community-level | Low No strategy favored | Low No strategy favored | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Obese Only
Self management | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Physical activity | Insufficient | Low Cycling group had 0.1 unit greater decrease in BMI than walking group. | Low Cycling group had 0.5 cm greater decrease in waist circumference than walking group. | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Combination | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Work-Based
Self management | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Physical activity | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Combination | Low Individual level diet and physical activity interventions along with an environmental component prevented BMI increases compared with no intervention. | Moderate Individual level diet and physical activity interventions along with an environmental component prevented weight gain compared with no intervention. Internet-based diet and physical activity counseling prevented weight gain compared with telephone based diet and physical activity counseling. Women in the military who received emails on diet and physical activity lost weight compared with women who received no intervention. | Low Individual level information on diet, physical activity, goal setting instructions and provision of a pedometer and measuring tape prevented waist circumference increases compared with no intervention. | Insufficient | Low Adherence ranged from 17 % to 64%. | Insufficient | Insufficient | Insufficient
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
College-Based
Self management | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Physical activity | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Combination | Low Small group, non-credit sessions with information on goal-setting, diet and physical activity prevented an increase in BMI compared with no intervention. | Low Small group, non-credit sessions with information on goal-setting, diet and physical activity prevented an increase in weight compared with no intervention. | Low No strategy favored. | Insufficient | Low 53% of students attended at least 60% of the sessions during year 1; 26% of students attended at least 60% of the sessions during year 2. | Insufficient | Insufficient | Insufficient
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
With or at Risk For Type 2 Diabetes Mellitus or Cardiovascular Disease
Self management | Low Goal setting results in a meaningful BMI change at one year compared with no intervention. | Insufficient | Low No strategy favored. | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Low No strategy favored. | Low No strategy favored. | Low No strategy favored. | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Physical activity | Low Endurance exercise training prevented BMI gain compared with no intervention. | Low Endurance exercise training prevented BMI gain compared with no intervention. | Low Endurance exercise training prevented BMI gain compared with no intervention. | Insufficient | Low Adherence to endurance exercise training was 57%. | Insufficient | Insufficient | Insufficient
Combination | Low No strategy favored. | Low No strategy favored. | Low Aerobic activity and strength training resulted in greater waist circumference decrease compared with no intervention. | Insufficient | Low Adherence ranged from 65% to 100%. | Low No strategy favored. | Insufficient | Insufficient
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Cancer
Self management | Low Less than 3 hours per day television viewing associated with less BMI gain after colorectal cancer diagnosis compared with viewing more than 5 hours of television per day. | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Insufficient | Low No strategy favored. | Insufficient | Insufficient | Low Adherence ranged from 60% to 90%. | Insufficient | Insufficient | Insufficient
Physical activity | Insufficient | Moderate Aerobic and resistance exercise performed at home prevented weight gain at 1 year compared with no intervention. | Insufficient | Insufficient | Low Adherence ranged from 65% to 79% in the exercise groups and was 100% among controls. | Insufficient | Insufficient | Insufficient
Combination | Low A reduced fat diet with self-management counseling among women with newly diagnosed cancer decreased BMI at 1 year compared with counseling on nutritional adequacy that did not teach self-management techniques. | Low A reduced fat diet with self-management counseling among women with newly diagnosed cancer decreased BMI at 1 year compared with counseling on nutritional adequacy that did not teach self-management techniques. | Insufficient | Insufficient | Low Intervention group reduced calories from fat through 5 years of followup. | Insufficient | Insufficient | Low No adverse events occurred.
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Mental Illness
Self management | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diet | Low No strategy favored | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Physical activity | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Combination | Low No strategy favored | Low No strategy favored | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Built environment or community-level | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

* No studies identified orlistat as a strategy to prevent weight gain.

† For BMI, weight change, and waist circumference the direction of effect is provided for strategies that met the between group difference threshold.

The interventions and approaches that prevented weight gain are described by population or setting below. In a population, if none of the strategies prevented weight gain, we describe all of the strategies that we identified. The strength of evidence for the body of evidence is provided in Table 18 which also includes the evidence about secondary outcomes.

## Evidence

### Evidence Among Adults From a General Population

Eleven randomized trials (65,562 participants) and 12 prospective cohorts (418,520 participants) were identified. The strength of evidence is low but indicates that the following may prevent weight gain: low fat diets (effective for one year but not longer) compared with nutrition guideline handouts, monitoring heart rate during exercise after being instructed how to perform the monitoring during a routine clinic visit compared with physician advice, group lifestyle sessions and text messages sent to mothers of young children compared with diet and physical activity guidelines handouts, and eating fewer meals prepared outside of the home compared with eating more meals prepared outside of the home.

### Evidence Among Obese Adults From a General Population

One randomized trial (124 participants) was identified. The strength of evidence is low that neither behavior was favored to prevent weight or waist circumference change over 18 months between women who were encouraged to walk or bicycle to work compared with those only encouraged to walk to work.

### Evidence for Work-Based Strategies

Seven randomized trials (73,012 participants) were identified. The strength of evidence is moderate for workplace based combination strategies for the prevention of weight gain compared with no intervention. A single work based intervention that combined diet, physical activity and environmental components resulted in meaningful and statistically significant prevention of BMI and waist circumference change at 12 months compared with no intervention. The same work based intervention that combined diet, physical activity and environmental components prevented BMI change at 12 months compared with no intervention and another work based intervention that combined internet-based diet and physical activity counseling prevented weight gain at 24 months compared with no intervention.

### Evidence for College-Based Strategies

Two randomized trials (155 participants) were identified. The strength of evidence is low that small group sessions about healthy lifestyle strategies, not taken for credit, prevented weight gain compared with no intervention.

### Evidence Among Adults at Risk for or With Cardiovascular Disease or Diabetes Mellitus

Eleven randomized trials and one non randomized trial (4,206 participants) were identified. The strength of evidence is low that physical activity interventions prevent weight gain and waist circumference increase in this population compared with no intervention.

### Evidence Among Adults With Cancer

Three randomized trials (2,671 participants) and one prospective cohort based on a cancer registry (1,966 participants) were identified. The strength of evidence is moderate that aerobic and resistance exercise performed at home prevent weight gain among women with cancer compared with no intervention. The strength of evidence is low that decreasing television viewing prevents weight gain among people with cancer compared with increasing or no change in television viewing.

### Evidence Among Adults With Mental Illness

Two trials were identified (163 participants). A randomized trial provided fruits and vegetables to group homes of people with schizophrenia compared with providing fruits and vegetables with education on how to prepare meals. A non randomized trial combined a behavioral intervention with education on diet and exercise among patients initiating anti-psychotic medications compared with no intervention. There is low strength of evidence that no intervention was favored to prevent weight gain.

### Populations Without Evidence

No study included only individuals with healthy weight at baseline; individuals with a family history of obesity; or socioeconomically disadvantaged individuals.

Despite the attention on primary prevention of obesity,108-111,112,113-115 this report provides little evidence for policymakers to use to make recommendations on specific strategies that will prevent weight gain. Existing recommendations are frequently based on intermediate measures of changes in diet or physical activity. For example, the recommendations by the Centers for Disease Control and Prevention for community interventions to prevent obesity acknowledge that the evidence to support the recommendations were not based on studies of at least one year duration that measured weight as an outcome, but on short term changes in food choices or use of environmental modifications to facilitate physical activity.108

The World Health Organization European Ministerial Conference on Counteracting Obesity recommended that primary care providers play a more active role in preventing obesity.111 Although the American Medical Association recommends the prevention of inappropriate weight gain,116 but reimbursement for the time required to provide weight maintenance counseling for the non obese is not supported by Medicare.116,117 The lack of reimbursement may at least partly explain the low adherence with these recommendations by providers. An analysis of the Behavioral Risk Factor Surveillance Survey data in 2003 indicated that only 2.6 percent of individuals with a BMI between 18 and 25 received advice to maintain their current weight by a healthcare provider.

Although evidence is limited to support factors associated with weight gain prevention, the rationale to prevent weight gain is sound given the robust evidence that obesity is associated with poor health outcomes,9,10-16 is costly,22 and is difficult to reverse.118

Identifying the best time to implement an intervention and the population that will be willing to utilize the interventions are areas for prioritization. Three of the interventions targeted populations experiencing life changes such as attending college83 or beginning to cohabitate with a partner.59 During these periods of change, individuals may be more likely to be open to lifestyle modification or more likely to be adherent to the changes. Although these interventions did not uniformly result in weight maintenance compared with control or result in higher levels of adherence, designing interventions to be implemented during these and other life changes (e.g., postpartum, retirement, relocating to a new region) may be considered in future research.

Identifying an individual's interest level in an intervention prior to recommending a weight maintenance strategy may also be of interest. Many studies randomized participants to an intervention followed by multiple in person visits, phone calls and mailings. One trial opted to provide patients with up to three phone invitations to participate in a walking program compared with an information session. Only 33 percent of those invited to walk took part in a walk.56 Allowing the option of participating in an intervention (rather than required visits, phone calls, etc.) demonstrates that individuals who consent to participate in a weight related study may not have the motivation to participate in the particular intervention of interest. Combining a time when a person is already in a period of change with an intervention that an individual is motivated to participate in may be an area for future research.

## Important Unanswered Questions

### Which of the Key Questions Remain Unanswered?

We had a particular interest in identifying evidence about preventing weight gain among individuals with healthy weight at baseline, but found no relevant studies. Similarly, we identified no studies addressing prevention of weight gain among socioeconomically disadvantaged individuals that met our inclusion criteria. Only one intervention was applied at a community level and this trial is more than 20 years old. Only three studies used a cell phone or web based technology as part of a combination intervention.60,73,74 No comparisons involved orlistat, which is available over the counter, and may be used for weight maintenance despite having only a weight loss indication.

### Is Weight Maintenance Relevant if the Majority of the Population Is Overweight or Obese?

One study specifically stated that participants would have preferred assistance losing weight rather than maintaining weight.58 The investigators conducting that study stated that they had a difficult time recruiting women in the healthy weight range and had to expand the study to include overweight women. Presently, the majority of the U.S. population is overweight or obese, so weight loss strategies may be more appropriate than weight gain prevention strategies for most of the population. However, changes that prevent weight gain may be more effective in the healthy weight population than encouraging weight loss in the overweight and obese population. This, however, remains unknown. Environment level interventions can benefit people of all weights. The CDC and WHO recommend environment level interventions, despite the limited availability of long-term data, for this reason.108

### What Are the Motivators To Maintain Weight Among Those Who Are Not Overweight?

In this review, we did not review attitudes about weight change. However, understanding what motivates individuals to maintain a healthy weight may inform strategies. Identifying these motives will be particularly important for individuals who are not overweight. Targeting weight maintenance advice based on one's motives may help increase adherence to modify behaviors and prevent weight gain.119

### Findings in Relationship to What Is Already Known

One previous systematic review has addressed weight gain prevention among adults.36 The authors included randomized trials that had a stated goal of primary prevention of obesity among those with BMI under 30 kg/m^2^ at baseline (or mean BMI less than 30 kg/m^2^ at baseline) or weight loss among those with a BMI of 25 to 30 kg/m^2^ at baseline, had at least three months of followup after the start of the intervention, reported on weight or BMI change and were published between 1996 and 2006. Nine trials were included. Only two of those trials were included in the current review. The other trials did not have followup of at least one year or they allowed participants to have a weight loss goal. The conclusion from that review was that the body of evidence is too small to compare the effectiveness of interventions for obesity prevention.

Despite the interest to prevent weight gain and obesity, there is little evidence to support long term strategies. Previous reviews on physical activity,120 fruit and vegetable consumption,121 and psychological models and behavior change methods122 have come to similar conclusions. A workshop on food technology to prevent obesity also commented that long term studies to support eating behaviors and interventions are lacking.123

## Applicability

Studies that met our inclusion criteria have been implemented in a variety of populations and settings, although very few were designed to prevent weight gain. Observational studies to identify predictors of weight gain have focused on the general population and individuals with cancer. The interventions and approaches described in this review apply to a variety of populations. The settings of the intervention were much more limited. We had hoped to identify more environment level interventions. Unfortunately, many studies about environment level interventions were cross sectional designs and did not meet the criteria for our review.

Although we included studies of individuals with a baseline weight in the healthy, overweight and obese range, these findings apply primarily to overweight individuals. No study included healthy weight individuals exclusively. The one study of obese individuals included abdominally obese individuals.

Because adherence was poor in many interventions, the results may have been more useful if they had been reported by adherence status in addition to the intent-to treat analyses. For example, if participants who adhered to an intervention were more likely to maintain weight than the nonadherent participants, we may have been able to evaluate the evidence based on adherence status and provide more detailed information about the effectiveness of the interventions.

## Implications for Clinical and Policy Decisionmaking

These results may help provide an evidence base for future practice guidelines to influence individual decision making, patient management, and policy decisions. However, we suspect that the strength of evidence for most comparisons is too low to support guidelines.

Behavior change is difficult for individuals whose goal is to prevent weight gain, just as behavior change is difficult for those attempting to lose weight. Eating meals prepared at home is a simple, low cost intervention that prevented weight gain in the included trial. College coursework on healthy diets and physical activity also prevented weight gain. The more intensive interventions, such as endurance exercise performed three times per week, reported few adverse events. Although intensive interventions did not result in strong evidence to promote their adoption, there is no evidence that not adopting a strategy to prevent weight gain is preferable.

## Limitations of the Comparative Effectiveness Review Process

The strength of evidence was low or insufficient for almost all comparison outcome relationships. There are several reasons for these low evidence grades based on how we assessed each study's quality and graded the strength of evidence. We feel, however, that this is a fair appraisal of the risk of bias in these studies.

Trials were frequently downgraded for lack of blinding, for not reporting the blinding of outcome assessors, or for not accounting for losses to followup. We included in this review only observational studies that accounted well for confounding and for losses to followup to ensure that we included only the highest quality observational studies.

Very few studies had a stated goal of weight maintenance or weight gain prevention. Goals to change dietary intake and physical activity commonly reported on weight without a weight-related goal. We excluded studies that explicitly mentioned that at least some of the patients had a goal of weight loss. The best known weight gain prevention trial was excluded for this reason, the Pound of Prevention trial.107 Only one of the included observational studies was nested within a cohort whose original design had a weight related outcome of interest.67

Very few studies reported standard errors or confidence intervals for the between group differences in change in a weight related outcome over time. When the majority of studies did not report a measure of variability, we graded the body of evidence as imprecise. In some instances, the studies did not report a mean difference or point estimate stating there was no significant difference in weight change between the groups.

The heterogeneity of the included interventions and variety of categories of exposures studied among the observational studies prevented meta-analysis. Had the interventions been more homogenous, the lack of reporting on variability would have still prohibited meta-analyses.

Studying weight gain prevention has particular challenges because the expected annual weight gain is small (0.5 kg/year). Measurement error can influence inference based on the small expected difference between groups. A poorly calibrated scale could lead to spurious findings. Even day to day variations in weight could affect the results. Studying weight gain prevention strategies for longer periods of time can help to decrease the noise introduced by these measurement errors. However, with longer followup, the financial resources and motivation of the participants to strictly adhere to an intervention may not be possible. In addition, the randomized trial that is the mainstay of pharmaceutical research is impossible for weight gain prevention strategies because the participants are aware of the strategies that they are following. Long-term observational studies with adequate control for confounding and selection bias may be able to produce evidence equivalent to that from a long-term trial because confounding and selection bias will need to be accounted for in both designs. If a smaller weight gain effect is of interest, such as 0.1 kg/year, the large number of patients needed may make an observational study more feasible than a randomized trial.

## Strengths and Limitations of the Evidence Base

The greatest strength of the evidence base was the variety of populations included. In addition to including populations with very few exclusion criteria representative of the general population, we also observed a variety of studies targeted at individuals that are known to be more likely to gain weight.

Many studies did not report a weight related goal and were included. We may have inadvertently included some trials that had a goal of weight loss but that did not say so explicitly in the published paper; that is, studies labeled as weight maintenance among overweight and obese individuals may not have been solely targeting weight maintenance. We excluded studies that included specific aims of “weight change” associated with power calculations for an expected decrease in weight among the intervention group. However, some studies did not report power calculations or an expected direction of weight change. These studies were necessarily included. All observational studies included individuals with unknown weight related goals.

Controls had better weight maintenance than we expected. In many studies, the weight maintenance was better in the control groups than is expected in a general population. Many control groups had no increase in weight over time. In the general United States population, adults typically gain about 0.5 kg per year.5 It is possible that the knowledge that one will be evaluated on weight regularly may help individuals to maintain weight without an intensive intervention. This may support the use of weight surveillance interventions in a workplace or primary care setting.

Concern exists that encouraging healthy weight individuals to focus on weight may lead to body image issues or eating disorders.124 The frequency of this adverse event was not estimable, as none of the included trials reported on this outcome. However, some believe that there is a spectrum of eating behaviors, including disorders such as anorexia nervosa and bulimia nervosa that may be triggered by weight gain prevention interventions. It is possible that interventions to promote healthful eating, physical activity and weight gain prevention may decrease disordered eating but this is not known.125 The evidence provides no support presently.

## Future Research Needs

We suggest that most comparisons and outcomes that have low or insufficient evidence are future research needs. In particular, we recommend future research to examine strategies to prevent weight gain among healthy weight individuals and, separately, overweight and obese individuals. Interventions for individuals taking anti-psychotic medications are also a high priority given that participants in one trial gained 10 kg in the first year of medication use. Diabetes medications are also associated with weight gain. Interventions for patients initiating diabetes medications are also a high priority subpopulation, although weight loss goals may be more relevant for many of these patients.

Different degrees of intensity of the interventions in varied populations should be compared. Less intensive interventions may be possible given that control groups responded nearly as well as intervention groups in most of the studies that we included.

There are design and reporting considerations that should be considered for future studies. Observational cohorts should make measuring weight a stated goal in their protocols. Studies designed to measure weight over time are more likely to collect high quality weight measurements and have adequate power to study weight gain prevention. Intervention trials should be of sufficient duration to assess the efficacy of interventions for preventing weight gain. We suggest that one year should be a minimum duration of follow up for these trials. Longer follow up will make it easier to identify true effectiveness if individuals typically gain 0.5 kg per year.

Identifying evidence grading criteria for complex, multifactorial, long-term exposures and outcomes such as the influences of habitual diet, activity, and environmental exposures and interventions on long-term weight gain is needed. An alternative method to grade evidence to allow high strength of evidence from observational studies may be worth pursuing for behavioral strategies.

## Conclusions

The evidence provides some, although limited, support for strategies to prevent weight gain. Potentially effective strategies included both those that involved modest behavior change (e.g., preparing meals at home) and more major changes (e.g., endurance exercise training in a gym at least three times per week). Despite the weak evidence for strategies to prevent long-term weight gain, there is no evidence that not adopting a strategy to prevent weight gain is preferable.