# Strength of Evidence Tables and Risk of Bias Assessment

Table 1a Strength of evidence of studies among adults in the general population

Table 1b Risk of bias assessment of studies addressing weight maintenance among adults from the general population

Table 2a Strength of evidence of studies among obese adults

Table 2b Obese only

Table3a Strength of evidence of studies among adults in the work environment

Table 3b Risk of bias assessment of studies in a work setting among adults

Table 4a Strength of evidence of studies among adults in the college environment

Table 4b Risk of bias assessment of studies in the college environment

Table5a Strength of evidence of studies among adults with or at risk for cardiovascular disease or diabetes mellitus

Table 5b Risk of bias assessment of studies addressing weight maintenance among adults with or at risk for cardiovascular disease of diabetes mellitus

Table 6a Strength of evidence of studies among adults with cancer

Table 6b Risk of bias assessment of studies addressing weight maintenance among adults with cancer

Table7a Strength of evidence of studies among adults with mental illness

Table 7b Risk of bias assessment of studies addressing weight maintenance among adults with psychiatric disorders