# Evidence Tables

Table 1 Characteristics of studies on populations with no specific diseases or conditions

Table 2 Participant characteristics in studies reporting on groups without specific diseases or conditions

Table 3 Description of observational exposures in studies among adults in the general population

Table 4 Description of interventions in studies among adults in the general population

Table 5a BMI outcomes among intervention studies among adults in the general population

Table 5b Weight outcomes among intervention studies adults in the general population

Table 5bi Additional detail on weight outcomes among intervention studies among adults in the general population

Table 5c Waist circumference outcomes among intervention studies among adults in the general population

Table 5d Adherence outcomes among intervention studies among adults in the general population

Table 5e Mortality outcomes among intervention studies among adults in the general population

Table 5f Activity related injury among intervention studies among adults in the general population

Table 5g Location of outcomes in the original publication for observational studies

Table 6 Characteristics of studies including only obese adults

Table 7 Participant characteristics of studies including only obese adults

Table 8 Description of interventions in studies among studies including only obese adults in the general population

Table 9a Weight outcomes among obese adults in the general population

Table 9b Waist circumference outcomes among obese adults in the general population

Table 9c Adherence outcomes among obese adults in the general population

Table 10 Characteristics of studies on populations in work setting

Table 11 Participant characteristics in studies reporting on groups in work settings

Table 12 Description of interventions in studies on populations in work settings

Table 13a BMI outcome in studies in a work setting

Table 13b Weight outcome in studies in a work setting, combination interventions

Table 13c Waist circumference outcome in studies in a work setting

Table 13d Adherence in studies in a work setting, combination interventions

Table 14 Characteristics of studies on populations in a college setting

Table 15 Participant characteristics in studies reporting on groups in a college settings

Table 16 Description of interventions in studies on populations in a college setting

Table 17a BMI outcomes in studies in college-settings, combination interventions

Table 17b Weight outcomes in studies in college-settings, combination interventions

Table 17c Waist circumference outcomes in studies in college-settings, combination interventions

Table 17d Adherence in studies in college-settings

Table 18 Characteristics of studies on populations with cardiovascular disease and type 2 Diabetes Mellitus

Table 19 Participant characteristics in studies not reporting on groups with cardiovascular disease and type 2 Diabetes Mellitus

Table 20 Description of interventions in studies on populations with cardiovascular disease and/or type 2 diabetes mellitus

Table 21a BMI outcomes in studies on cardiovascular disease and/or type 2 diabetes mellitus

Table 21b Weight change outcomes in interventional studies on CVD_T2DM

Table 21c Waist circumference outcomes in interventional studies on cardiovascular disease and/or type 2 diabetes mellitus

Table 21d Adherence outcomes in interventional studies cardiovascular disease and/or type 2 diabetes mellitus

Table 21e QOL outcomes in studies without an underlying condition

Table 22 Characteristics of studies on populations with cancer conditions

Table 23 Participant characteristics in studies on populations with Cancer conditions

Table 24a Description of interventions in studies on populations with cancer

Table 24b Description of approaches in observational studies on populations with cancer

Table 25a BMI Outcomes in studies on subjects with cancer

Table 25b Weight outcomes in studies on subjects with cancer

Table 26 Characteristics of weight maintenance intervention studies in populations with psychiatric disorders

Table 27 Baseline characteristics of participants in weight maintenance studies in populations with psych disorders

Table 28 Description of interventions in studies in populations with psychiatric disorders

Table 29a BMI outcomes in interventional studies among adults with psychiatric disorders

Table 29 b Weight outcomes in interventional studies among adults with psychiatric disorders