# List of Excluded Articles

## Does not report [underlined: weight change] over 1 year

Abbott J, Conway S, Etherington C, Fitzjohn J, Gee L, Morton A, Musson H, Webb AK. Perceived body image and eating behavior in young adults with cystic fibrosis and their healthy peers. J Behav Med. 2000;23:501-17. [pmid: 11199084].
Abduelkarem AR, Sharif SI, Hammrouni AM, Aldouibi SS, Albraiki WM, El-Shareif HJ. Risk calculation of developing type 2 diabetes in Libyan adults. Pract. Diabetes Int. 2009;26:148-151.
Abramson EE, Jones D. Reducing junk food palatability and consumption by aversive conditioning. Addictive behaviors. 81(6):145-8.
Abtahi F, Naghshzan A, Zibaeenezhad MJ, Heydari ST, Khosropanah SH, Zamirian M, Aghasadeghi K, Moaref AR. The relationship between body mass index and Pre-Diabetes in teachers residing in Shiraz-Iran 2009. Iran. Cardiovasc. Res. J. 2010;4:112-117.
Abu-Omar Karim, Rütten Alfred. Relation of leisure time, occupational, domestic, and commuting physical activity to health indicators in Europe. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;47:319-323.
Adams Jean, White Martin. Time perspective in socioeconomic inequalities in smoking and body mass index. Health Psychology. 2009;28:83-90. [pmid: 19210021].
Ahn SangNam, Sharkey Joseph R, Smith Matthew Lee, Ory Marcia G, Phillips Charles D. Variations in body mass index among older Americans: The roles of social and lifestyle factors. Journal of Aging and Health. 2011;23:347-366. [pmid: 20881105].
Al-Baghli NA, Al-Ghamdi AJ, Al-Turki KA, El-Zubaier AG, Al-Ameer MM, Al-Baghli FA. Overweight and obesity in the eastern province of Saudi Arabia. Saudi Med J. 2008;29:1319-25. [pmid: 18813420].
Allan JD. Women who successfully manage their weight. West J Nurs Res. 89(11):657-69. discussion 669-75.
Almeida Osvaldo P, Alfonso Helman, Pirkis Jane, Kerse Ngaire, Sim Moira, Flicker Leon, Snowdon John, Draper Brian, Byrne Gerard, Goldney Robert, Lautenschlager Nicola T, Stocks Nigel, Scazufca Marcia, Huisman Martijn, Araya Ricardo, Pfaff Jon. A practical approach to assess depression risk and to guide risk reduction strategies in later life. International Psychogeriatrics. 2011;23:280-291. [pmid: 20880427].
al-shoshan AA. Some sociodemographic factors influencing the nutritional awareness of the Saudi teens and adults: preliminary observations. J R Soc Health. 90(110):213-6.
Althuizen E, van Poppel MN, Seidell JC, van der Wijden C, van Mechelen W. Design of the New Life(style) study: a randomised controlled trial to optimise maternal weight development during pregnancy. BMC Public Health. 2006;6:168. [pmid: 16800869].
Alvarez-Blasco F, Luque-Ramirez M, Escobar-Morreale HF. Diet composition and physical activity in overweight and obese premenopausal women with or without polycystic ovary syndrome. Gynecol Endocrinol. 2011.
American Association of Diabetes Educators. Addressing obesity via diabetes self-management education and training. Diabetes Educ. 2012;38(1):151-4. [pmid: 22328044].
Ames SC, Ames GE, Stevens SR, Patten CA, Werch CE, Schroeder DR. Effect of expressive writing as a treatment adjunct for reducing smoking cessation related weight gain in young adult smokers. Subst. Use Misuse. 2008;43:1315-1325. [pmid: 18696370].
Andajani-Sutjahjo S, Ball K, Warren N, Inglis V, Crawford D. Perceived personal, social and environmental barriers to weight maintenance among young women: A community survey. Int J Behav Nutr Phys Act. 2004;1:15. [pmid: 15462679].
Anderson RM, Funnell MM, Nwankwo R, Gillard ML, Oh M, Fitzgerald JT. Evaluating a problem-based empowerment program for African Americans with diabetes: Results of a randomized controlled trial. Ethn. Dis. 2005;15:671-678. [pmid: 16259492].
Andersson J, Boman K, Jansson JH, Nilsson TK, Lindahl B. Effect of intensive lifestyle intervention on C-reactive protein in subjects with impaired glucose tolerance and obesity. Results from a randomized controlled trial with 5-year follow-up. Biomarkers. 2008;13:671-9. [pmid: 19096961].
Andrade AM, Greene GW, Melanson KJ. Eating slowly led to decreases in energy intake within meals in healthy women. Journal of the American Dietetic Association. 2008;108:1186-91. [pmid: 18589027].
Andrich DE, Filion ME, Woods M, Dwyer JT, Gorbach SL, Goldin BR, Adlercreutz H, Aubertin-Leheudre M. Relationship between essential amino acids and muscle mass, independent of habitual diets, in pre- and post-menopausal US women. Int J Food Sci Nutr. 2011.
Andryukhin A, Frolova E, Vaes B, Degryse J. The impact of a nurse-led care programme on events and physical and psychosocial parameters in patients with heart failure with preserved ejection fraction: a randomized clinical trial in primary care in Russia. Eur J Gen Pract. 2010;16:205-14. [pmid: 21073267].
Appelhans BM, Woolf K, Pagoto SL, Schneider KL, Whited MC, Liebman R. Inhibiting Food Reward: Delay Discounting, Food Reward Sensitivity, and Palatable Food Intake in Overweight and Obese Women. Obesity (Silver Spring). 2011.
Aranceta J, Perez-Rodrigo C, Serra-Majem L, Bellido D, ML, Formiguera X, Moreno B. Prevention of overweight and obesity: a Spanish approach. Public Health Nutrition. 2007;10:1187-1193. [pmid: 17903329].
Arthritis as a potential barrier to physical activity among adults with diabetes--United States, 2005 and 2007. MMWR Morb Mortal Wkly Rep. 2008;57:486-9. [pmid: 18463606].
Artinian Nancy T, Schim Stephanie Myers, Vander Wal Jillon S, Nies Mary A. Eating Patterns and Cardiovascular Disease Risk in a Detroit Mexican American Population. Public Health Nursing. 2004;21:425-434. [pmid: 15363023].
Auchincloss AH, Diez Roux AV, Brown DG, Erdmann CA, Bertoni AG. Neighborhood resources for physical activity and healthy foods and their association with insulin resistance. Epidemiology. 2008;19:146-57. [pmid: 18091002].
Austrin Klein D, Stone WJ. Stages of exercise behavior and caloric expenditure. J Sports Med Phys Fitness. 2002;42:95-102. [pmid: 11832882].
Ayala GX, Elder JP, Campbell NR, Slymen DJ, Roy N, Engelberg M, Ganiats T. Correlates of body mass index and waist-to-hip ratio among Mexican women in the United States: implications for intervention development. Womens Health Issues. 2004;14:155-64. [pmid: 15482966].
Ball K, Owen N, Salmon J, Bauman A, Gore CJ. Associations of physical activity with body weight and fat in men and women. Int J Obes Relat Metab Disord. 2001;25:914-9. [pmid: 11439308].
Banks E. Cohort profile: The 45 and up study. Int. J. Epidemiol. 2008;37:941-947. [pmid: 17881411].
Bathalon GP, Hays NP, McCrory MA, Vinken AG, Tucker KL, Greenberg AS, Castaneda C, Roberts SB. The energy expenditure of postmenopausal women classified as restrained or unrestrained eaters. Eur J Clin Nutr. 2001;55:1059-67. [pmid: 11781672].
Bathalon GP, Hays NP, Meydani SN, Dawson-Hughes B, Schaefer EJ, Lipman R, Nelson M, Greenberg AS, Roberts SB. Metabolic, psychological, and health correlates of dietary restraint in healthy postmenopausal women. J Gerontol A Biol Sci Med Sci. 2001;56:M206-11. [pmid: 11283192].
Baughman Kristin, Logue Everett, Sutton Karen, Capers Cynthia, Jarjoura David, Smucker William. Biopsychosocial characteristics of overweight and obese primary care patients: Do psychosocial and behavior factors mediate sociodemographic effects?. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2003;37:129-137.
Bazata Debbra D, Robinson Jennifer G, Fox Kathleen M, Grandy Susan. Affecting behavior change in individuals with diabetes: Findings from the study to help improve early evaluation and management of risk factors leading to diabetes (SHIELD). The Diabetes Educator. 2008;34:1025-1036. [pmid: 19075084].
Beattie VA, Edwards CA, Hosker JP, Cullen DR, Ward JD, Read NW. Does adding fibre to a low energy, high carbohydrate, low fat diet confer any benefit to the management of newly diagnosed overweight type II diabetics?. British Medical Journal Clinical Research. 94. 1988:1147-1149.
Beaudoin CE, Fernandez C, Wall JL, Farley TA. Promoting healthy eating and physical activity short-term effects of a mass media campaign. Am J Prev Med. 2007;32:217-23. [pmid: 17236742].
Begum P, Richardson CE, Carmichael AR. Obesity in post menopausal women with a family history of breast cancer: prevalence and risk awareness. Int Semin Surg Oncol. 2009;6:1. [pmid: 19133122].
Behn S, Lane DS. A self-teaching weight-control manual: method for increasing compliance and reducing obesity. Patient Education and Counseling. 83(5):63-7.
Belhumeur R, Greene GW, Riebe D, Caldwell M, Ruggiero L, Stillwell K. Fatty acid intake and serum lipids in overweight and obese adults: short-term effects of fat reduction, exercise, and weight loss. Topics in Clinical Nutrition. 2004;19:255-264.
Bemelmans W, van Baal P, Wendel-Vos W, Schuit J, Feskens E, Ament A, Hoogenveen R. The costs, effects and cost-effectiveness of counteracting overweight on a population level. A scientific base for policy targets for the Dutch national plan for action. Prev Med. 2008;46:127-32. [pmid: 17822752].
Beresford SA, Locke E, Bishop S, West B, McGregor BA, Bruemmer B, Duncan GE, Thompson B. Worksite study promoting activity and changes in eating (PACE): design and baseline results. Obesity (Silver Spring). Suppl 1. 2007;15:4S-15S. [pmid: 18073337].
Beresford Shirley AA, Locke Emily, Bishop Sonia, West Briana, McGregor Bonnie A, Bruemmer Barbara, Duncan Glen E, Thompson Beti. Worksite study promoting activity and changes in eating (PACE): Design and baseline results. Obesity. 2007;15:4S-15S. [pmid: 18073337].
Berge JM. What is being served for dinner? Associations between the emotional atmosphere at family meals and health outcomes. Obesity. 2011;19:S130.
Bingham SA, Welch AA, McTaggart A, Mulligan AA, Runswick SA, Luben R, Oakes S, Khaw KT, Wareham N, Day NE. Nutritional methods in the European Prospective Investigation of Cancer in Norfolk. Public Health Nutrition. 2001;4:847-858. [pmid: 11415493].
Birketvedt GS, Aaseth J, Florholmen JR, Ryttig K. Long-term effect of fibre supplement and reduced energy intake on body weight and blood lipids in overweight subjects. Acta Medica (Hradec Kralove). 2000;43:129-32. [pmid: 11294130].
Blanson Henkemans OA, van der Boog PJ, Lindenberg J, van der Mast CA, Neerincx MA, Zwetsloot-Schonk BJ. An online lifestyle diary with a persuasive computer assistant providing feedback on self-management. Technol Health Care. 2009;17:253-67. [pmid: 19641261].
Bleich SN, Wang YC, Wang Y, Gortmaker SL. Increasing consumption of sugar-sweetened beverages among US adults: 1988-1994 to 1999-2004. American Journal of Clinical Nutrition. 2009;89:372-381. [pmid: 19056548].
Blow Julie A, Taylor Thom, Cooper Theodore V, Redfearn Christopher K. Correlates of weight concern and control in a Hispanic college student sample. Eating Behaviors. 2010;11:6-10. [pmid: 19962114].
Blundell JE, Stubbs RJ, Golding C, Croden F, Alam R, Whybrow S, Le Noury J, Lawton CL. Resistance and susceptibility to weight gain: Individual variability in response to a high-fat diet. Physiology & Behavior. 2005;86:614-622. [pmid: 16225895].
Bobb-Liverpool B, Duff EMW, Bailey EY. Compliance and blood pressure control in women with hypertension. West Indian Med. J. 2002;51:236-240. [pmid: 12632640].
Boehmer TK, Hoehner CM, Deshpande AD, Brennan Ramirez LK, Brownson RC. Perceived and observed neighborhood indicators of obesity among urban adults. Int J Obes (Lond). 2007;31:968-77. [pmid: 17224932].
Bolocofsky DN, Coulthard-Morrris L, Spinler D. Prediction of successful weight management from personality and demographic data. Psychol Rep. 84(55):795-802.
Boutelle KN, Jeffery RW, French SA. Predictors of vigorous exercise adoption and maintenance over four years in a community sample. Int J Behav Nutr Phys Act. 2004;1:13. [pmid: 15341656].
Boutelle KN, Kirschenbaum DS, Baker RC, Mitchell ME. How can obese weight controllers minimize weight gain during the high risk holiday season? By self-monitoring very consistently. Health Psychol. 99(18):364-8.
Boutelle Kerri N, Murray David M, Jeffery Robert W, Hennrikus Deborah J, Lando Harry A. Associations between exercise and health behaviors in a community sample of working adults. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2000;30:217-224.
Boyden TW, Pamenter RW, Going SB, Lohman TG, Hall MC, Houtkooper LB, Bunt JC, Ritenbaugh C, Aickin M. Resistance exercise training is associated with decreases in serum low-density lipoprotein cholesterol levels in premenopausal women. Archives of internal medicine. 93(153):97-100.
Bravis V, Hui E, Salih S, Mehar S, Hassanein M, Devendra D. Ramadan Education and Awareness in Diabetes (READ) programme for Muslims with type 2 diabetes who fast during Ramadan. Diabet. Med. 2010;27:327-331. [pmid: 20536496].
Breckenkamp J, Mielck A, Razum O. Health inequalities in Germany: do regional-level variables explain differentials in cardiovascular risk?. BMC Public Health. 2007;7:132. [pmid: 17603918].
Brestrich M, Claus J, Blümchen G. Lactovegetarian diet: effect on changes in body weight, lipid status, fibrinogen and lipoprotein (a) in cardiovascular patients during inpatient rehabilitation treatment. Zeitschrift Für Kardiologie. 1996;85(6):418-27. [pmid: 8767366].
Brown H, Roberts J. Exercising choice: The economic determinants of physical activity behaviour of an employed population. Soc Sci Med. 2011;73:383-90. [pmid: 21757272].
Brown BB, Yamada I, Smith KR, Zick CD, Kowaleski-Jones L, Fan JX. Mixed land use and walkability: Variations in land use measures and relationships with BMI, overweight, and obesity. Health Place. 2009;15:1130-41. [pmid: 19632875].
Brown SA, Garcia AA, Winter M, Silva L, Brown A, Hanis CL. Integrating education, group support, and case management for diabetic Hispanics. Ethn Dis. 2011;21:20-6. [pmid: 21462725].
Brown Wendy J, Trost Stewart G. Life Transitions and Changing Physical Activity Patterns in Young Women. American Journal of Preventive Medicine. 2003;25:140-143. [pmid: 12880882].
Brubaker PH, Rejeski WJ, Smith MJ, Sevensky KH, Lamb KA, Sotile WM, Miller HS Jr. A home-based maintenance exercise program after center-based cardiac rehabilitation: Effects on blood lipids, body composition, and functional capacity. J. Cardiopulm. Rehabil. 2000;20:50-56. [pmid: 10680098].
Buchowski Maciej S, Cohen Sarah S, Matthews Charles E, Schlundt David G, Signorello Lisa B, Hargreaves Margaret K, Blot William J. Physical activity and obesity gap between Black and White women in the southeastern U.S. American Journal of Preventive Medicine. 2010;39:140-147. [pmid: 20621261].
Burleson WE. Giving health a place at the table Two years of progress on Minnesota's obesity plan. Minn Med. 2010;93:47-9. [pmid: 20827956].
Burnett Kent F, Taylor C Barr, Agras W Stewart. Ambulatory computer-assisted behavior therapy for obesity: An empirical model for examining behavioral correlates of treatment outcome. Computers in Human Behavior. 92(8):239-248.
Caan BJ, Flatt SW, Rock CL, Ritenbaugh C, Newman V, Pierce JP. Low-energy reporting in women at risk for breast cancer recurrence. Cancer Epidemiol. Biomarkers Prev. 2000;9:1091-1097. [pmid: 11045793].
Campbell K, Foster-Schubert K, Xiao L, et al. Injuries in sedentary individuals enrolled in a 12-month, randomized, controlled, exercise trial. J Phys Act Health. 2012;9:198-207. [pmid: 22368219].
Carr Lucas J, Bartee R Todd, Dorozynski Chris M, Broomfield James F, Smith Marci L, Smith Derek T. Eight-month follow-up of physical activity and central adiposity: Results from an Internet-delivered randomized control trial intervention. Journal of Physical Activity & Health. 2009;6:444-455. [pmid: 19842458].
Carraca EV, Silva MN, Markland D, et al. Body image change and improved eating self-regulation in a weight management intervention in women. Int J Behav Nutr Phys Act. 2011;8:75. [pmid: 21767360].
Carroll Dianna D, Blanck Heidi M, Serdula Mary K, Brown David R. Obesity, physical activity, and depressive symptoms in a cohort of adults aged 51 to 61. Journal of Aging and Health. 2010;22:384-398. [pmid: 20164412].
Carroll SL, Lee RE, Kaur H, Harris KJ, Strother ML, Huang TT. Smoking, weight loss intention and obesity-promoting behaviors in college students. J Am Coll Nutr. 2006;25:348-53. [pmid: 16943457].
Catlin TK, Simoes EJ, Brownson RC. Environmental and policy factors associated with overweight among adults in Missouri. Am J Health Promot. 2003;17:249-58. [pmid: 12640781].
Chal+_-Rush Angela, Guralnik Jack M, Walkup Michael P, Miller Michael E, Rejeski W Jack, Katula Jeffrey A, King Abby C, Glynn Nancy W, Manini Todd M, Blair Steven N, Fielding Roger A. Relationship between physical functioning and physical activity in the lifestyle interventions and independence for elders pilot. Journal of the American Geriatrics Society. 2010;58:1918-1924. [pmid: 20738437].
Chang HC, Kung YY, Hsieh CF, Hsiung LH Y, Chang SH, Chen THH. Biological risk factors relevant to chronic disease in three ethnic groups in Taiwan: Results from Li-Shin outreaching neighborhood screening (Lions A1). Ethn. Dis. 2008;18:228-234. [pmid: 18507279].
Chang MW, Brown RL, Baumann LJ, Nitzke SA. Self-efficacy and dietary fat reduction behaviors in obese African-American and white mothers. Obesity (Silver Spring). 2008;16:992-1001. [pmid: 18292751].
Chang VW, Christakis NA. Income inequality and weight status in US metropolitan areas. Soc Sci Med. 2005;61:83-96. [pmid: 15847964].
Chang WC, Hsiao CF, Chang HY, Lan TY, Hsiung CA, Shih YT, Tai TY. Betel nut chewing and other risk factors associated with obesity among Taiwanese male adults. International Journal of Obesity. 2006;30:359-363. [pmid: 16116491].
Charreire H, Casey R, Salze P, Kesse-Guyot E, Simon C, Chaix B, Banos A, Badariotti D, Touvier M, Weber C, Oppert JM. Leisure-time physical activity and sedentary behavior clusters and their associations with overweight in middle-aged French adults. International Journal of Obesity. 2010;34:1293-1301. [pmid: 20195284].
Chen CK, Chen YC, Huang YS. Effects of a 10-week weight control program on obese patients with schizophrenia or schizoaffective disorder: A 12-month follow up. Psychiatry Clin. Neurosci. 2009;63:17-22. [pmid: 19067997].
Chen DR, Wen TH. Elucidating the changing socio-spatial dynamics of neighborhood effects on adult obesity risk in Taiwan from 2001 to 2005. Health Place. 2010;16:1248-1258. [pmid: 20832348].
Chen Ellen H, Thom David H, Hessler Danielle M, Phengrasamy La, Hammer Hali, Saba George, Bodenheimer Thomas. Using the Teamlet Model to improve chronic care in an academic primary care practice. Journal of General Internal Medicine. 2010;25:610-614.
Chen Z, Meltzer D. Beefing up with the Chans: evidence for the effects of relative income and income inequality on health from the China Health and Nutrition Survey. Soc Sci Med. 2008;66:2206-17. [pmid: 18325651].
Cho S, Dietrich M, Brown CJ, Clark CA, Block G. The effect of breakfast type on total daily energy intake and body mass index: results from the Third National Health and Nutrition Examination Survey (NHANES III). J Am Coll Nutr. 2003;22:296-302. [pmid: 12897044].
Cholewa Scott, Irwin Jennifer D. Project IMPACT: Brief report on a pilot programme promoting physical activity among university students. Journal of Health Psychology. 2008;13:1207-1212. [pmid: 18987094].
Christian H, Giles-Corti B, Knuiman M, Timperio A, Foster S. The influence of the built environment, social environment and health behaviors on body mass index. Results from RESIDE. Prev Med. 2011.
Cizza G, Marincola P, Mattingly M, Williams L, Mitler M, Skarulis M, Csako G. Treatment of obesity with extension of sleep duration: a randomized, prospective, controlled trial. Clin Trials. 2010;7:274-85. [pmid: 20423926].
Clark D, Chrysler L, Perkins A, Keith NR, Willis DR, Abernathy G, Smith F. Screening, referral, and participation in a weight management program implemented in five CHCs. J Health Care Poor Underserved. 2010;21:617-28. [pmid: 20453361].
Cleghorn GD, Nguyen M, Roberts B, Duran G, Tellez T, Alecon M. Practice-based interventions to improve health care for Latinos with diabetes. Ethn Dis. 2004;14:S117-21. [pmid: 15682780].
Cleland VJ, Dwyer T, Venn AJ. Physical activity and healthy weight maintenance from childhood to adulthood. Obesity (Silver Spring). 2008;16:1427-33. [pmid: 18421277].
Coleman Karen J, Rosenberg Dori E, Conway Terry L, Sallis James F, Saelens Brian E, Frank Lawrence D, Cain Kelli. Physical activity, weight status, and neighborhood characteristics of dog walkers. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;47:309-312.
Collins E, O'Connell S, Jelinek C, Miskevics S, Budiman-Mak E. Evaluation of psychometric properties of Walking Impairment Questionnaire in overweight patients with osteoarthritis of knee. Journal of Rehabilitation Research & Development. 2008;45:559-566. [pmid: 18712641].
Conn VS, Minor MA, Burks KJ. Sedentary older women's limited experience with exercise. J Community Health Nurs. 2003;20:197-208. [pmid: 14644687].
Conner Mark, Johnson Charlotte, Grogan Sarah. Gender, Sexuality, Body Image and Eating Behaviours. Journal of Health Psychology. 2004;9:505-515. [pmid: 15231053].
Cornelisse-Vermaat Judith R, van den Brink Henri+ tte Maassen. Ethnic differences in lifestyle and overweight in the Netherlands. Obesity. 2007;15:483-493. [pmid: 17299122].
Craig CL, Russell SJ, Cameron C. Reliability and validity of Canada's physical activity monitor for assessing trends. Medicine & Science in Sports & Exercise. 2002;34:1462-1467. [pmid: 12218739].
Crawford D, Owen N. The behavioural epidemiology of weight control. Aust J Public Health. 94(18):143-8.
Cress M Elaine, Lewis Richard D, Flatt William. “Better 'n ever” changes with age: A 20-Year Case Study of Successful Aging. ACSM's Health & Fitness Journal. 2011;15:20-25.
Crichton GE, Howe PRC, Buckley JD, et al. Dairy consumption and cardiometabolic health: Outcomes of a 12-month crossover trial. Nutr Metab. 2012;9:19.
Crichton GE, Howe PRC, Buckley JD, et al. Dairy consumption and cardiometabolic health: Outcomes of a 12-month crossover trial. Nutr Metab. 2012;9:19.
Cruz I, Serna C, Real J, Galindo G, Gasco E, Galvan L. Ischemic heart disease and primary care: identifying gender-related differences. An observational study. BMC Fam Pract. 2008;9:60. [pmid: 18973693].
Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. BMJ (Clinical research ed.). 94(309):993-6.
Curry SJ, Kristal AR, Bowen DJ. An application of the stage model of behavior change to dietary fat reduction. Health Educ Res. 92(7):97-105.
Cutts BB, Darby KJ, Boone CG, Brewis A. City structure, obesity, and environmental justice: An integrated analysis of physical and social barriers to walkable streets and park access. Soc. Sci. Med. 2009;69:1314-1322. [pmid: 19751959].
Dale J, Caramlau I, Docherty A, Sturt J, Hearnshaw H. Telecare motivational interviewing for diabetes patient education and support: a randomised controlled trial based in primary care comparing nurse and peer supporter delivery. Trials. 2007;8:18. [pmid: 17598895].
Dallow CB, Anderson J. Using self-efficacy and a transtheoretical model to develop a physical activity intervention for obese women. American journal of health promotion : AJHP. 2003;17:373-81. [pmid: 12858617].
Dejoy DM, Wilson MG, Padilla HM, et al. Process Evaluation Results From an Environmentally Focused Worksite Weight Management Study. Health Educ Behav. 2011;39:405-18. [pmid: 22002249].
Delahanty LM, Meigs JB, Hayden D, Williamson DA, Nathan DM. Psychological and behavioral correlates of baseline BMI in the Diabetes Prevention Program (DPP). Diabetes Care. 2002;25:1992-1998. [pmid: 12401745].
deShazo R, Minor D. Southern Remedy's healthy living: a portion and calorie control program for Mississippi. J Miss State Med Assoc. 2011;52:390-3. 395. 402. [pmid: 22329117].
Devine Carol M, Bove Caron F, Olson Christine M. Continuity and change in women's weight orientations and lifestyle practices through pregnancy and the postpartum period: The influence of life course trajectories and transitional events. Social Science & Medicine. 2000;50:567-582. [pmid: 10641808].
Dietz W. Focus group data pertinent to the prevention of obesity in African Americans. Am J Med Sci. 2001;322:275-8. [pmid: 11721801].
Diller Paul A, Graff Samantha. Regulating Food Retail for Obesity Prevention: How Far Can Cities Go?. Journal of Law, Medicine & Ethics. 2011;39:89-93.
Dinneen SF, O'Hara MC, Byrne M, Newell J, Daly L, O'Shea D, Smith D. The Irish DAFNE Study Protocol: A cluster randomised trial of group versus individual follow-up after structured education for type 1 diabetes. Trials. 2009;10:88. [pmid: 19775465].
Djuric Z, Ellsworth JS, Weldon AL, et al. A diet and exercise intervention during Chemotherapy for breast cancer. Open Obes J. 2011;3:87-97. [pmid: 22238561].
Djuric Z, Ren J, Brown PR, et al. Lifestyle factors associated with serum N-3 fatty acid levels in breast cancer patients. Breast. 2012;21:608-11. [pmid: 22377591].
Dolfing JG, Dubois EF, Wolffenbuttel BHR, Ten Hoor-Aukema NM, Schweitzer DH. Different cycle ergometer outcomes in severely obese men and women without documented cardiopulmonary morbidities before bariatric surgery. Chest. 2005;128:256-262. [pmid: 16002944].
Donnelly JE, Sullivan DK, Smith BK, Jacobsen DJ, Washburn RA, Johnson SL, Hill JO, Mayo MS, Spaeth KR, Gibson C. Alteration of dietary fat intake to prevent weight gain: Jayhawk Observed Eating Trial. Obesity (Silver Spring). 2008;16:107-12. [pmid: 18223621].
Dorsey RR, Eberhardt MS, Ogden CL. Racial and ethnic differences in weight management behavior by weight perception status. Ethn Dis. 2010;20:244-50. [pmid: 20828097].
Drewnowski A, Fiddler EC, Dauchet L, Galan P, Hercberg S. Diet quality measures and cardiovascular risk factors in France: applying the Healthy Eating Index to the SU.VI.MAX study. J Am Coll Nutr. 2009;28:22-9. [pmid: 19571156].
Duffey KJ, Gordon-Larsen P, Shikany JM, Guilkey D, Jacobs DR Jr, Popkin BM. Food price and diet and health outcomes: 20 years of the CARDIA Study. Arch Intern Med. 2010;170:420-6. [pmid: 20212177].
Dumith SC, Gigante DP, Domingues MR. Stages of change for physical activity in adults from Southern Brazil: a population-based survey. Int J Behav Nutr Phys Act. 2007;4:25. [pmid: 17555603].
Dutton Gareth R, Napolitano Melissa A, Whiteley Jessica A, Marcus Bess H. Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;46:216-221.
Duvigneaud N, Wijndaele K, Matton L, Philippaerts R, Lefevre J, Thomis M, Delecluse C, Duquet W. Dietary factors associated with obesity indicators and level of sports participation in Flemish adults: a cross-sectional study. Nutr J. 2007;6:26. [pmid: 17883880].
Dwyer T, Hosmer D, Hosmer T, Venn AJ, Blizzard CL, Granger RH, Cochrane JA, Blair SN, Shaw JE, Zimmet PZ, Dunstan D. The inverse relationship between number of steps per day and obesity in a population-based sample--the AusDiab study. International Journal of Obesity. 2007;31:797-804. [pmid: 17047641].
Dzien A, Dzien-Bischinger C, Winner H, et al. Physical fitness in elderly - Relationship with regular exercise and nutrition. Eur Geriatr Med. 2011;2:S156.
Eakin Elizabeth G, Youlden Danny R, Baade Peter D, Lawler Sheleigh P, Reeves Marina M, Heyworth Jane S, Fritschi Lin. Health behaviors of cancer survivors: Data from an Australian population-based survey. Cancer Causes & Control. 2007;18:881-894. [pmid: 17638108].
Economos CD, Hildebrandt ML, Hyatt RR. College freshman stress and weight change: differences by gender. Am J Health Behav. 2008;32:16-25. [pmid: 18021030].
Eisen SA, Lyons MJ, Goldberg J, True WR. The impact of cigarette and alcohol consumption on weight and obesity. An analysis of 1911 monozygotic male twin pairs. Arch Intern Med. 93(153):2457-63.
Elbel R, Aldana S, Bloswick D, Lyon JL. A pilot study evaluating a peer led and professional led physical activity intervention with blue-collar employees. Work. 2003;21:199-210. [pmid: 14600324].
Elbel Russ, Aldana Steve, Bloswick Don, Lyon Joseph L. A pilot study evaluating a peer led and professional led physical activity intervention with blue-collar employees. Work: Journal of Prevention, Assessment & Rehabilitation. 2003;21:199-210.
Ellaway A, Macintyre S, Bonnefoy X. Graffiti, greenery, and obesity in adults: secondary analysis of European cross sectional survey. BMJ. 2005;331:611-2. [pmid: 16113034].
Elmadfa I, Freisling H. Nutritional status in Europe: methods and results. Nutr Rev. Suppl 1. 2009;67:S130-4. [pmid: 19453667].
Emery SL, Szczypka G, Powell LM, Chaloupka FJ. Public health obesity-related TV advertising: lessons learned from tobacco. Am J Prev Med. 2007;33:S257-63. [pmid: 17884574].
Endres J, Poon SW, Welch P. Diabetics in long-term care. Effect of sweetness on dietary intake. Ann N Y Acad Sci. 89(561):157-61.
Epstein LH, Gordy CC, Raynor HA, Beddome M, Kilanowski CK, Paluch R. Increasing fruit and vegetable intake and decreasing fat and sugar intake in families at risk for childhood obesity. Obesity research. 2001;9:171-8. [pmid: 11323442].
Epstein LH, Dearing KK, Paluch RA, Roemmich JN, Cho D. Price and maternal obesity influence purchasing of low- and high-energy-dense foods. American Journal of Clinical Nutrition. 2007;86:914-922. [pmid: 17921365].
Estaquio C, Kesse-Guyot E, Deschamps V, Bertrais S, Dauchet L, Galan P, Hercberg S, Castetbon K. Adherence to the French Programme National Nutrition Sante Guideline Score is associated with better nutrient intake and nutritional status. J Am Diet Assoc. 2009;109:1031-41. [pmid: 19465185].
Ewing R, Schmid T, Killingsworth R, Zlot A, Raudenbush S. Relationship between urban sprawl and physical activity, obesity, and morbidity. Am J Health Promot. 2003;18:47-57. [pmid: 13677962].
Ezenwaka CE, Akanji AO, Akanji BO, Unwin NC, Adejuwon CA. The prevalence of insulin resistance and other cardiovascular disease risk factors in healthy elderly southwestern Nigerians. Atherosclerosis. 97(128):201-11.
Faber M, Kruger HS. Dietary intake, perceptions regarding body weight, and attitudes toward weight control of normal weight, overweight, and obese black females in a rural village in South Africa. Ethni. Dis. 2005;15:238-245.
Fadupin GT, Joseph EU, Keshinro OO. Prevalence of obesity among type 2 diabetics in Nigeria a case study of patients in Ibadan, Oyo State, Nigeria. Afr J Med Med Sci. 2004;33:381-4. [pmid: 15977449].
Farmer B, Larson BT, Fulgoni VL 3rd, Rainville AJ, Liepa GU. A vegetarian dietary pattern as a nutrient-dense approach to weight management: an analysis of the national health and nutrition examination survey 1999-2004. J Am Diet Assoc. 2011;111:819-27. [pmid: 21616194].
Farrell MA, Hayashi T, Loo RK, Rocha DA, Sanders C, Hernandez M, Will JC. Clinic-based nutrition and lifestyle counseling for hispanic women delivered by community health workers: design of the California WISEWOMAN Study. Journal of Women's Health. 2009;18:733-9.
Felber Dietrich D, Ackermann-Liebrich U, Schindler C, Barthelemy JC, Brandli O, Gold DR, Knopfli B, Probst-Hensch NM, Roche F, Tschopp JM, Eckardstein A, Gaspoz JM. Effect of physical activity on heart rate variability in normal weight, overweight and obese subjects: Results from the SAPALDIA study. Eur. J. Appl. Physiol. 2008;104:557-565. [pmid: 18597107].
Fernandez ID, Su H, Winters PC, Liang H. Association of workplace chronic and acute stressors with employee weight status: data from worksites in turmoil. J Occup Environ Med. Suppl 1. 2010;52:S34-41. [pmid: 20061885].
Fernandez ID, Su H, Winters PC, Liang H. Association of workplace chronic and acute stressors with employee weight status: data from worksites in turmoil. Journal of Occupational & Environmental Medicine. 2010;52:S34-41. [pmid: 20061885].
Ferrario M, Sega R, Chatenoud L, Mancia G, Mocarelli P, Crespi C, Cesana G. Time trends of major coronary risk factors in a northern Italian population (1986-1994). How remarkable are socioeconomic differences in an industrialized low CHD incidence country?. Int. J. Epidemiol. 2001;30:285-291. [pmid: 11369728].
Finkelstein EA, Zhen C, Nonnemaker J, Todd JE. Impact of targeted beverage taxes on higher- and lower-income households. Arch Intern Med. 2010;170:2028-34. [pmid: 21149762].
Flanagan DE, Cox P, Paine D, Davies J, Armitage M. Secondary prevention of coronary heart disease in primary care: a healthy heart initiative. QJM. 99(92):245-50.
Fleet-Michaliszyn SB, Soreca I, Otto AD, Jakicic JM, Fagiolini A, Kupfer DJ, Goodpaster BH. A prospective observational study of obesity, body composition, and insulin resistance in 18 women with bipolar disorder and 17 matched control subjects. J. Clin. Psychiatry. 2008;69:1892-1900. [pmid: 19026257].
Fletcher JM, Frisvold D, Tefft N. Can Soft Drink Taxes Reduce Population Weight?. Contemp Econ Policy. 2010;28:23-35. [pmid: 20657817].
Folsom AR, Jensen MD, Jacobs DR Jr, Hilner JE, Tsai AW, Schreiner PJ. Serum leptin and weight gain over 8 years in African American and Caucasian young adults. Obes Res. 99(7):1-8.
Fontaine KR, Heo M, Bathon J. Are US adults with arthritis meeting public health recommendations for physical activity?. Arthritis Rheum. 2004;50:624-8. [pmid: 14872507].
Forbes GB, Brown MR. Energy need for weight maintenance in human beings: effect of body size and composition. J Am Diet Assoc. 89(89):499-502. [pmid: 2703626].
Ford Denyce S, Goode Carolyn R. African American college students' health behaviors and perceptions of related health issues. Journal of American College Health. 94(42):206-210.
Ford ES, Mokdad AH, Giles WH, Galuska DA, Serdula MK. Geographic variation in the prevalence of obesity, diabetes, and obesity-related behaviors. Obes Res. 2005;13:118-22. [pmid: 15761170].
Forsberg KA, Bj+¦rkman T, Sandman PO, Sandlund M. Influence of a lifestyle intervention among persons with a psychiatric disability: A cluster randomised controlled trial on symptoms, quality of life and sense of coherence. Journal of Clinical Nursing. 2010;19(11-12):1519-28. [pmid: 20384660].
Fortmann AL, Gallo LC, Walker C, Philis-Tsimikas A. Support for disease management, depression, self-care, and clinical indicators among Hispanics with type 2 diabetes in San Diego County, United States of America. Rev Panam Salud Publica. 2010;28:230-4. [pmid: 20963271].
Fowles ER, Walker LO. Correlates of dietary quality and weight retention in postpartum women. Journal of Community Health Nursing. 2006;23:183-197. [pmid: 16863403].
Fox M, Thumshirn M, Menne D, Stutz B, Fried M, Schwizer W. The pathophysiology of faecal spotting in obese subjects during treatment with orlistat. Alimentary pharmacology & therapeutics. 2004;19:311-21. [pmid: 14984378].
Frable PJ, Dart L, Bradley PJ. Healthy Weigh (El camino saludable) phase 1: a retrospective critical examination of program evaluation. Prev Chronic Dis. 2006;3:A98. [pmid: 16776899].
Frame CJ, Green CG, Herr DG, Myers JE, Taylor ML. The stages of change for dietary fat and fruit and vegetable intake of patients at the outset of a cardiac rehabilitation program. American Journal of Health Promotion. 2001;15:405-413. [pmid: 11523497].
Frank LD, Andresen MA, Schmid TL. Obesity relationships with community design, physical activity, and time spent in cars. Am J Prev Med. 2004;27:87-96. [pmid: 15261894].
Frank LD, Kerr J, Sallis JF, Miles R, Chapman J. A hierarchy of sociodemographic and environmental correlates of walking and obesity. Prev Med. 2008;47:172-8. [pmid: 18565576].
Frank LD, Saelens BE, Powell KE, Chapman JE. Stepping towards causation: do built environments or neighborhood and travel preferences explain physical activity, driving, and obesity?. Soc Sci Med. 2007;65:1898-914. [pmid: 17644231].
Frank Lawrence D, Andresen Martin A, Schmid Thomas L. Obesity Relationships with Community Design, Physical Activity, and Time Spent in Cars. American Journal of Preventive Medicine. 2004;27:87-96. [pmid: 15261894].
Freak-Poli R, Wolfe R, Peeters A. Risk of cardiovascular disease and diabetes in a working population with sedentary occupations. J Occup Environ Med. 2010;52:1132-7. [pmid: 21063192].
French SA, Harnack LJ, Toomey TL, Hannan PJ. Association between body weight, physical activity and food choices among metropolitan transit workers. Int J Behav Nutr Phys Act. 2007;4:52. [pmid: 17980026].
Fuemmeler Bernard F, Dedert Eric, McClernon F Joseph, Beckham Jean C. Adverse childhood events are associated with obesity and disordered eating: Results from a U.S. Population-based survey of young adults. Journal of Traumatic Stress. 2009;22:329-333. [pmid: 19588510].
Fulgoni VL 3rd. Current protein intake in America: analysis of the National Health and Nutrition Examination Survey, 2003-2004. Am J Clin Nutr. 2008;87:1554S-1557S. [pmid: 18469286].
Gallant MP, Dorn GP. Gender and race differences in the predictors of daily health practices among older adults. Health Educ. Res. 2001;16:21-31. [pmid: 11252281].
Gapp O, Schweikert B, Meisinger C, Holle R. Disease management programmes for patients with coronary heart disease--an empirical study of German programmes. Health Policy. 2008;88:176-85. [pmid: 18442868].
Garden FL, Jalaludin BB. Impact of urban sprawl on overweight, obesity, and physical activity in Sydney, Australia. J Urban Health. 2009;86:19-30. [pmid: 19052877].
Gavish D, Leibovitz E, Elly I, Shargorodsky M, Zimlichman R. Follow-up in a lipid clinic improves the management of risk factors in cardiovascular disease patients. Isr Med Assoc J. 2002;4:694-7. [pmid: 12440233].
Gebel K, Bauman A, Owen N. Correlates of non-concordance between perceived and objective measures of walkability. Ann Behav Med. 2009;37:228-38. [pmid: 19396503].
Geiss Linda S, James Cherie, Gregg Edward W, Albright Ann, Williamson David F, Cowie Catherine C. Diabetes risk reduction behaviors among U.S. adults with prediabetes. American Journal of Preventive Medicine. 2010;38:403-409. [pmid: 20307809].
Ghayour-Mobarhan M, Taylor A, Lanham-New S, Lamb DJ, Nezhad MA, Kazemi-Bajestani SMR, Ghafouri F, Livingstone C, Wang T, Ferns GAA. Serum selenium and glutathione peroxidase in patients with obesity and metabolic syndrome. Pak. J. Nutr. 2008;7:112-117.
Ghorob A, Vivas MM, De Vore D, Ngo V, Bodenheimer T, Chen E, Thom DH. The effectiveness of peer health coaching in improving glycemic control among low-income patients with diabetes: protocol for a randomized controlled trial. BMC Public Health. 2011;11:208. [pmid: 21457567].
Gibney MJ, Flynn A, Livingstone MBE, McCarthy SN. Overweight, obesity and physical activity levels in Irish adults: Evidence from the North/South Ireland Food Consumption Survey. Proc. Nutr. Soc. 2002;61:3-7. [pmid: 12002792].
Gibson SA. Are diets high in non-milk extrinsic sugars conducive to obesity? An analysis from the Dietary and Nutritional Survey of British Adults. J Hum Nutr Diet. 2007;20:229-38. [pmid: 17539875].
Giesen JCAH, Havermans RC, Nederkoorn C, et al. Impulsivity in the supermarket. Responses to calorie taxes and subsidies in healthy weight undergraduates. Appetite. 2012;58:6-10. [pmid: 22019544].
Giles-Corti B, Macintyre S, Clarkson JP, Pikora T, Donovan RJ. Environmental and lifestyle factors associated with overweight and obesity in Perth, Australia. Am J Health Promot. 2003;18:93-102. [pmid: 13677967].
Gilliland FD, Li YF, Baumgartner K, Crumley D, Samet JM. Physical activity and breast cancer risk in hispanic and non-hispanic white women. Am. J. Epidemiol. 2001;154:442-450. [pmid: 11532786].
Gilson Nicholas D, Puig-Ribera Anna, McKenna Jim, Brown Wendy J, Burton Nicola W, Cooke Carlton B. Do walking strategies to increase physical activity reduce reported sitting in workplaces: A randomized control trial. The International Journal of Behavioral Nutrition and Physical Activity. 2009;6.
Girois Susan B, Kumanyika Shiriki K, Morabia Alfredo, Mauger Elizabeth. A comparison of knowledge and attitudes about diet and health among 35- to 75-year-old adults in the United States and Geneva, Switzerland. American Journal of Public Health. 2001;91:418-424. [pmid: 11236407].
Gold DB, Anderson DR, Serxner SA. Impact of a telephone-based intervention on the reduction of health risks. Am. J. Health Promot. 2000;15:97-106. [pmid: 11194702].
Good CK, Holschuh N, Albertson AM, Eldridge AL. Whole grain consumption and body mass index in adult women: an analysis of NHANES 1999-2000 and the USDA pyramid servings database. J Am Coll Nutr. 2008;27:80-7. [pmid: 18460485].
Goslar PW, Macera CA, Castellanos LG, Hussey JR, Sy FS, Sharpe PA. Blood pressure in Hispanic women: the role of diet, acculturation, and physical activity. Ethn Dis. 97(7):106-13.
Goss J, Grubbs L. Comparative analysis of body mass index, consumption of fruits and vegetables, smoking, and physical activity among Florida residents. Journal of Community Health Nursing. 2005;22:37-46. [pmid: 15695195].
Gow RW, Trace SE, Mazzeo SE. Preventing weight gain in first year college students: an online intervention to prevent the “freshman fifteen”. Eat Behav. 2010;11:33-9. [pmid: 19962118].
Goyenechea E, Holst C, Saris WH, Jebb S, Kafatos A, Pfeiffer A, Handjiev S, Hlavaty P, Stender S, Larsen TM, Astrup A, Martinez JA. Effects of different protein content and glycemic index of ad libitum diets on diabetes risk factors in overweight adults: the DIOGenes multicentre, randomised, dietary intervention trial. Diabetes Metab Res Rev. 2011.
Grabowski DC, Campbell CM, Ellis JE. Obesity and mortality in elderly nursing home residents. Journals of Gerontology Series A: Biological Sciences & Medical Sciences. 2005;60A:1184-1189.
Grafova IB, Freedman VA, Kumar R, Rogowski J. Neighborhoods and obesity in later life. Am J Public Health. 2008;98:2065-71. [pmid: 18799770].
Grafova IB, Freedman VA, Kumar R, Rogowski J. Neighborhoods and obesity in later life [corrected]. [published erratum appears in AM J PUBLIC HEALTH 2009 Mar;99(3):392]. American Journal of Public Health. 2008;98:2065-2071. [pmid: 18799770].
Granner Michelle L, Mburia-Mwalili Adel. Correlates of television viewing among African American and Caucasian women. Women & Health. 2010;50:783-794.
Green CG, Klein EG. Promoting active transportation as a partnership between urban planning and public health: the columbus healthy places program. Public Health Rep. Suppl 1. 2011;126:41-9. [pmid: 21563711].
Greene GW, Schembre SM, White AA, Hoerr SL, Lohse B, Shoff S, Horacek T, Riebe D, Patterson J, Phillips BW, Kattelmann KK, Blissmer B. Identifying clusters of college students at elevated health risk based on eating and exercise behaviors and psychosocial determinants of body weight. J Am Diet Assoc. 2011;111:394-400. [pmid: 21338738].
Guillen Cabrera EO, Barr SI. Comparison of Yukon Women by Weight Loss Effort and Body Mass Index: Self-reported Nutrition and Exercise Practices and Beliefs and Self-rated Health. Can J Diet Pract Res. 98(59):67-74.
Guo X, Warden BA, Paeratakul S, Bray GA. Healthy Eating Index and obesity. Eur J Clin Nutr. 2004;58:1580-6. [pmid: 15162130].
Gupta N, Shah P, Goel K, Misra A, Rastogi K, Vikram NK, Kumari V, Pandey RM, Kondal D, Wasir JS, Bhardwaj S, Gulati S. Imbalanced dietary profile, anthropometry, and lipids in urban Asian Indian adolescents and young adults. J Am Coll Nutr. 2010;29:81-91. [pmid: 20679142].
Hainer V, Kunesova M, Bellisle F, Parizkova J, Braunerova R, Wagenknecht M, Lajka J, Hill M, Stunkard A. The Eating Inventory, body adiposity and prevalence of diseases in a quota sample of Czech adults. International Journal of Obesity. 2006;30:830-836. [pmid: 16418762].
Hall RG, Hanson RW, Borden BL. Permance of two self-managed treatments of overweight in university and community populations. Journal of consulting and clinical psychology. 74(42):781-6.
Hallal PC, Victora CG, Wells JCK, Lima RC. Physical inactivity: prevalence and associated variables in Brazilian adults. Medicine & Science in Sports & Exercise. 2003;35:1894-1900. [pmid: 14600556].
Hallfrisch J, Drinkwater DT, Muller DC, Fleg J, Busby-Whitehead MJ, Andres R, Goldberg A. Physical conditioning status and diet intake in active and sedentary older men. NUTR. RES. 94(14):817-827.
Hansen AR, Ekholm O, Kjoller M. Health behaviour among non-Western immigrants with Danish citizenship. Scand J Public Health. 2008;36:205-10. [pmid: 18519286].
Harralson TL, Emig JC, Polansky M, Walker RE, Cruz JO, Garcia-Leeds C. Un Corazon Saludable: factors influencing outcomes of an exercise program designed to impact cardiac and metabolic risks among urban Latinas. J Community Health. 2007;32:401-12. [pmid: 17940871].
Harring HA, Montgomery K, Hardin J. Perceptions of body weight, weight management strategies, and depressive symptoms among US college students. J. Am. Coll. Health. 2010;59:43-50. [pmid: 20670928].
Harring HA, Montgomery K, Hardin J. Perceptions of body weight, weight management strategies, and depressive symptoms among US college students. Journal of American College Health. 2010;59:43-50. [pmid: 20670928].
Harrington DW, Elliott SJ. Weighing the importance of neighbourhood: a multilevel exploration of the determinants of overweight and obesity. Social Science & Medicine. 2009;68:593-600. [pmid: 19095339].
Harris N, Rosenberg A, Jangda S, O'Brien K, Gallagher ML. Prevalence of obesity in International Special Olympic athletes as determined by body mass index. Journal of the American Dietetic Association. 2003;103:235-237. [pmid: 12589332].
Harshman RS, Richerson GT, Hadker N, Greene BL, Brown TM, Foster TS, Turner BH, Skrepnek SH, Doyle JJ. Impact of a hypertension management/health promotion program on commercial driver's license employees of a self-insured utility company. J Occup Environ Med. 2008;50:359-65. [pmid: 18332786].
Hays NP, Bathalon GP, McCrory MA, Roubenoff R, Lipman R, Roberts SB. Eating behavior correlates of adult weight gain and obesity in healthy women aged 55-65 y. Am J Clin Nutr. 2002;75:476-83. [pmid: 11864852].
Heath Gregory W, Brown David W. Recommended levels of physical activity and health-related quality of life among overweight and obese adults in the United States, 2005. Journal of Physical Activity & Health. 2009;6:403-411. [pmid: 19842453].
Heinrich KM, Lee RE, Regan GR, Reese-Smith JY, Howard HH, Haddock CK, Poston WSC, Ahluwalia JS. How does the built environment relate to body mass index and obesity prevalence among public housing residents?. Am. J. Health Promot. 2008;22:187-194. [pmid: 18251120].
Henwood T, Tuckett A, Turner C. What makes a healthier nurse, workplace or leisure physical activity? Informed by the Australian and New Zealand e-Cohort Study. J Clin Nurs. 2012;21:1746-54. [pmid: 22487492].
Herman DR, Ganz PA, Petersen L, Greendale GA. Obesity and cardiovascular risk factors in younger breast cancer survivors: The Cancer and Menopause Study (CAMS). Breast Cancer Res Treat. 2005;93:13-23. [pmid: 16184454].
Hersey JC, Khavjou O, Strange LB, et al. The efficacy and cost-effectiveness of a community weight management intervention: A randomized controlled trial of the health weight management demonstration. Prev Med. 2012;54:42-49. [pmid: 22001689].
Hlaing W, Nath SD, Huffman FG. Assessing overweight and cardiovascular risks among college students. American Journal of Health Education. 2007;38:83-90.
Hoffman DJ, Policastro P, Quick V, Lee S. Changes in body weight and fat mass of men and women in the first year of college: a study of the “Freshman 15”. Journal of American College Health. 2006;55:41-45. [pmid: 16889314].
Holm-Denoma JM, Joiner TE Jr., Vohs KD, Heatherton TF. The “freshman fifteen” (the “freshman five” actually): predictors and possible explanations. Health Psychology. 2008;27:S3-9. [pmid: 18248103].
Holtgrave DR, Crosby R. Is social capital a protective factor against obesity and diabetes? Findings from an exploratory study. Ann Epidemiol. 2006;16:406-8. [pmid: 16246583].
Howarth NC, Huang TTK, Roberts SB, Lin BH, McCrory MA. Eating patterns and dietary composition in relation to BMI in younger and older adults. International Journal of Obesity. 2007;31:675-684. [pmid: 16953255].
Hsieh C, Wang P, Liu R, Tung S, Chien W, Chen J, Chen C, Kuo M, Hu Y. Orlistat for obesity: benefits beyond weight loss. Diabetes Research & Clinical Practice. 2005;67:78-83. [pmid: 15620437].
Hu FB, Willett WC, Li T, Stampfer MJ, Colditz GA, Manson JE. Adiposity as compared with physical activity in predicting mortality among women. New Engl. J. Med. 2004;351:2694-2703. [pmid: 15616204].
Huang Terry TK, Harris Kari Jo, Lee Rebecca E, Nazir Niaman, Born Wendi, Kaur Harsohena. Assessing Overweight, Obesity, Diet, and Physical Activity in College Students. Journal of American College Health. 2003;52:83-86. [pmid: 14765762].
Hyypp+ñ MT, M+ñki J, Impivaara O, Aromaa A. Leisure participation predicts survival: A population-based study in Finland. Health Promotion International. 2006;21(1):5-12.
Iijima K, Iimuro S, Ohashi Y, et al. Lower physical activity, but not excessive calorie intake, is associated with metabolic syndrome in elderly with type2 diabetes mellitus: The Japanese elderly diabetes intervention trial. Geriatr Gerontol Int. 2012;12:68-76. [pmid: 22435942].
Inelmen EM, Toffanello ED, Enzi G, Sergi G, Coin A, Busetto L, Manzato E. Differences in dietary patterns between older and younger obese and overweight outpatients. J Nutr Health Aging. 2008;12:3-8. [pmid: 18165838].
Irazusta A, Gil S, Ruiz F, Gondra J, Jauregi A, Irazusta J, Gil J. Exercise, physical fitness, and dietary habits of first-year female nursing students. Biol Res Nurs. 2006;7:175-86. [pmid: 16552945].
Irwin ML, McTiernan A, Bernstein L, Gilliland FD, Baumgartner R, Baumgartner K, Ballard-Barbash R. Physical activity levels among breast cancer survivors. Med Sci Sports Exerc. 2004;36:1484-91. [pmid: 15354027].
Jackson M, Ball K, Crawford D. Beliefs about the causes of weight change in the Australian population. Int J Obes Relat Metab Disord. 2001;25:1512-6. [pmid: 11673774].
James KS, Connelly CD, Rutkowski E, McPherson D, Gracia L, Mareno N, Zirkle D. Family-based weight management with Latino mothers and children. Journal for Specialists in Pediatric Nursing. 2008;13:249-262. [pmid: 19238713].
Janelle KC, Barr SI. Nutrient intakes and eating behavior scores of vegetarian and nonvegetarian women. J Am Diet Assoc. 95(95):180-6. 189. quiz 187-8. [pmid: 7852684].
Jarvandi S, Gougeon R, Bader A, et al. Differences in food intake among obese and nonobese women and men with type 2 diabetes. J Am Coll Nutr. 2011;30:225-32. [pmid: 21917702].
Jeong HS, Chae JS, Moon JS, Yoo YS. An individualized teaching program for atherosclerotic risk factor reduction in patients with myocardial infarction. Yonsei medical journal. 2002;43:93-100. [pmid: 11854938].
Jerome GJ, Rohm Young D, Dalcin A, Charleston J, Anthony C, Hayes J, Daumit GL. Physical activity levels of persons with mental illness attending psychiatric rehabilitation programs. Schizophr. Res. 2009;108:252-257. [pmid: 19157787].
Jimenez-Garcia R, Jimenez-Trujillo I, Hernandez-Barrera V, Carrasco-Garrido P, Lopez A, Angel G. Ten-year trends in self-rated health among Spanish adults with diabetes, 1993-2003. Diabetes Care. 2008;31:90-92. [pmid: 17909089].
Jitnarin N, Kosulwat V, Boonpraderm A, Haddock CK, Poston WS. The relationship between smoking, BMI, physical activity, and dietary intake among Thai adults in central Thailand. J Med Assoc Thai. 2008;91:1109-16. [pmid: 18839854].
John U, Hanke M, Rumpf HJ, Thyrian JR. Smoking status, cigarettes per day, and their relationship to overweight and obesity among former and current smokers in a national adult general population sample. Int J Obes (Lond). 2005;29:1289-94. [pmid: 15997244].
Jones Gwyn C, Bell Kianda. Adverse Health Behaviors and Chronic Conditions in Working-Age Women with Disabilities. Family & Community Health: The Journal of Health Promotion & Maintenance. 2004;27:22-36.
Jones H, Edwards L, Vallis TM, Ruggiero L, Rossi SR, Rossi JS, Greene G, Prochaska JO, Zinman B. Changes in diabetes self-care behaviors make a difference in glycemic control: The diabetes stages of change (DiSC) study. Diabetes Care. 2003;26:732-737. [pmid: 12610030].
Jones Katherine E, Otten Jennifer J, Johnson Rachel K, Harvey-Berino Jean R. Removing the bedroom television set: A possible method for decreasing television viewing time in overweight and obese adults. Behavior Modification. 2010;34:290-298. [pmid: 20562322].
Jones-Smith JC, Gordon-Larsen P, Siddiqi A, Popkin BM. Original contribution: Cross-national comparisons of time trends in overweight inequality by socioeconomic status among women using repeated cross-sectional surveys from 37 developing countries, 1989-2007. Am. J. Epidemiol. 2011;173:667-675. [pmid: 21300855].
Juhakoski R, Tenhonen S, Malmivaara A, et al. A pragmatic randomized controlled study of the effectiveness and cost consequences of exercise therapy in hip osteoarthritis. Clin Rehabil. 2011;25:370-83. [pmid: 21078702].
Kaleta D, Makowiec-Dabrowska T, Jegier A. Occupational and leisure-time energy expenditure and body mass index. Int J Occup Med Environ Health. 2007;20:9-16. [pmid: 17509966].
Kalter-Leibovici O, Atamna A, Lubin F, Alpert G, Keren MG, Murad H, Chetrit A, Goffer D, Eilat-Adar S, Goldbourt U. Obesity among Arabs and Jews in Israel: a population-based study. Isr Med Assoc J. 2007;9:525-30. [pmid: 17710784].
Kapinos KA, Yakusheva O. Environmental influences on young adult weight gain: Evidence from a natural experiment. J. Adolesc. Health. 2011;48:52-58. [pmid: 21185524].
Katon WJ, Lin EHB, Russo J, Von Korff M, Ciechanowski P, Simon G, Ludman E, Bush T, Young B. Cardiac risk factors in patients with diabetes mellitus and major depression. J. Gen. Intern. Med. 2004;19:1192-1199. [pmid: 15610329].
Keller C, Trevino RP. Effects of two frequencies of walking on cardiovascular risk factor reduction in Mexican American women. Res Nurs Health. 2001;24:390-401. [pmid: 11746068].
Kelley George A. Gender differences in the physical activity levels of young African-American adults. Journal of the National Medical Association. 95(87):545-548. [pmid: 12911252].
Kennedy BM, Champagne CM, Ryan DH, Newton R Jr, Conish BK, Harsha DW, Levy EJ, Bogle ML. The “Rolling Store:” an economical and environmental approach to the prevention of weight gain in African American women. Ethn Dis. 2009;19:7-12. [pmid: 19341156].
Kennedy BM, Newton RL Jr, York-Crowe E, Walden HM, Ryan DH, White MA, Williamson DA. Recruiting African American girls and parents for a secondary weight gain prevention study. J Cult Divers. 2008;15:181-6. [pmid: 19202720].
KESK-_N G, ENGIN E, DULGERLER. Eating attitude in the obese patients: the evaluation in terms of relational factors. Journal of Psychiatric & Mental Health Nursing. 2010;17:900-908. [pmid: 21078005].
Khare Manorama M, Huber Rachel, Carpenter Ruth Ann, Balmer Pamela W, Bates Nancy J, Nolen Kristen N, Hudson Heather K, Lattyak Rose M, Cursio John F, Loo Ryan K, Farris Rosanne P, Will Julie C. A lifestyle approach for reducing cardiovascular risk factors in underserved women: Design and methods of the Illinois WISEWOMAN program. Journal of Women's Health. 2009;18:409-419.
Khazaal Y, Fr+_sard E, Zimmermann Gg, et al. Eating and weight related cognitions in people with schizophrenia: A case control study. Clinical Practice and Epidemiology in Mental Health. 2006;2.
Kim Daniel, Kawachi Ichiro, Hoorn Stephen Vander, Ezzati Majid. Is inequality at the heart of it? Cross-country associations of income inequality with cardiovascular diseases and risk factors. Social Science & Medicine. 2008;66:1719-1732. [pmid: 18280021].
Kim H, Suzuki T, Yoshida Y, Yoshida H. Effectiveness of multidimensional exercises for the treatment of stress urinary incontinence in elderly community-dwelling Japanese women: a randomized, controlled, crossover trial. Journal of the American Geriatrics Society. 2007;55:1932-9. [pmid: 17944890].
Kim Y, Pike J, Adams H, Cross D, Doyle C, Foreyt J. Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50:112-7. [pmid: 20006642].
Kim Youngmee, Pike Joanne, Adams Heather, Cross Di, Doyle Colleen, Foreyt John. Telephone intervention promoting weight-related health behaviors. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2010;50:112-117.
King Abby C, Goldberg Jennifer H, Salmon Jo, Owen Neville, Dunstan David, Weber Deanne, Doyle Colleen, Robinson Thomas N. Identifying subgroups of U.S. adults at risk for prolonged television viewing to inform program development. American Journal of Preventive Medicine. 2010;38:17-26. [pmid: 20117553].
King Abby C, Marcus Bess, Ahn David, Dunn Andrea L, Rejeski W Jack, Sallis James F, Coday Mace. Identifying subgroups that succeed or fail with three levels of physical activity intervention: The activity counseling trial. Health Psychology. 2006;25:336-347. [pmid: 16719605].
Kirchner CE, Gerber EG, Smith BC. Designed to deter. Community barriers to physical activity for people with visual or motor impairments. Am J Prev Med. 2008;34:349-52. [pmid: 18374250].
Kirjonen J, Telama R, Luukkonen R, Kaaria S, Kaila-Kangas L, Leino-Arjas P. Stability and prediction of physical activity in 5-, 10-, and 28-year follow-up studies among industrial employees. Scandinavian Journal of Medicine & Science in Sports. 2006;16:201-208. [pmid: 16643199].
Klisiewicz AM, Raal F. Sub-optimal management of type 2 diabetes mellitus - A local audit. J. Endocrinol. Metab. Diabetes S. Afr. 2009;14:13-16.
Klumbiene J, Petkeviciene J, Helasoja V, Pr+ñtt+ñl+ñ R, Kasmel A. Sociodemographic and health behaviour factors associated with obesity in adult populations in Estonia, Finland and Lithuania. European Journal of Public Health. 2004;14(4):390-4. [pmid: 15542875].
Knolle-Veentjer S, Huth V, Ferstl R, Aldenhoff JB, Hinze-Selch D. Delay of gratification and executive performance in individuals with schizophrenia: putative role for eating behavior and body weight regulation. J Psychiatr Res. 2008;42:98-105. [pmid: 17126365].
Ko GTC, Cha JCN, Chan AWY, Wong PTS, Hui SSC, Tong SDY, Ng SM, Chow F, Chan CLW. Association between sleeping hours, working hours and obesity in Hong Kong Chinese: The ‘better health for better Hong Kong’ health promotion campaign. International Journal of Obesity. 2007;31:254-260. [pmid: 16718283].
Ko GTC, Chan JCN, Chan AWY, Wong PTS, Hui SSC, Tong SDY, Ng SM, Chow F, Chan CLW. Association between sleeping hours, working hours and obesity in Hong Kong Chinese: The 'better health for better Hong Kong' health promotion campaign. Int. J. Obes. 2007;31:254-260.
Ko Gary TC. Both Obesity and Lack of Physical Activity are Associated with a Less Favorable Health-related Quality of Life in Hong Kong Chinese. American Journal of Health Promotion. 2006;21:49-52. [pmid: 16977913].
Kohl HW III, Dunn AL, Marcus BH, Blair SN. A randomized trial of physical activity interventions: Design and baseline data from Project Active. Med. Sci. Sports Exerc. 98(30):275-283.
Koster A, Harris TB, Moore SC, Schatzkin A, Hollenbeck AR, Van Eijk JTM, Leitzmann MF. Joint associations of adiposity and physical activity with mortality. Am. J. Epidemiol. 2009;169:1344-1351. [pmid: 19372216].
Kourlaba G, Polychronopoulos E, Zampelas A, Lionis C, Panagiotakos DB. Development of a diet index for older adults and its relation to cardiovascular disease risk factors: the Elderly Dietary Index. J Am Diet Assoc. 2009;109:1022-30. [pmid: 19465184].
Krousel-Wood MA, Berger L, Jiang X, Blonde L, Myers L, Webber L. Does home-based exercise improve body mass index in patients with type 2 diabetes? Results of a feasibility trial. Diabetes Res Clin Pract. 2008;79:230-6. [pmid: 17942181].
Kruger J, Yore MM, Kohl HW III. Leisure-time physical activity patterns by weight control status: 1999-2002 NHANES. Med. Sci. Sports Exerc. 2007;39:788-795. [pmid: 17468575].
Kruger J, Yore MM, Kohl HW 3rd. Physical activity levels and weight control status by body mass index, among adults--National Health and Nutrition Examination Survey 1999-2004. Int J Behav Nutr Phys Act. 2008;5:25. [pmid: 18452602].
Kuchler F, Lin BH. The influence of individual choices and attitudes on adiposity. International Journal of Obesity. 2002;26:1017-1022. [pmid: 12080457].
Kwak L, Kremers SP, Werkman A, Visscher TL, van Baak MA, Brug J. The NHF-NRG In Balance-project: the application of Intervention Mapping in the development, implementation and evaluation of weight gain prevention at the worksite. Obes Rev. 2007;8:347-61. [pmid: 17578384].
Kyle UG, Genton L, Gremion G, Slosman DO, Pichard C. Aging, physical activity and height-normalized body composition parameters. Clin Nutr. 2004;23:79-88. [pmid: 14757396].
La Londe Michelle A, Graffagnino Cheryl L, Falko James M, Snow Richard J, Spencer Kathy, Caulin-Glaser Teresa. Effect of a weight management program on the determinants and prevalence of metabolic syndrome. Obesity. 2008;16:637-642. [pmid: 18239562].
Laaksonen M, Prattala R, Helasoja V, Uutela A, Lahelma E. Income and health behaviours. Evidence from monitoring surveys among Finnish adults. J Epidemiol Community Health. 2003;57:711-7. [pmid: 12933778].
Lairon D, Arnault N, Bertrais S, Planells R, Clero E, Hercberg S, Boutron-Ruault M. Dietary fiber intake and risk factors for cardiovascular disease in French adults. American Journal of Clinical Nutrition. 2005;82:1185-1194. [pmid: 16332650].
Lairon D, Arnault N, Bertrais S, Planells R, Clero E, Hercberg S, Boutron-Ruault MC. Dietary fiber intake and risk factors for cardiovascular disease in French adults. The American journal of clinical nutrition. 2005;82:1185-94. [pmid: 16332650].
Lairon D, Bertrais S, Vincent S, Arnault N, Galan P, Boutron MC, and Hercberg S. Dietary fibre intake and clinical indices in the French Supplementation en Vitamines et Mineraux AntioXydants (SU.VI.MAX) adult cohort. Proc Nutr Soc. 2003;62:11-5. [pmid: 12740051].
Lampert T. Smoking, physical inactivity, and obesity: Associations with social status. Deutsches +Ärzteblatt International. 2010;107(1-2):1-7. [pmid: 20090874].
Lantz Paula M, House James S, Lepkowski James M, Williams David R, Mero Richard P, Chen Jieming. Socioeconomic factors, health behaviors, and mortality: Results from a nationally representative prospective study of US adults. JAMA: Journal of the American Medical Association. 98(279):1703-1708.
Laube H, Raptis S, Pfeiffer EF. Effect of nutritional factors on the development of obesity and hyperinsulinism. Deutsche medizinische Wochenschrift (1946). 73(98):1256-9.
Laws R, Counterweight Project Team. A new evidence-based model for weight management in primary care: the Counterweight Programme. Journal of human nutrition and dietetics : the official journal of the British Dietetic Association. 2004;17:191-208. [pmid: 15139891].
Ledikwe JH, Blanck HM, Kettel Khan L, Serdula MK, Seymour JD, Tohill BC, Rolls BJ. Dietary energy density is associated with energy intake and weight status in US adults. Am J Clin Nutr. 2006;83:1362-8. [pmid: 16762948].
Ledikwe JH, Blanck HM, Khan LK, Serdula MK, Seymour JD, Tohill BC, Rolls BJ. Dietary energy density is associated with energy intake and weight status in US adults. Am. J. Clin. Nutr. 2006;83:1362-1368. [pmid: 16762948].
Ledikwe JH, Blanck HM, Khan LK, Serdula MK, Seymour JD, Tohill BC, Rolls BJ. Dietary energy density is associated with energy intake and weight status in US adults. American Journal of Clinical Nutrition. 2006;83:1362-1368. [pmid: 16762948].
Lee PH, Chang WY, Liou TH, Chang PC. Stage of exercise and health-related quality of life among overweight and obese adults. J Adv Nurs. 2006;53:295-303. [pmid: 16441534].
Lee Yin-Yang, Lin Julia L. The effects of trust in physician on self-efficacy, adherence and diabetes outcomes. Social Science & Medicine. 2009;68:1060-1068. [pmid: 19162386].
Legrand P, Schmitt B, Mourot J, Catheline D, Chesneau G, Mireaux M, Kerhoas N, Weill P. The consumption of food products from linseed-fed animals maintains erythrocyte omega-3 fatty acids in obese humans. Lipids. 2010;45:11-9. [pmid: 20012223].
LEITH W. Experiences with the Pennington diet in the management of obesity. Can Med Assoc J. 61(84):1411-4.
Levy J, Atkinson AB, Bell PM, McCance DR, Hadden DR. Beta-cell deterioration determines the onset and rate of progression of secondary dietary failure in type 2 diabetes mellitus: The 10-year follow-up of the belfast diet study. Diabetic Med. 98(15):290-296.
Li C, Chen S, Lan C, Pan W, Chou H, Bai Y, Tzeng M, Lee M, Lai J. The effects of physical activity, body mass index (BMI) and waist circumference (WC) on glucose intolerance in older people: A nationwide study from Taiwan. Archives of Gerontology & Geriatrics. 2011;52:54-59. [pmid: 20206389].
Li F, Harmer PA, Cardinal BJ, Bosworth M, Acock A, Johnson-Shelton D, Moore JM. Built environment, adiposity, and physical activity in adults aged 50-75. Am J Prev Med. 2008;35:38-46. [pmid: 18541175].
Li F, Harmer P, Cardinal BJ, Bosworth M, Johnson-Shelton D. Obesity and the built environment: does the density of neighborhood fast-food outlets matter?. Am J Health Promot. 2009;23:203-9. [pmid: 19149426].
Li F, Harmer P, Cardinal BJ, Bosworth M, Johnson-Shelton D, Moore JM, Acock A, Vongjaturapat N. Built environment and 1-year change in weight and waist circumference in middle-aged and older adults: Portland Neighborhood Environment and Health Study. Am J Epidemiol. 2009;169:401-8. [pmid: 19153214].
Li K, Seo D, Torabi MR, Peng C, Kay NS, Kolbe LJ. Leisure-time physical activity and obesity in black adults in Indianapolis. American Journal of Health Behavior. 2010;34:442-452. [pmid: 20218756].
Liese AD, Bortsov A, Gunther ALB, Dabelea D, Reynolds K, Standiford DA, Liu L, Williams DE, Mayer-Davis EJ, D'Agostino RB, Bell R, Marcovina S. Association of DASH diet with cardiovascular risk factors in youth with diabetes mellitus: The SEARCH for diabetes in youth study. Circulation. 2011;123:1410-1417. [pmid: 21422385].
Lillis Jason, Hayes Steven C. Measuring avoidance and inflexibility in weight related problems. International Journal of Behavioral Consultation and Therapy. 2008;4:348-354.
Lin SJ, Lee KT, Lin KC, Cheng KH, Tsai WC, Sheu SH, Wu MT, Lee CH, Lai WT. Prevalence of prehypertension and associated risk factors in a rural Taiwanese adult population. Int. J. Cardiol. 2010;144:269-273. [pmid: 19223086].
Lin Yi-Chin, Yen Lee-Lan, Chen Ssu-Yuan, Kao Mei-Ding, Tzeng Min-Su, Huang Po-Chao, Pan Wen-Harn. Prevalence of overweight and obesity and its associated factors: Findings from National Nutrition and Health Survey in Taiwan, 1993-1996. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2003;37:233-241.
Lindstrom J, Peltonen M, Eriksson JG, Aunola S, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Uusitupa M, Tuomilehto J. Determinants for the effectiveness of lifestyle intervention in the Finnish Diabetes Prevention Study. Diabetes Care. 2008;31:857-862. [pmid: 18252900].
Liou D, Bauer KD. Exploratory investigation of obesity risk and prevention in Chinese Americans. J Nutr Educ Behav. 2007;39:134-41. [pmid: 17493563].
Liu XQ, Li YH. Epidemiological and nutritional research on prevention of cardiovascular disease in China. Br J Nutr. Suppl 2. 2000;84:S199-203. [pmid: 11242470].
Livingstone M, Robson P, McCarthy S, Kiely M, Harrington K, Browne P, Galvin M, Wareham N, Rennie K. Physical activity patterns in a nationally representative sample of adults in ireland. Public Health Nutr. 2001;4:1107-1116. [pmid: 11820924].
Lockwood CM, Moon JR, Tobkin SE, Walter AA, Smith AE, Dalbo VJ, Cramer JT, Stout JR. Minimal nutrition intervention with high-protein/low-carbohydrate and low-fat, nutrient-dense food supplement improves body composition and exercise benefits in overweight adults: a randomized controlled trial. Nutrition and Metabolism. 2008;5:11. [pmid: 18426586].
Lofgren I, Greene G, Schembre S, Delmonico MJ, Riebe D, Clark P. Comparison of diet quality, physical activity and biochemical values of older adults either reporting or not reporting use of lipid-lowering medication. J Nutr Health Aging. 2010;14:168-72. [pmid: 20126967].
Logan CM, McCaffrey TA, Wallace JM, Robson PJ, Welch RW, Dunne A, Livingstone MB. Investigation of the medium-term effects of Olibratrade mark fat emulsion on food intake in non-obese subjects. European journal of clinical nutrition. 2006;60:1081-91. [pmid: 16538239].
Lombard C, Deeks A, Jolley D, Teede HJ. Preventing weight gain: the baseline weight related behaviors and delivery of a randomized controlled intervention in community based women. BMC Public Health. 2009;9:2. [pmid: 19121220].
Lopez R. Urban sprawl and risk for being overweight or obese. Am J Public Health. 2004;94:1574-9. [pmid: 15333317].
Lowe Michael R, Timko C Alix. What a difference a diet makes: Towards an understanding of differences between restrained dieters and restrained nondieters. Eating Behaviors. 2004;5:199-208. [pmid: 15135332].
Lowry R, Galuska DA, Fulton JE, Wechsler H, Kann L, Collins JL. Physical activity, food choice, and weight management goals and practices among US college students. Am J Prev Med. 2000;18:18-27. [pmid: 10808979].
Lyles TE 3rd, Desmond R, Faulk LE, Henson S, Hubbert K, Heimburger DC, Ard JD. Diet variety based on macronutrient intake and its relationship with body mass index. MedGenMed. 2006;8:39. [pmid: 17406172].
Ma M, Dollar KM, Kibler JL, et al. The Effects of Priming on a Public Health Campaign Targeting Cardiovascular Risks. Prev Sci. 2011;12:333-8. [pmid: 21678029].
Macera CA, Pate RR, Davis DR. Runners' health habits, 1985- ‘The Alameda 7’ revisited. PUBLIC HEALTH REP. 89(104):341-349.
Maddah M, Karandish M. Gender difference in obesity management among Iranian patients with metabolic syndrome. Int. J. Cardiol. 2011;148:109-110. [pmid: 21310499].
Maddigan Sheri L, Majumdar Sumit R, Johnson Jeffrey A. Understanding the complex associations between patient-provider relationships, self-care behaviours, and health-related quality of life in type 2 diabetes: A structural equation modeling approach. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2005;14:1489-1500.
Maley M, Warren BS, Devine CM. Perceptions of the environment for eating and exercise in a rural community. Journal of Nutrition Education & Behavior. 2010;42:185-191. [pmid: 20303828].
Malinauskas BM, Raedeke TD, Aeby VG, Smith JL, Dallas MB. Dieting practices, weight perceptions, and body composition: a comparison of normal weight, overweight, and obese college females. Nutr J. 2006;5:11. [pmid: 16579846].
Managing PraderGÇôWilli syndrome in families: An embodied exploration. Social Science & Medicine. 2011;72(4):460-8. [pmid: 21216515].
Manios Y, Panagiotakos DB, Pitsavos C, Polychronopoulos E, Stefanadis C. Implication of socio-economic status on the prevalence of overweight and obesity in Greek adults: the ATTICA study. Health Policy. 2005;74:224-232. [pmid: 16153482].
Manwaring Jamie L, Bryson Susan W, Goldschmidt Andrea B, Winzelberg Andrew J, Luce Kristine H, Cunning Darby, Wilfley Denise E, Taylor C Barr. Do adherence variables predict outcome in an online program for the prevention of eating disorders?. Journal of Consulting and Clinical Psychology. 2008;76:341-346. [pmid: 18377129].
Marks BL, Ward A, Morris DH, Castellani J, Rippe JM. Fat-free mass is maintained in women following a moderate diet and exercise program. Med Sci Sports Exerc. 95(27):1243-51.
Martin LJ, Lee SY, Couch SC, et al. Shared genetic contributions of fruit and vegetable consumption with BMI in families 20 y after sharing a household. Am J Clin Nutr. 2011;94:1138-43. [pmid: 21831991].
Martin KS, Ferris AM. Food insecurity and gender are risk factors for obesity. Journal of Nutrition Education & Behavior. 2007;39:31-36. [pmid: 17276325].
Maruhama Y, Abe R, Okuguchi F, Ohneda A. Dietary intake and hyperlipidemia in controlled diabetic outpatients. Diabetes. 77(26):94-9.
Mata J, Todd PM, Lippke S. When weight management lasts. Lower perceived rule complexity increases adherence. Appetite. 2010;54:37-43. [pmid: 19751781].
Matheson FI, Moineddin R, Glazier RH. The weight of place: a multilevel analysis of gender, neighborhood material deprivation, and body mass index among Canadian adults. Soc Sci Med. 2008;66:675-90. [pmid: 18036712].
Matus CD, Klaege K. Exercise and weight management. Prim Care. 2007;34:109-16. [pmid: 17481989].
McCabe-Sellers BJ, Bowman S, Stuff JE, Champagne CM, Simpson PM, Bogle ML. Assessment of the diet quality of US adults in the Lower Mississippi Delta. Am J Clin Nutr. 2007;86:697-706. [pmid: 17823435].
McConnon A, Kirk SF, Cockroft JE, Harvey EL, Greenwood DC, Thomas JD, Ransley JK, Bojke L. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res. 2007;7:206. [pmid: 18093289].
McCrone S, Dennis K, Tomoyasu N, Carroll J. A profile of early versus late onset of obesity in postmenopausal women. J Womens Health Gend Based Med. 2000;9:1007-13. [pmid: 11103101].
McGuire MT, Wing RR, Klem ML, Hill JO. Behavioral strategies of individuals who have maintained long-term weight losses. Obes Res. 99(7):334-41.
McTiernan A, Tworoger SS, Rajan KB, Yasui Y, Sorenson B, Ulrich CM, Chubak J, Stanczyk FZ, Bowen D, Irwin ML, Rudolph RE, Potter JD, Schwartz RS. Effect of exercise on serum androgens in postmenopausal women: a 12-month randomized clinical trial. Cancer epidemiology, biomarkers & prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2004;13:1099-105.
McTiernan Anne, Sorensen Bess, lrwin Melinda L, Morgan Angela, Yasui Yutaka, Rudolph Rebecca E, Surawicz Christina, Lampe Johanna W, Lampe Paul D, Ayub Kamran, Potter John D. Exercise effect on weight and body fat in men and women. Obesity. 2007;15:1496-1512. [pmid: 17557987].
Meier M, Berchtold A, Akre C, Michaud PA, Suris JC. Who eats healthily? A population-based study among young Swiss residents. Public Health Nutr. 2010;13:2068-75. [pmid: 20441665].
Mei-Wei Chang, Nitzke Susan, Brown Roger, Baumann Linda. Predictors of Low-income, Obese Mothers' Use of Healthful Weight Management Behaviors. Journal of Nutrition Education & Behavior. 2011;43:87-95. [pmid: 20980206].
Melamed Samuel, Shirom Arie, Toker Sharon, Shapira Itzhak. Burnout and Risk of Type 2 Diabetes: A Prospective Study of Apparently Healthy Employed Persons. Psychosomatic Medicine. 2006;68:863-869. [pmid: 17132837].
Meng H, Liebel D, Wamsley BR. Body mass index and the impact of a health promotion intervention on health services use and expenditures. J Aging Health. 2011;23:743-63. [pmid: 21311047].
Meng H, Wamsley BR, Friedman B, Liebel D, Dixon DA, Gao S, Oakes D, Eggert GM. Impact of body mass index on the effectiveness of a disease management-health promotion intervention on disability status. Am J Health Promot. 2010;24:214-22. [pmid: 20073389].
Meng Hongdao, Wamsley Brenda R, Friedman Bruce, Liebel Dianne, Dixon Denise A, Gao Song, Oakes David, Eggert Gerald M. Impact of body mass index on the effectiveness of a disease management-health promotion intervention on disability status. American Journal of Health Promotion. 2010;24:214-222. [pmid: 20073389].
Mensink GBM, Ziese T, Kok FJ. Benefits of leisure-time physical activity on the cardiovascular risk profile at older age. Int. J. Epidemiol. 99(28):659-666.
Mensink GB, Ziese T, Kok FJ. Benefits of leisure-time physical activity on the cardiovascular risk profile at older age. Int J Epidemiol. 99(28):659-66.
Merchant A, Vatanparast H, Barlas S, Cheskin LJ. Comment on: carbohydrate intake and overweight and obesity among healthy adults. Nutrition in Clinical Practice. 2010;25:680-681.
Metcalf PA, Scagg RRK, Schaaf D, Dyall L, Black PN, Jackson RT. Comparison of different markers of socioeconomic status with cardiovascular disease and diabetes risk factor in the diabetes, heart and health survey. New Zealand Med. J. 2008;121:45-56. [pmid: 18278081].
Mills JP, Perry CD, Reicks M. Eating frequency is associated with energy intake but not obesity in midlife women. Obesity (Silver Spring). 2011;19:552-9. [pmid: 20966909].
Milne Barry J, Belsky Jay, Poulton Richie, Thomson W Murray, Caspi Avshalom, Kieser Jules. Fluctuating asymmetry and physical health among young adults. Evolution and Human Behavior. 2003;24:53-63.
Mirmiran P, Mohammadi F, Allahverdian S, Azizi F. Estimation of energy requirements for adults: Tehran lipid and glucose study. Int J Vitam Nutr Res. 2003;73:193-200. [pmid: 12847996].
Mitchell M. Do African American, Latino, and Caucasian parents and children benefit equally from a weight management intervention?. Southern Online Journal of Nursing Research. 2008;8:2.
Mitchell SD, Eide R, Olsen CH, Stephens MB. Body composition and physical fitness in a cohort of US military medical students. J Am Board Fam Med. 2008;21:165-7. [pmid: 18343867].
Mitsui T, Shimaoka K, Kobayashi T. Examining a 30-minute walking program using a pedometer in the management of type 2 diabetes. Gazz. Med. Ital. Arch. Sci. Med. 2008;167:293-298.
Miyatake N, Takahashi K, Wada J, Nishikawa H, Morishita A, Suzuki H, Kunitomi M, Makino H, Kira S, Fujii M. Daily exercise lowers blood pressure and reduces visceral adipose tissue areas in overweight Japanese men. Diabetes Research & Clinical Practice. 2003;62:149-157. [pmid: 14625129].
Mobley LR, Root ED, Finkelstein EA, Khavjou O, Farris RP, Will JC. Environment, obesity, and cardiovascular disease risk in low-income women. Am J Prev Med. 2006;30:327-332. [pmid: 16530620].
Mojtahedi MC, Valentine RJ, Arngrimsson SA, Wilund KR, Evans EM. The association between regional body composition and metabolic outcomes in athletes with spinal cord injury. Spinal Cord. 2008;46:192-7. [pmid: 17502877].
Mokdad AH, Bowman BA, Ford ES, Vinicor F, Marks JS, Koplan JP. The continuing epidemics of obesity and diabetes in the United States. JAMA. 2001;286:1195-200. [pmid: 11559264].
Monninkhof EM, Peeters PH, Schuit AJ. Design of the sex hormones and physical exercise (SHAPE) study. BMC public health. 2007;7:232. [pmid: 17767724].
Moreno CRC, Louzada FM, Teixeira LR, Borges F, Lorenzi-Filho G. Short sleep is associated with obesity among truck drivers. Chronobiology International. 2006;23:1295-1303. [pmid: 17190714].
Moreno O, Meoro A, Martinez A, Rodriguez C, Pardo C, Aznar S, Lopez P, Serrano J, Boix E, Martin MD, Pico Alfonso AM. Comparison of two low-calorie diets: a prospective study of effectiveness and safety (Structured abstract). Journal of Endocrinological Investigation. 2006;29:633-640. [pmid: 16957412].
Morgan Barbara S, Littell Donna H. A closer look at teaching and contingency contracting with Type II diabetes. Patient Education and Counseling. 88(12):145-158.
Morio B, Barra V, Ritz P, Fellmann N, Bonny JM, Beaufrere B, Boire JY, Vermorel M. Benefit of endurance training in elderly people over a short period is reversible. Eur. J. Appl. Physiol. 2000;81:329-336. [pmid: 10664093].
Morren JA, Baboolal N, Davis GK, McRae A. Assessment of treatment goals attained by patients according to guidelines for diabetes management in primary care centres in North Trinidad. Qual Prim Care. 2010;18:335-43. [pmid: 21114914].
Moser M, Franklin SS. Hypertension management: results of a new national survey for the hypertension education foundation: Harris interactive. J Clin Hypertens (Greenwich). 2007;9:316-23. [pmid: 17485966].
Muros Molina JJ, Oliveras Lopez MJ, Mayor Reyes M, et al. Influence of physical activity and dietary habits on lipid profile, blood pressure and BMI in subjects with metabolic syndrome. Nutr Hosp. 2011;26:1105-9. [pmid: 22072359].
Nagasaka S, Ishikawa S, Nakamura T, Kawakami A, Rokkaku K, Hayashi H, Kusaka I, Higashiyama M, Saito T. Association of endogenous insulin secretion and mode of therapy with body fat and serum leptin levels in diabetic subjects. Metabolism. 98(47):1391-6.
Ndetan H, Evans MW Jr, Felini M, Bae S, Rupert R, Singh KP. Chiropractic and medical use of health promotion in the management of arthritis: analysis of the 2006 National Health Interview Survey. J Manipulative Physiol Ther. 2010;33:419-24. [pmid: 20732578].
Nederkoorn C, Havermans RC, Giesen JCAH, Jansen A. High tax on high energy dense foods and its effects on the purchase of calories in a supermarket. An experiment. Appetite. 2011;56:760-765.
Neighbors LA, Sobal J. Weight and weddings: women's weight ideals and weight management behaviors for their wedding day. Appetite. 2008;50:550-4. [pmid: 18160128].
Nelson KM, Reiber G, Boyko EJ. Diet and exercise among adults with type 2 diabetes: findings from the third national health and nutrition examination survey (NHANES III). Diabetes Care. 2002;25:1722-8. [pmid: 12351468].
Nelson MC, Lust K, Story M, Ehlinger E. Credit card debt, stress and key health risk behaviors among college students. Am J Health Promot. 2008;22:400-7. [pmid: 18677880].
Nelson MC, Lust K, Story M, Ehlinger E. Credit card debt, stress and key health risk behaviors among college students. American Journal of Health Promotion. 2008;22:400-407. [pmid: 18677880].
Nelson Melissa C, Lust Katherine, Story Mary, Ehlinger Ed. Alcohol use, eating patterns, and weight behaviors in a university population. American Journal of Health Behavior. 2009;33:227-237. [pmid: 19063644].
Neumark-Sztainer D, Sherwood NE, French SA, Jeffery RW. Weight control behaviors among adult men and women: cause for concern?. Obes Res. 99(7):179-88.
Neumark-Sztainer Dianne, Rock Cheryl L, Thornquist Mark D, Cheskin Lawrence J, Neuhouser Marian L, Barnett Matt J. Weight-control behaviors among adults and adolescents: Associations with dietary intake. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2000;30:381-391.
Neville L, Bauman A. Self-reported risk factors and management strategies used by people with diabetes mellitus identified from the 1997 and 1998 NSW Health Surveys. N S W Public Health Bull. 2004;15:57-62. [pmid: 15213769].
Nies Mary A, Buffington Cynthia, Cowan George, Hepworth Joseph T. Comparison of lifestyles among obese and nonobese African American and European American women in the commmunity. Nursing Research. 98(47):251-257.
Nishigaki M, Kobayashi K, Abe Y, Seki N, Yokomura T, Yokoyama M, Kazuma K. Preventive behaviour in adult offspring of Type 2 diabetic patients and its relationship to parental advice. Diabet Med. 2008;25:1343-8. [pmid: 19046226].
Noel PH, Copeland LA, Pugh MJ, Kahwati L, Tsevat J, Nelson K, Wang CP, Bollinger MJ, Hazuda HP. Obesity diagnosis and care practices in the Veterans Health Administration. J Gen Intern Med. 2010;25:510-6. [pmid: 20180155].
Nogueira JA, Da Costa TH. Nutrient intake and eating habits of triathletes on a Brazilian diet. Int J Sport Nutr Exerc Metab. 2004;14:684-97. [pmid: 15657473].
Normand Matthew P. Increasing physical activity through self-monitoring, goal setting, and feedback. Behavioral Interventions. 2008;23:227-236.
Nothwehr F, Sinetselaar L, Yang J, Wu H. Stage of change for healthful eating and use of behavioral strategies. Journal of the American Dietetic Association. 2006;106:1035-1041. [pmid: 16815119].
Nothwehr F, Peterson NA. Healthy eating and exercise: strategies for weight management in the rural midwest. Health Educ Behav. 2005;32:253-63. [pmid: 15749970].
Nothwehr F, Dennis L, Wu H. Measurement of behavioral objectives for weight management. Health Educ Behav. 2007;34:793-809. [pmid: 16816028].
Nothwehr Faryle, Dennis Leslie, Wu Haotong. Measurement of behavioral objectives for weight management. Health Education & Behavior. 2007;34:793-809. [pmid: 16816028].
Odoms AM. Dietary approaches for weight management in African Americans. Ethn Dis. 2002;12:S3-34-9. [pmid: 12477152].
OGÇÖDonovan G, Thomas EL, McCarthy JP, et al. Fat distribution in men of different waist girth, fitness level and exercise habit. International Journal of Obesity. 2009;33(12):1356-62. [pmid: 19752873].
Ogden J, Fox P. Examination of the use of smoking for weight control in restrained and unrestrained eaters. INT. J. EATING DISORD. 94(16):177-185.
Ojofeitimi EO, Adeyeye AO, Fadiora AO, Kuteyi AO, Faborode TG, Adegbenro CA, Bakare OE, Setiloane K, Towobola KS. Awareness of obesity and its health hazard among women in a University Community. Pak. J. Nutr. 2007;6:502-505.
O'Neil CE, Nicklas TA, Liu Y, Franklin FA. The impact of dairy product consumption on nutrient adequacy and weight of Head Start mothers. Public Health Nutr. 2009;12:1693-701. [pmid: 19000345].
O'Neil CE, Zanovec M, Cho SS, Nicklas TA. Whole grain and fiber consumption are associated with lower body weight measures in US adults: National Health and Nutrition Examination Survey 1999-2004. Nutr Res. 2010;30:815-22. [pmid: 21147364].
Oppert JM, Kettaneh A, Borys JM, Basdevant A, Ducimetiere P, Charles MA. The relationships between indicators of physical activity, indicators of sedentary behaviour and adiposity in French adults: The FLVS II study. J. Public Health (Germany). 2006;14:87-93.
Orchard J. Sport is more important to health than most realise. J Sci Med Sport. 2004;7:iv-v. [pmid: 15362307].
Orsega-Smith Elizabeth, Mowen Andrew J, Payne Laura L, Godbey Geoffrey. The Interaction of Stress and Park Use on Psycho-physiological Health in Older Adults. Journal of Leisure Research. 2004;36:232-256.
Owens Chequita Smith. Diabetes and obesity risks in African American young adult freshmen attending a historically Black college/university. Journal of Health Care for the Poor and Underserved. 2008;19:1096-1118. [pmid: 19029739].
Paffenbarger RS Jr., Kampert JB, Lee IM, Hyde RT, Leung RW, Wing AL. Changes in physical activity and other lifeway patterns influencing longevity. MED. SCI. SPORTS EXERC. 94(26):857-865.
Park SY, Murphy SP, Wilkens LR, Yamamoto JF, Sharma S, Hankin JH, Henderson BE, Kolonel LN. Dietary patterns using the Food Guide Pyramid groups are associated with sociodemographic and lifestyle factors: the multiethnic cohort study. J Nutr. 2005;135:843-9. [pmid: 15795445].
Park Y, Neckerman KM, Quinn J, Weiss C, Rundle A. Place of birth, duration of residence, neighborhood immigrant composition and body mass index in New York City. Int J Behav Nutr Phys Act. 2008;5:19. [pmid: 18394171].
Paschal Angelia M, Lewis Rhonda K, Martin Arneatha, Dennis-Shipp Donna, Simpson Donna Sanders. Baseline Assessment of the Health Status and Health Behaviors of African Americans Participating in the Activities-for-Life Program: A Community-Based Health Intervention Program. Journal of Community Health: The Publication for Health Promotion and Disease Prevention. 2004;29:305-318.
Pavlou KN, Steffee WP, Lerman RH, Burrows BA. Effects of dieting and exercise on lean body mass, oxygen uptake, and strength. Medicine and science in sports and exercise. 85(17):466-71.
Pendola R, Gen S. BMI, auto use, and the urban environment in San Francisco. Health Place. 2007;13:551-6. [pmid: 16621666].
Perez AP, Phillips MM, Cornell CE, Mays G, Adams B. Promoting dietary change among state health employees in Arkansas through a worksite wellness program: the Healthy Employee Lifestyle Program (HELP). Prev Chronic Dis. 2009;6:A123. [pmid: 19754999].
Perkins KA, Marcus MD, Levine MD, D'Amico D, Miller A, Broge M, Ashcom J, Shiffman S. Cognitive-behavioral therapy to reduce weight concerns improves smoking cessation outcome in weight-concerned women. J Consult Clin Psychol. 2001;69:604-13. [pmid: 11550727].
Peter P, Kumar S. Management of the overweight patient with Type 2 diabetes. Diabet Med. Suppl 4. 2003;20:10-3. [pmid: 12940860].
Phelan Suzanne, Wing Rena R, Raynor Hollie A, Dibello Julia, Nedeau Kim, Peng Wanfeng. Holiday weight management by successful weight losers and normal weight individuals. Journal of Consulting and Clinical Psychology. 2008;76:442-448. [pmid: 18540737].
Pickett Kate E, Kelly Shona, Brunner Eric, Lobstein Tim, Wilkinson Richard G. Wider income gaps, wider waistbands? An ecological study of obesity and income inequality. Journal of Epidemiology and Community Health. 2005;59:670-674. [pmid: 16020644].
Pieniak Z, Perez-Cueto F, Verbeke W. Association of overweight and obesity with interest in healthy eating, subjective health and perceived risk of chronic diseases in three European countries. Appetite. 2009;53:399-406. [pmid: 19712715].
Pinto BM, Borrelli B, King TK, Bock BC, Clark MM, Roberts M, Marcus BH. Weight control smoking among sedentary women. Addict. Behav. 99(24):75-86.
Piron J, Smith LV, Simon P, Cummings PL, Kuo T. Knowledge, attitudes and potential response to menu labelling in an urban public health clinic population. Public Health Nutr. 2010;13:550-5. [pmid: 19706217].
Polimeni Anne-Maree, Austin S Bryn, Kavanagh Anne M. Sexual orientation and weight, body image, and weight control practices among young Australian women. Journal of Women's Health. 2009;18:355-362.
Pon LW, Noor-Aini MY, Ong FB, Adeeb N, Seri SS, Shamsuddin K, Mohamed AL, Hapizah N, Mokhtar A, Wan HW. Diet, nutritional knowledge and health status of urban middle-aged Malaysian women. Asia Pac J Clin Nutr. 2006;15:388-99. [pmid: 16837432].
Poortinga Wouter. Perceptions of the environment, physical activity, and obesity. Social Science & Medicine. 2006;63:2835-2846. [pmid: 16952415].
Pouliou T, Elliott SJ. Individual and socio-environmental determinants of overweight and obesity in Urban Canada. Health Place. 2010;16:389-98. [pmid: 20022286].
Pratt CA. Findings from the 2007 active living research conference implications for future research. Am J Prev Med. 2008;34:366-8. [pmid: 18374254].
Pratt JP, Overfield T, Hilton HG. Health behaviors of nurses and general population women. Health Values: The Journal of Health Behavior, Education & Promotion. 94(18):41-46.
Provencher V, Drapeau V, Tremblay A, Despres JP, Bouchard C, Lemieux S. Eating behaviours, dietary profile and body composition according to dieting history in men and women of the Quebec Family Study. Br J Nutr. 2004;91:997-1004. [pmid: 15182403].
Puhl Rebecca M, Brownell Kelly D. Confronting and Coping with Weight Stigma: An Investigation of Overweight and Obese Adults. Obesity. 2006;14:1802-1815. [pmid: 17062811].
Purcell C, Moyle W, Evans K. An exploration of modifiable health associated risk factors within a cohort of undergraduate nursing students. Contemp Nurse. 2006;23:100-10. [pmid: 17083323].
Qayad MG, Chowdhury PP, Town GM, et al. Sociodemographic differences in body mass index changes among U.S. adults in the behavioral risk factor surveillance system data (BRFSS). Am J Epidemiol. 2011;173:S261.
Quiles JL, Manas M, Martinez MA, Ochoa JJ, Yago MD, Ramirez-Tortosa MC, Carazo E, Martinez-Victoria E. Dietary intake and anthropometric measures in a Spanish students group. Int J Vitam Nutr Res. 96(66):371-7.
Rabin BA, Boehmer TK, Brownson RC. Cross-national comparison of environmental and policy correlates of obesity in Europe. Eur J Public Health. 2007;17:53-61. [pmid: 16751632].
Ramadan J, Barac-Nieto M. Low-frequency physical activity insufficient for aerobic conditioning is associated with lower body fat than sedentary conditions. Nutrition. 2001;17:225-9. [pmid: 11312064].
Rasheed P. Perception of body weight and self-reported eating and exercise behaviour among obese and non-obese women in Saudi Arabia. Public Health. 98(112):409-14.
Raynor uA, Jankowiak NM. Accelerometry-determined adherence to the 2008 physical activity guidelines for americans among college students. American Journal of Health Education. 2010;41:353-362.
Reed JA, Morrison A, Arant CA. Profile differences of users of paved versus natural-surface trails. J Phys Act Health. 2009;6:112-8. [pmid: 19211965].
Reedy Jill, Haines Pamela S, Campbell Marci Kramish. The influence of health behavior clusters on dietary change. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2005;41:268-275.
Regidor E, Gutierrez-Fisac JL, Ronda E, Calle ME, Martinez D, Dominguez V. Impact of cumulative area-based adverse socioeconomic environment on body mass index and overweight. J Epidemiol Community Health. 2008;62:231-8. [pmid: 18272738].
Rennie KL, McCarthy N, Yazdgerdi S, Marmot M, Brunner E. Association of the metabolic syndrome with both vigorous and moderate physical activity. International journal of epidemiology. 2003;32:600-6. [pmid: 12913036].
Reyes-Garc+¡a V, McDade TW, Molina JL, et al. Social rank and adult male nutritional status: Evidence of the social gradient in health from a foraging-farming society. Social Science & Medicine. 2008;67(12):2107-15. [pmid: 18945532].
Rguibi M, Belahsen R. Overweight and obesity among urban Sahraoui women of South Morocco. Ethn Dis. 2004;14:542-7. [pmid: 15724774].
Richard B, Fahimi F, Naderi N. Improving risk factors in diabetic patients participating in a weight management program. South Med J. 2005;98:496-7. [pmid: 15898537].
Richards EL, Riner ME, Sands LP. A social ecological approach of community efforts to promote physical activity and weight management. J Community Health Nurs. 2008;25:179-92. [pmid: 18979329].
Rimmer JH, Rauworth A, Wang E, Heckerling PS, Gerber BS. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Preventive medicine. 2009;48:473-9. [pmid: 19459233].
Risonar MG, Rayco-Solon P, Ribaya-Mercado JD, Solon JA, Cabalda AB, Tengco LW, Solon FS. Physical activity, energy requirements, and adequacy of dietary intakes of older persons in a rural Filipino community. Nutr J. 2009;8:19. [pmid: 19409110].
Ritzwoller DP, Sukhanova AS, Glasgow RE, et al. Intervention costs and cost-effectiveness for a multiple-risk-factor diabetes self-management trial for Latinas: economic analysis of inverted exclamation Viva Bien!. Transl Behav Med. 2011;1:427-35. [pmid: 22081776].
Ritzwoller DP, Toobert D, Sukhanova A, Glasgow RE. Economic analysis of the Mediterranean Lifestyle Program for postmenopausal women with diabetes. Diabetes Educ. 2006;32:761-9. [pmid: 16971709].
Rivera Fernando I, Lieberman Leslie Sue, Rivadeneyra Gloria M, Sallas Anita M. Using a social marketing framework to transform an education program: Lessons from the Hispanic Obesity Prevention and Education (PESO) Program. Social Marketing Quarterly. 2010;16:2-17.
Robert SA, Reither EN. A multilevel analysis of race, community disadvantage, and body mass index among adults in the US. Soc Sci Med. 2004;59:2421-34. [pmid: 15474198].
Robinson JG, Fox KM, Grandy S, Bays H, Bazata DD, Gavin JR III, Green AJ, Lewis SJ, Reed ML, Robinson JG, Rodbard H, Fanning T. Attitudes about health and health-related behaviors in patients with cardiovascular disease or at elevated risk for cardiovascular disease. Prev. Cardiol. 2009;12:136-143. [pmid: 19523056].
Rodriguez-Salceda I, Escortell-Mayor E, Rico-Blazquez M, Riesgo-Fuertes R, Asunsolo-del Barco A, Valdivia-Perez A, del Cura-Gonzalez I, Garcia-Canon AB, Ortiz-Jimenez MF, Cabello-Ballesteros L, Garrido-Elustondo S, Chamorro-Gonzalez L, Rodriguez-Barrientos R. EDUCORE project: a clinical trial, randomised by clusters, to assess the effect of a visual learning method on blood pressure control in the primary healthcare setting. BMC Public Health. 2010;10:449. [pmid: 20673325].
Rolls BJ, Kim-Harris S, Fischman MW, Foltin RW, Moran TH, Stoner SA. Satiety after preloads with different amounts of fat and carbohydrate: implications for obesity. Am J Clin Nutr. 94(60):476-87.
Roof K, Oleru N. Public health: Seattle and King County's push for the built environment. J Environ Health. 2008;71:24-7. [pmid: 18724501].
Roos E, Sarlio-Lahteenkorva S, Lallukka T. Having lunch at a staff canteen is associated with recommended food habits. Public Health Nutr. 2004;7:53-61. [pmid: 14972072].
Rosal MC, Ockene IS, Restrepo A, et al. Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income Latinos: Latinos en control. Diabetes Care. 2011;34:838-44. [pmid: 21378213].
Rosmond R, Bj+¦rntorp P. Quality of life, overweight, and body fat distribution in middle-aged men. Behavioral Medicine. 2000;26(2):90-4. [pmid: 11147295].
Rowland JL, White GW, Wyatt DA. Analysis of an intervention to reduce or prevent secondary conditions for people with spinal cord injuries. J. Clin. Psychol. Med. Settings. 2006;13:263-271.
Rundle A, Field S, Park Y, Freeman L, Weiss CC, Neckerman K. Personal and neighborhood socioeconomic status and indices of neighborhood walk-ability predict body mass index in New York City. Soc Sci Med. 2008;67:1951-8. [pmid: 18954927].
Rutt CD, Coleman KJ. Examining the relationships among built environment, physical activity, and body mass index in El Paso, TX. Prev Med. 2005;40:831-41. [pmid: 15850885].
Ryabov I. The impact of community health workers on behavioral outcomes and glycemic control of diabetes patients on the U.S.-mexico border. Int Q Community Health Educ. 2010;31:387-99. [pmid: 22192944].
Ryttig KR, Larsen S, Haegh L. Treatment of slightly to moderately overweight persons. A double-blind placebo-controlled study with diet and fibre tablets (DumoVital). Tidsskrift for Den Norske Lægeforening : Tidsskrift for Praktisk Medicin, Ny Række. 1984;104(14):989-91.
Sacco WP, Malone JI, Morrison AD, Friedman A, Wells K. Effect of a brief, regular telephone intervention by paraprofessionals for type 2 diabetes. J Behav Med. 2009;32:349-59. [pmid: 19365719].
Sacker A, Cable N. Do adolescent leisure-time physical activities foster health and well-being in adulthood? Evidence from two British birth cohorts. Eur. J. Public Health. 2006;16:331-335.
Sacks Gary, Tikellis Kim, Millar Lynne, Swinburn Boyd. Impact of ‘traffic-light’ nutrition information on online food purchases in Australia. Australian & New Zealand Journal of Public Health. 2011;35:122-126. [pmid: 21463406].
Saelens BE, Sallis JF, Black JB, Chen D. Neighborhood-based differences in physical activity: an environment scale evaluation. Am J Public Health. 2003;93:1552-8. [pmid: 12948979].
Salois MJ. Obesity and diabetes, the built environment, and the ‘local’ food economy in the United States, 2007. Econ Hum Biol. 2011.
Salyer J, Sneed G, Corley MC. Lifestyle and health status in long-term cardiac transplant recipients. Heart & Lung. 2001;30:445-457. [pmid: 11723449].
Santana P, Santos R, Nogueira H. The link between local environment and obesity: a multilevel analysis in the Lisbon Metropolitan Area, Portugal. Soc Sci Med. 2009;68:601-9. [pmid: 19135287].
Saris WH, Astrup A, Prentice AM, Zunft HJ, Formiguera X, Verboeket-van de Venne WP, Raben A, Poppitt SD, Seppelt B, Johnston S, Vasilaras TH, Keogh GF. Randomized controlled trial of changes in dietary carbohydrate/fat ratio and simple vs complex carbohydrates on body weight and blood lipids: the CARMEN study. The Carbohydrate Ratio Management in European National diets. Int J Obes Relat Metab Disord. 2000;24:1310-8. [pmid: 11093293].
Sarraf-Zadegan N, Sadri G, Malek Afzali H, Baghaei M, Mohammadi Fard N, Shahrokhi S, Tolooie H, Poormoghaddas M, Sadeghi M, Tavassoli A, Rafiei M, Kelishadi R, Rabiei K, Bashardoost N, Boshtam M, Asgary S, Naderi G, Changiz T, Yousefie A. Isfahan Healthy Heart Programme: a comprehensive integrated community-based programme for cardiovascular disease prevention and control. Design, methods and initial experience. Acta Cardiologica. 2003;58:309-320. [pmid: 12948036].
Sasaki S, Ishikawa T, Yanagibori R, Amano K. Change and 1-year maintenance of nutrient and food group intakes at a 12-week worksite dietary intervention trial for men at high risk of coronary heart disease. J Nutr Sci Vitaminol (Tokyo). 2000;46:15-22. [pmid: 10868348].
Satia JA, Galanko JA, Neuhouser ML. Food nutrition label use is associated with demographic, behavioral, and psychosocial factors and dietary intake among African Americans in North Carolina. J Am Diet Assoc. 2005;105:392-402. discussion 402-3. [pmid: 15746826].
Schafer E, Schafer RB, Keith PM, B+¦se J. Self-esteem and fruit and vegetable intake in women and men. Journal of Nutrition Education. 1999;31(3):153-60.
Scherwitz L, Kesten D. Seven eating styles linked to overeating, overweight, and obesity. Explore (NY). 2005;1:342-59. [pmid: 16781565].
Schmalz DL. ‘I feel fat’: weight-related stigma, body esteem, and BMI as predictors of perceived competence in physical activity. Obes Facts. 2010;3:15-21. [pmid: 20215791].
Schmidt SL, Harmon KA, Sharp TA, et al. The Effects of Overfeeding on Spontaneous Physical Activity in Obesity Prone and Obesity Resistant Humans. Obesity. 2012. Epub ahead of print.
Schmidt ME, Steindorf K, Mutschelknauss E, Slanger T, Kropp S, Obi N, Flesch-Janys D, Chang-Claude J. Physical activity and postmenopausal breast cancer: effect modification by breast cancer subtypes and effective periods in life. Cancer Epidemiol Biomarkers Prev. 2008;17:3402-10. [pmid: 19029400].
Scholz U, Ochsner S, Luszczynska A. Comparing different boosters of planning interventions on changes in fat consumption in overweight and obese individuals: A randomized controlled trial. Int J Psychol. 2012. Epub ahead of print.
Schrop Susan Labuda, Pendleton Brian F, McCord Gary, Gil Karen M, Stockton LuAnne, McNatt Joshua, Gilchrist Valerie J. The Medically Underserved: Who Is Likely to Exercise and Why?. Journal of Health Care for the Poor and Underserved. 2006;17:276-289. [pmid: 16702715].
Schur EA, Cummings DE, Callahan HS, Foster-Schubert KE. Association of cognitive restraint with ghrelin, leptin, and insulin levels in subjects who are not weight-reduced. Physiology & behavior. 2008;93:706-12. [pmid: 18164043].
Schwartz TL, Jindal S, Simionescu M, Nihalani N, Azhar N, Tirmazi S, Hussein J. Effectiveness of orlistat versus diet and exercise for weight gain associated with antidepressant use: a pilot study. Journal of clinical psychopharmacology. 2004;24:555-6. [pmid: 15349017].
Scott MM, Dubowitz T, Cohen DA. Regional differences in walking frequency and BMI: what role does the built environment play for Blacks and Whites?. Health Place. 2009;15:882-7. [pmid: 19345134].
Sea MM, Woo J, Tong PC, Chow CC, Chan JC. Associations between food variety and body fatness in Hong Kong Chinese adults. J Am Coll Nutr. 2004;23:404-13. [pmid: 15466947].
Segar Michelle, Spruijt-Metz Donna, Nolen-Hoeksema Susan. Go Figure? Body-Shape Motives are Associated with Decreased Physical Activity Participation Among Midlife Women. Sex Roles. 2006;54:175-187.
Selvais PL, Amoussou-Guenou KD, Hermans MP. Belonging to a diabetes patients' association is predictive of better metabolic control. Diabetes Metab. 2008;34:279-82. [pmid: 18436464].
Senekal Marjanne, Steyn Nelia Patricia, Mashego Teresa-Ann B, Nel Johanna Helena. Evaluation of body shape, eating disorders and weight management related parameters in black female students of rural and urban origins. South African Journal of Psychology. 2001;31:45-53.
Shamaley-Kornatz Angelee, Smith Brenda, Tomaka Joe. Weight goals, perceptions, and practices among Hispanic and Anglo college females. Hispanic Journal of Behavioral Sciences. 2007;29:535-553.
Sharkey JR, Branch LG, Giuliani C, Zohoori M, Haines PS. Nutrient intake and BMI as predictors of severity of ADL disability over 1 year in homebound elders. J Nutr Health Aging. 2004;8:131-9. [pmid: 15129297].
Sherwood NE, Morton N, Jeffery RW, French SA, Neumark-Sztainer D, Falkner NH. Consumer preferences in format and type of community-based weight control programs. Am J Health Promot. 98(13):12-8.
Shobana R, Snehalatha C, Latha E, Vijay V, Ramachandran A. Dietary profile of urban south Indians and its relation with glycaemic status. Diabetes Res. Clin. Pract. 98(42):181-186.
Sicras A, Rejas J, Navarro R, Serrat J, Blanca M. Metabolic syndrome in bipolar disorder: A cross-sectional assessment of a Health Management Organization database. Bipolar Disord. 2008;10:607-616. [pmid: 18657245].
Siervo M, Grey P, Nyan OA, Prentice AM. Urbanization and obesity in The Gambia: a country in the early stages of the demographic transition. Eur J Clin Nutr. 2006;60:455-63. [pmid: 16306924].
Silva MN, Markland D, Vieira PN, et al. Helping overweight women become more active: Need support and motivational regulations for different forms of physical activity. Psychology of Sport and Exercise. 2010;11(6):591-601.
Silva EF, Lewi DS, Vedovato GM, Garcia VR, Tenore SB, Bassichetto KC. Nutritional and clinical status, and dietary patterns of people living with HIV/AIDS in ambulatory care in Sao Paulo, Brazil. Rev Bras Epidemiol. 2010;13:677-88. [pmid: 21180856].
Silva M, Clinton J, Appleton S, Flanagan P. Diabetes self-management education in South Auckland, New Zealand, 2007-2008. Prev Chronic Dis. 2011;8:A42. [pmid: 21324256].
Simkin-Silverman LR, Wing RR. Weight gain during menopause. Is it inevitable or can it be prevented?. Postgrad Med. 2000;108:47-50. 53. 6. [pmid: 11004935].
Sisson SB, Camhi SM, Church TS, Tudor-Locke C, Johnson WD, Katzmarzyk PT. Accelerometer-determined steps/day and metabolic syndrome. Am J Prev Med. 2010;38:575-82. [pmid: 20494233].
Slattery ML, Sweeney C, Edwards S, Herrick J, Murtaugh M, Baumgartner K, Guiliano A, Byers T. Physical activity patterns and obesity in Hispanic and non-Hispanic white women. Medicine & Science in Sports & Exercise. 2006;38:33-41. [pmid: 16394951].
Slawta JN, McCubbin JA, Wilcox AR, Fox SD, Nalle DJ, Anderson G. Coronary heart disease risk between active and inactive women with multiple sclerosis. Med Sci Sports Exerc. 2002;34:905-12. [pmid: 12048314].
Slentz CA, Bateman LA, Willis LH, et al. Effects of aerobic vs. resistance training on visceral and liver fat stores, liver enzymes, and insulin resistance by HOMA in overweight adults from STRRIDE AT/RT. Am J Physiol Endocrinol Metab. 2011;301:E1033-9. [pmid: 21846904].
Smith KE, Levine BA, Clement SC, Hu M, Alaoui A, Mun SK. Impact of MYCARETEAM for poorly controlled diabetes mellitus. Diabetes Technology & Therapeutics. 2004;6:828-835. [pmid: 15684636].
Smith S, Yeomans D, Bushe CJ, Eriksson C, Harrison T, Holmes R, Mynors-Wallis L, Oatway H, Sullivan G. A well-being programme in severe mental illness. Baseline findings in a UK cohort. Int J Clin Pract. 2007;61:1971-8. [pmid: 17997803].
Smith T, Hawks SR. Intuitive eating, diet composition, and the meaning of food in healthy weight promotion. American Journal of Health Education. 2006;37:130-136.
Snethen JA, Broome ME, Kelber S, Leicht S, Joachim J, Goretzke M. Dietary and physical activity patterns: examining fathers' perspectives. J Spec Pediatr Nurs. 2008;13:201-11. [pmid: 18638050].
Sohler N, Lubetkin E, Levy J, Soghomonian C, Rimmerman A. Factors associated with obesity and coronary heart disease in people with intellectual disabilities. Soc Work Health Care. 2009;48:76-89. [pmid: 19197767].
Solomon TP, Haus JM, Kelly KR, Cook MD, Filion J, Rocco M, Kashyap SR, Watanabe RM, Barkoukis H, Kirwan JP. A low-glycemic index diet combined with exercise reduces insulin resistance, postprandial hyperinsulinemia, and glucose-dependent insulinotropic polypeptide responses in obese, prediabetic humans. The American journal of clinical nutrition. 2010;92:1359-68. [pmid: 20980494].
Spring B, Pagoto S, Pingitore R, Doran N, Schneider K, Hedeker D. Randomized controlled trial for behavioral smoking and weight control treatment: effect of concurrent versus sequential intervention. J Consult Clin Psychol. 2004;72:785-96. [pmid: 15482037].
Stachowska E, Wesolowska T, Safranow K, Domanski L, Rac M, Dziedziejko V, Ciechanowski K, Chlubek D. Simple dietary interventions reduce the risk factors of atherosclerosis in renal graft recipients. Journal of renal nutrition : the official journal of the Council on Renal Nutrition of the National Kidney Foundation. 2005;15:291-7. [pmid: 16007558].
Stamatakis KA, Brownson RC. Sleep duration and obesity-related risk factors in the rural Midwest. Prev Med. 2008;46:439-44. [pmid: 18155130].
Sternfeld B, Ainsworth BE, Quesenberry CP Jr. Physical activity patterns in a diverse population of women. Preventive Medicine. 99(28):313-323.
Sternfeld B, Ainsworth BE, Quesenberry CP. Physical activity patterns in a diverse population of women. Prev Med. 99(28):313-23.
Stewart T, Han H, Allen RH, Bathalon G, Ryan DH, Newton RL Jr, Williamson DA. H.E.A.L.T.H.: efficacy of an internet/population-based behavioral weight management program for the U.S. Army. J Diabetes Sci Technol. 2011;5:178-87. [pmid: 21303642].
Stice E, Ragan J. A preliminary controlled evaluation of an eating disturbance psychoeducational intervention for college students. The International journal of eating disorders. 2002;31:159-71. [pmid: 11920977].
Stiggelbout Maarten, Hopman-Rock Marijke, van Mechelen Willem. Entry correlates and motivations of older adults participating in organized exercise programs. Journal of Aging and Physical Activity. 2008;16:342-354. [pmid: 18660554].
Stolarczyk LM, Gilliland SS, Lium DJ, Owen CL, Perez GE, Kriska AM, Ainsworth BE, Carter JS. Knowledge, attitudes and behaviors related to physical activity among Native Americans with diabetes. Ethn Dis. 99(9):59-69.
Stolz D, Miller M, Bannerman E, Whitehead C, Crotty M, Daniels L. Nutrition screening and assessment of patients attending a multidisciplinary falls clinic. Nutrition & Dietetics. 2002;59:234-239.
Streppel MT, de Groot LCPGM, Feskens EJM. Nutrient-rich foods in relation to various measures of anthropometry. Fam Pract. 2012;29:i36-i43. [pmid: 22399554].
Strong KA, Parks SL, Anderson E, Winett R, Davy BM. Weight gain prevention: identifying theory-based targets for health behavior change in young adults. J Am Diet Assoc. 2008;108:1708-1715. [pmid: 18926139].
Subramanian SV, Kawachi I, Smith GD. Income inequality and the double burden of under- and overnutrition in India. J Epidemiol Community Health. 2007;61:802-9. [pmid: 17699536].
Suder Agnieszka. Body fatness and its social and lifestyle determinants in young working males from Cracow, Poland. Journal of Biosocial Science. 2009;41:139-154. [pmid: 18442432].
Sutherland LA, Kaley LA, Fischer L. Guiding stars: the effect of a nutrition navigation program on consumer purchases at the supermarket. Am J Clin Nutr. 2010;91:1090S-1094S. [pmid: 20147468].
Suzuki M, Murashima M, Hoerr SL. Body mass and fatness of Japanese college women and relationship to place of residence. Nutrition & Dietetics. 2007;64:159-164.
Tahbaz F, Kreis I, Calvert D. An audit of diabetes control, dietary management and quality of life in adults with type 1 diabetes mellitus, and a comparison with nondiabetic subjects. Journal of Human Nutrition & Dietetics. 2006;19:3-11. [pmid: 16448469].
Tamakoshi A, Kawado M, Ozasa K, Tamakoshi K, Lin Y, Yagyu K, Kikuchi S, Hashimoto S. Impact of smoking and other lifestyle factors on life expectancy among japanese: findings from the Japan Collaborative Cohort (JACC) Study. J Epidemiol. 2010;20:370-6. [pmid: 20631456].
Tang TS, Funnell MM, Noorulla S, et al. Sustaining short-term improvements over the long-term: results from a 2-year diabetes self-management support (DSMS) intervention. Diabetes Res Clin Pract. 2012;95:85-92. [pmid: 21872962].
Tang TS, Funnell MM, Oh M. Long-lasting effects of a 2-year diabetes self-management (DSMS) intervention: outcomes at 1-year follow-up. Diabetes. 2011;60:A83.
Tang Tricia S, Funnell Martha M, Brown Morton B, Kurlander Jacob E. Self-management support in Gǣreal-worldGg̱ settings: An empowerment-based intervention. Patient Education and Counseling. 2010;79:178-184. [pmid: 19889508].
Tapsell LC, Hokman A, Sebastiao A, Denmeade S, Martin G, Calvert GD, Jenkins AB. The impact of usual dietary patterns, selection of significant foods and cuisine choices on changing dietary fat under ‘free living’ conditions. Asia Pac J Clin Nutr. 2004;13:86-91. [pmid: 15003920].
Tariq SH, Karcic E, Thomas DR, Thomson K, Philpot C, Chapel DL, Morley JE. The use of a no-concentrated-sweets diet in the management of type 2 diabetes in nursing homes. J Am Diet Assoc. 2001;101:1463-6. [pmid: 11762744].
Taru C, Tsutou A, Nakawatase Y, Usami M, Miyawaki I. Gender differences of dietary self-management behavior affecting control indices in type II diabetes. Kobe J Med Sci. 2008;54:E82-96. [pmid: 18772617].
Taylor Adrian H, Doust Jo, Webborn Nick. Randomised controlled trial to examine the effects of a GP exercise referral programme in Hailsham, East Sussex, on modifiable coronary heart disease risk factors. Journal of Epidemiology and Community Health. 98(52):595-601.
Teng Ju-Hsi, Lin Kuan-Chia, Ho Bin-Shenq. Application of classification tree and logistic regression for the management and health intervention plans in a community-based study. Journal of Evaluation in Clinical Practice. 2007;13:741-748. [pmid: 17824867].
Terry PE, Seaverson EL, Grossmeier J, Anderson DR. Effectiveness of a worksite telephone-based weight management program. Am J Health Promot. 2011;25:186-9. [pmid: 21192748].
Teunissen-Beek KF, Dopheide J, Geleijnse JM, et al. Protein supplementation lowers blood pressure in overweight adults: effect of dietary proteins on blood pressure (PROPRES), a randomized trial. Am J Clin Nutr. 2012;95:966-71. [pmid: 22357725].
Thoolen B, De Ridder D, Bensing J, Maas C, Griffin S, Gorter K, Rutten G. Effectiveness of a self-management intervention in patients with screen-detected type 2 diabetes. Diabetes Care. 2007;30:2832-7. [pmid: 17666461].
Thornton PL, Kieffer EC, Salabarria-Pena Y, Odoms-Young A, Willis SK, Kim H, Salinas MA. Weight, diet, and physical activity-related beliefs and practices among pregnant and postpartum Latino women: the role of social support. Matern Child Health J. 2006;10:95-104. [pmid: 16534660].
Tilt JH, Unfried TM, Roca B. Using objective and subjective measures of neighborhood greenness and accessible destinations for understanding walking trips and BMI in Seattle, Washington. Am J Health Promot. 2007;21:371-9. [pmid: 17465183].
Timperio A, Crawford DA. Public definitions of success in weight management. Nutrition & Dietetics. 2004;61:215-220.
Toda Y, Kobayashi T. The usefulness of walking for preventing sarcopenia in dieting postmenopausal women complaining of knee pain. Annals of the New York Academy of Sciences. 2000;904:610-3. [pmid: 10865813].
Tolppanen AM, Pulkkinen L, Kolehmainen M, et al. Tenomodulin is associated with obesity and diabetes risk: The Finnish Diabetes Prevention Study. Obesity. 2007;15(5):1082-8. [pmid: 17495183].
Tranter PJ. Speed kills: the complex links between transport, lack of time and urban health. J Urban Health. 2010;87:155-66. [pmid: 20180154].
Troped PJ, Tamura K, Whitcomb HA, et al. Perceived built environment and physical activity in U.S. women by sprawl and region. Am. J. Prev Med. 2011;41:473-79. [pmid: 22011417].
Troumbley Patricia F, Lenz Elizabeth R. Application of Cox's Interaction Model of Client Health Behavior in a weight control program for military personnel: A preintervention baseline. Advances in Nursing Science. 92(14):65-78.
Trueman P, Haynes SM, Felicity Lyons G, Louise McCombie E, McQuigg MS, Mongia S, Noble PA, Quinn MF, Ross HM, Thompson F, Broom JI, Laws RA, Reckless JP, Kumar S, Lean ME, Frost GS, Finer N, Haslam DW, Morrison D, Sloan B. Long-term cost-effectiveness of weight management in primary care. Int J Clin Pract. 2010;64:775-83. [pmid: 20353431].
Truong K, Fernandes M, An R, Shier V, Sturm R. Measuring the physical food environment and its relationship with obesity: evidence from California. Public Health. 2010;124:115-8. [pmid: 20167339].
Tse MM, Benzie IF. Dietary-related profile of older persons in the Chinese community: an exploratory study. J Nutr Health Aging. 2008;12:163-7. [pmid: 18309435].
Tucker LA, Bagwell M. Relationship between serum cholesterol levels and television viewing in 11,947 employed adults. Am J Health Promot. 92(6):437-42.
Tylavsky FA, Smith K, Surprise H, Garland S, Yan X, McCammon E, Hudson MM, Pui CH, Kaste SC. Nutritional intake of long-term survivors of childhood acute lymphoblastic leukemia: evidence for bone health interventional opportunities. Pediatr Blood Cancer. 2010;55:1362-9. [pmid: 20981691].
UK Prospective Diabetes Study (UKPDS). VIII. Study design, progress and performance. Diabetologia. 91(34):877-90.
Vallance JKH, Courneya KS, Jones LW, Reiman T. Exercise preferences among a population-based sample of non-Hodgkin's lymphoma survivors. European Journal of Cancer Care. 2006;15:34-43. [pmid: 16441675].
Vallis M, Ruggiero L, Greene G, Jones H, Zinman B, Rossi S, Edwards L, Rossi JS, Prochaska JO. Stages of change for healthy eating in diabetes: relation to demographic, eating-related, health care utilization, and psychosocial factors. Diabetes Care. 2003;26:1468-1474. [pmid: 12716806].
Van Baal PHM, Van Den Berg M, Hoogenveen RT, Vijgen SMC, Engelfriet PM. Cost-effectiveness of a low-calorie diet and orlistat for obese persons: Modeling long-term health gains through prevention of obesity-related chronic diseases. Value Health. 2008;11:1033-1040. [pmid: 18494748].
van Beurden E, James R, Montague D, Christian J, Dunn T. Community-based cholesterol screening and education to prevent heart disease: five-year results of the North Coast Cholesterol Check Campaign. Aust J Public Health. 93(17):109-16.
Van Den Ham ECH, Kooman JP, Christiaans MHL, Van Hooff JP. Relation between steroid dose, body composition and physical activity in renal transplant patients. Transplantation. 2000;69:1591-1598. [pmid: 10836368].
Van Rompay MI, McKeown NM, Castaneda-Sceppa C, et al. Acculturation and Sociocultural Influences on Dietary Intake and Health Status among Puerto Rican Adults in Massachusetts. J Acad Nutr Diet. 2012;112:64-74. [pmid: 22389874].
Vaz de Almeida MD, Graca P, Afonso C, D'Amicis A, Lappalainen R, Damkjaer S. Physical activity levels and body weight in a nationally representative sample in the European Union. Public Health Nutr. 99(2):105-13.
Venti CA, Votruba SB, Franks PW, Krakoff J, Salbe AD. Reproducibility of ad libitum energy intake with the use of a computerized vending machine system. Am J Clin Nutr. 2010;91:343-8. [pmid: 19923376].
Verheijden Marieke W, Jans Marielle P, Hildebrandt Vincent H, Hopman-Rock Marijke. Rates and determinants of repeated participation in web-based behavior change program for healthy body weight and healthy lifestyle. Journal of Medical Internet Research. 2007;9:1-7.
Verweij LM, Proper KI, Weel AN, Hulshof CT, van Mechelen W. Design of the Balance@Work project: systematic development, evaluation and implementation of an occupational health guideline aimed at the prevention of weight gain among employees. BMC Public Health. 2009;9:461. [pmid: 20003405].
Vincent D, Pasvogel A, Barrera L. A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biol Res Nurs. 2007;9:130-41. [pmid: 17909165].
Vincent D. Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. J Am Acad Nurse Pract. 2009;21:520-7. [pmid: 19845810].
Vincent Deborah. Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. Journal of the American Academy of Nurse Practitioners. 2009;21:520-527. [pmid: 19845810].
von Bothmer Margareta IK, Fridlund Bengt. Gender differences in health habits and in motivation for a healthy lifestyle among Swedish university students. Nursing & Health Sciences. 2005;7:107-118. [pmid: 15877687].
Von MacKensen S, Eifrig B, Zaech D, et al. Benefits of a specific aqua-training for adult haemophilia patients - Results of the longitudinal watercise study (WAT-QOL). J Thromb Haemost. 2011;9:924-5.
von Thiele Schwarz U, Lindfors P, Lundberg U. Health-related effects of worksite interventions involving physical exercise and reduced workhours. Scandinavian journal of work, environment & health. 2008;34:179-88.
Wadden TA, Vogt RA, Andersen RE, Bartlett SJ, Foster GD, Kuehnel RH, Wilk J, Weinstock R, Buckenmeyer P, Berkowitz RI, Steen SN. Exercise in the treatment of obesity: effects of four interventions on body composition, resting energy expenditure, appetite, and mood. Journal of consulting and clinical psychology. 97(65):269-77.
Walker EA, Stevens KA, Persaud S. Promoting diabetes self-management among African Americans: an educational intervention. J Health Care Poor Underserved. 2010;21:169-86. [pmid: 20675953].
Walsh JR, White AA, Greaney ML. Using focus groups to identify factors affecting healthy weight maintenance in college men. Nutr Res. 2009;29:371-8. [pmid: 19628102].
Wammes B, Breedveld B, Looman C, Brug J. The impact of a national mass media campaign in The Netherlands on the prevention of weight gain. Public Health Nutr. 2005;8:1250-7. [pmid: 16372920].
Wammes B, Oenema A, Brug J. The evaluation of a mass media campaign aimed at weight gain prevention among young Dutch adults. Obesity (Silver Spring). 2007;15:2780-9. [pmid: 18070769].
Wang A, Kinsinger LS, Kahwati LC, Das SR, Gizlice Z, Harvey RT, Burdick MB, Yevich SJ. Obesity and weight control practices in 2000 among veterans using VA facilities. Obes Res. 2005;13:1405-11. [pmid: 16129723].
Wang Feifei, McDonald Tim, Reffitt Bonnie, Edington Dee W. BMI, Physical Activity, and Health Care Utilization/Costs among Medicare Retirees. Obesity Research. 2005;13:1450-1457. [pmid: 16129728].
Wanner M, Martin-Diener E, Braun-Fahrländer C. Effectiveness of active-online, an individually tailored physical activity intervention, in a real-life setting: randomized controlled trial. Journal of medical Internet research. 2009;11:23.
Wardle J, Griffith J. Socioeconomic status and weight control practices in British adults. Journal of Epidemiology & Community Health. 2001;55:185-190. [pmid: 11160173].
Wardle J, Rapoport L, Miles A, Afuape T, Duman M. Mass education for obesity prevention: the penetration of the BBC's ‘Fighting Fat, Fighting Fit’ campaign. Health Educ Res. 2001;16:343-55. [pmid: 11497117].
Washburn RA, Donnelly JE, Smith BK, et al. Resistance training volume, energy balance and weight management: Rationale and design of a 9month trial. Contemp Clin Trials. 2012;33:749-58. [pmid: 22446169].
Washburn RA, Donnelly JE, Smith BK, et al. Resistance training volume, energy balance and weight management: Rationale and design of a 9month trial. Contemp Clin Trials. 2012;33:749-58. [pmid: 22446169].
Weaver JBI, Mays D, Sargent Weaver S, et al. Health-risk correlates of video-game playing among adults. American Journal of Preventive Medicine. 2009;37(4):299-305. [pmid: 19765501].
Weidinger KA, Lovegreen SL, Elliott MB, Hagood L, Haire-Joshu D, McGill JB, Brownson RC. How to make exercise counseling more effective: lessons from rural America. J Fam Pract. 2008;57:394-402. [pmid: 18544323].
Weinstock RS, Brooks G, Palmas W, et al. Lessened decline in physical activity and impairment of older adults with diabetes with telemedicine and pedometer use: results from the IDEA Tel study. Age Ageing. 2011;40:98-105. [pmid: 21081539].
Weiss EC, Galuska DA, Khan LK, Serdula MK. Weight-control practices among U.S. adults, 2001-2002. Am J Prev Med. 2006;31:18-24. [pmid: 16777538].
Wen Li Ming, Rissel Chris. Inverse associations between cycling to work, public transport, and overweight and obesity: Findings from a population based study in Australia. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;46:29-32.
Wengreen HJ, Moncur C. Change in diet, physical activity, and body weight among young-adults during the transition from high school to college. Nutr J. 2009;8:32. [pmid: 19624820].
Werkman A, Schuit AJ, Kwak L, Kremers SP, Visscher TL, Kok FJ, Schouten EG. Study protocol of a cluster randomised controlled trial investigating the effectiveness of a tailored energy balance programme for recent retirees. BMC Public Health. 2006;6:293. [pmid: 17147832].
Whitt-Glover Melicia C, Taylor Wendell C, Heath Gregory W, Macera Caroline A. Self-reported physical activity among Blacks: Estimates from national surveys. American Journal of Preventive Medicine. 2007;33:412-417. [pmid: 17950407].
Wilcox S, Dowda M, Wegley S, Ory MG. Maintenance of change in the Active-for-Life initiative. Am J Prev Med. 2009;37:501-4. [pmid: 19944915].
Will Julie C, Farris Rosanne P, Sanders Charlene G, Stockmyer Chrisandra K, Finkelstein Eric A. Health Promotion Interventions for Disadvantaged Women: Overview of the WISEWOMAN Projects. Journal of Women's Health. 2004;13:484-502.
Williams PT. Attenuating effect of vigorous physical activity on the risk for inherited obesity: a study of 47,691 runners. PLoS One. 2012;7:e31436. [pmid: 22384023].
Williams PT. Exercise attenuates the association of body weight with diet in 106,737 runners. Med Sci Sports Exerc. 2011;43:2120-6. [pmid: 21502899].
Williams Andrew E, Vogt Thomas M, Stevens Victor J, Albright Cheryl A, Nigg Claudia R, Meenan Richard T, Finucane Melissa L. Work, weight, and wellness: The 3W program: A worksite obesity prevention and intervention trial. Obesity. 2007;15:16S-26S. [pmid: 18073338].
Williams K, Prevost AT, Griffin S, Hardeman W, Hollingworth W, Spiegelhalter D, Sutton S, Ekelund U, Wareham N, Kinmonth AL. The ProActive trial protocol - a randomised controlled trial of the efficacy of a family-based, domiciliary intervention programme to increase physical activity among individuals at high risk of diabetes. BMC Public Health. 2004;4:48. [pmid: 15491494].
Williams PT. Evidence for the incompatibility of age-neutral overweight and age-neutral physical activity standards from runners. Am J Clin Nutr. 97(65):1391-6.
Williams PT. Evidence for the incompatibility of age-neutral overweight and age-neutral physical activity standards from runners. American Journal of Clinical Nutrition. 97(65):1391-1396.
Wilson DK, Trumpeter NN, St George SM, Coulon SM, Griffin S, Lee Van Horn M, Lawman HG, Wandersman A, Egan B, Forthofer M, Goodlett BD, Kitzman-Ulrich H, Gadson B. An overview of the “Positive Action for Today's Health” (PATH) trial for increasing walking in low income, ethnic minority communities. Contemp Clin Trials. 2010;31:624-33. [pmid: 20801233].
Wing RR, Matthews KA, Kuller LH, Smith D, Becker D, Plantinga PL, Meilahn EN. Environmental and familial contributions to insulin levels and change in insulin levels in middle-aged women. JAMA. 92(268):1890-5.
Winningham ML, MacVicar MG, Bondoc M, Anderson JI, Minton JP. Effect of aerobic exercise on body weight and composition in patients with breast cancer on adjuvant chemotherapy. Oncol Nurs Forum. 89(16):683-9.
Witte F. A clarification about normal body weight. Dtsch Med Wochenschr. Suppl 1. 2006:30-2. [pmid: 17595815].
Witten K, Hiscock R, Pearce J, Blakely T. Neighbourhood access to open spaces and the physical activity of residents: a national study. Prev Med. 2008;47:299-303. [pmid: 18533242].
Wood D, Kotseva K, Connolly S, Jennings C, Mead A, Jones J, Holden A, De Bacquer D, Collier T, De Backer G, Faergeman O. Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999-2012. [pmid: 18555911].
Wood MD, Fairlie AM, Fernandez AC, Borsari B, Capone C, Laforge R, Carmona-Barros R. Brief motivational and parent interventions for college students: a randomized factorial study. Journal of consulting and clinical psychology. 2010;78:349-61. [pmid: 20515210].
Yen Steven T, Chen Zhuo, Eastwood David B. Lifestyles, demographics, dietary behavior, and obesity: A switching regression analysis. Health Services Research. 2009;44:1345-1369. [pmid: 19490158].
York-Crowe Emily E, White Marney A, Paeratakul Sahasporn, Williamson Donald A. The diet and health knowledge survey: Development of a short interview format. Eating Behaviors. 2006;7:235-242. [pmid: 16843226].
YOUNG CM, RINGLER I, GREER BJ. Reducing and post-reducing maintenance on the moderate-fat diet; metabolic studies. J Am Diet Assoc. 53(29):890-6.
Zapka JM, Lemon SC, Magner RP, Hale J. Lifestyle behaviours and weight among hospital-based nurses. J Nurs Manag. 2009;17:853-60. [pmid: 19793242].
Zemel MB, Shi H, Greer B, Dirienzo D, Zemel PC. Regulation of adiposity by dietary calcium. FASEB J. 2000;14:1132-8. [pmid: 10834935].
Zhang Qi, Wang Youfa. Trends in the Association between Obesity and Socioeconomic Status in U.S. Adults: 1971 to 2000. Obesity Research. 2004;12:1622-1632. [pmid: 15536226].
Zhao G, Ford ES, Li C, Balluz LS. Physical activity in U.S. older adults with diabetes mellitus: prevalence and correlates of meeting physical activity recommendations. J Am Geriatr Soc. 2011;59:132-7. [pmid: 21226683].
Zick CD, Smith KR, Fan JX, Brown BB, Yamada I, Kowaleski-Jones L. Running to the store? The relationship between neighborhood environments and the risk of obesity. Soc Sci Med. 2009;69:1493-500. [pmid: 19766372].
Ziegler O, Filipecki J, Girod I, Guillemin F. Development and validation of a French obesity-specific quality of life questionnaire: Quality of Life, Obesity and Dietetics (QOLOD) rating scale. Diabetes Metab. 2005;31:273-83. [pmid: 16142018].
Zullo MD, Dolansky MA, Jackson LW. Cardiac rehabilitation, health behaviors, and body mass index post-myocardial infarction. J Cardiopulm Rehabil Prev. 2010;30:28-34. [pmid: 20068420].
Zunft HJ, Friebe D, Seppelt B, Widhalm K, Remaut de Winter AM, Vaz de Almeida MD, Kearney JM, Gibney M. Perceived benefits and barriers to physical activity in a nationally representative sample in the European Union. Public Health Nutr. 99(2):153-60.

## Goal of studies is weight loss or weight maintenance after weight loss

A new evidence-based model for weight management in primary care: the Counterweight Programme. Journal of Human Nutrition & Dietetics. 2004;17:191-208. [pmid: 15139891].
Ackermann RT, Finch EA, Brizendine E, Zhou H, Marrero DG. Translating the Diabetes Prevention Program into the community. The DEPLOY Pilot Study. American journal of preventive medicine. 2008;35:357-63. [pmid: 18779029].
Ahern AL, Olson AD, Aston LM, Jebb SA. Weight Watchers on prescription: An observational study of weight change among adults referred to Weight Watchers by the NHS. BMC Public Health. 2011;11:434. [pmid: 21645343].
Andersen RE, Wadden TA, Bartlett SJ, Zemel B, Verde TJ, Franckowiak SC. Effects of lifestyle activity vs structured aerobic exercise in obese women: a randomized trial. JAMA. 99(281):335-40.
Andersson J, Boman K, Jansson JH, Nilsson TK, Lindahl B. Effect of intensive lifestyle intervention on C-reactive protein in subjects with impaired glucose tolerance and obesity. Results from a randomized controlled trial with 5-year follow-up. Biomarkers. 2008;13:671-9. [pmid: 19096961].
Ash S, Reeves M, Bauer J, Dover T, Vivanti A, Leong C, O'Moore Sullivan T, Capra S. A randomised control trial comparing lifestyle groups, individual counselling and written information in the management of weight and health outcomes over 12 months. Int J Obes (Lond). 2006;30:1557-64. [pmid: 16534529].
Atkinson RL, Russ CS, Ciavarella PA, Owsley ES, Bibbs ML. A comprehensive approach to outpatient obesity management. J Am Diet Assoc. 84(84):439-44. [pmid: 6707401].
Azadbakht L, Mirmiran P, Esmaillzadeh A, Azizi F. Better dietary adherence and weight maintenance achieved by a long-term moderate-fat diet. Br J Nutr. 2007;97:399-404. [pmid: 17298711].
Balducci S, Zanuso S, Massarini M, Corigliano G, Nicolucci A, Missori S, Cavallo S, Cardelli P, Alessi E, Pugliese G, Fallucca F, Italian Diabetes Exercise Study (IDES) Group. The Italian Diabetes and Exercise Study (IDES): design and methods for a prospective Italian multicentre trial of intensive lifestyle intervention in people with type 2 diabetes and the metabolic syndrome. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2008;18:585-95.
Ball GD, Gingras JR, Fimrite A, Villetard K, Kayman S, McCargar LJ. Weight relapsers, maintainers, and controls: metabolic and behavioural differences. Can J Appl Physiol. 99(24):548-58.
Bartfield JK, Stevens VJ, Jerome GJ, Batch BC, Kennedy BM, Vollmer WM, Harsha D, Appel LJ, Desmond R, Ard JD. Behavioral Transitions and Weight Change Patterns Within the PREMIER Trial. Obesity (Silver Spring). 2011.
Bazzano Alicia T, Zeldin Ari S, Diab Ida R, Shihady, Garro Nicole M, Allevato Nathalia A, Lehrer Danise. The Healthy Lifestyle Change Program: A pilot of a community-based health promotion intervention for adults with developmental disabilities. American Journal of Preventive Medicine. 2009;37:S201-S208. [pmid: 19896020].
Behn S, Lane DS. A self-teaching weight-control manual: method for increasing compliance and reducing obesity. Patient Education and Counseling. 83(5):63-7.
Bergström I, Lombardo C, Brinck J. Physical training decreases waist circumference in postmenopausal borderline overweight women. Acta Obstetricia Et Gynecologica Scandinavica. 2009;88(3):308-13. [pmid: 19165639].
Birketvedt GS, Aaseth J, Florholmen JR, Ryttig K. Long-term effect of fibre supplement and reduced energy intake on body weight and blood lipids in overweight subjects. Acta Medica (Hradec Kralove). 2000;43:129-32. [pmid: 11294130].
Black DR. A minimal intervention program and a problem-solving program for weight control. Cognitive-Therapy-and-Research. 87(11):107-20.
Bleich SN, Wang YC, Wang Y, Gortmaker SL. Increasing consumption of sugar-sweetened beverages among US adults: 1988-1994 to 1999-2004. American Journal of Clinical Nutrition. 2009;89:372-381. [pmid: 19056548].
Bolocofsky DN, Coulthard-Morrris L, Spinler D. Prediction of successful weight management from personality and demographic data. Psychol Rep. 84(55):795-802.
Boutelle KN, Kirschenbaum DS, Baker RC, Mitchell ME. How can obese weight controllers minimize weight gain during the high risk holiday season? By self-monitoring very consistently. Health Psychol. 99(18):364-8.
Braun B, Parker D, Harvey L, Bissen J, Melko C, Xi M. Arthritis-friendly adaptations for weight management and physical activity promotion: Two 12-month interventions. American Public Health Association 134th Annual Meeting & Exposition. Nov 4 2006. Boston,MA. 2006.
Brehm BJ, Lattin BL, Summer SS, Boback JA, Gilchrist GM, Jandacek RJ, D'Alessio DA. One-year comparison of a high-monounsaturated fat diet with a high-carbohydrate diet in type 2 diabetes. Diabetes care. 2009;32:215-20. [pmid: 18957534].
Brestrich M, Claus J, Blümchen G. Lactovegetarian diet: effect on changes in body weight, lipid status, fibrinogen and lipoprotein (a) in cardiovascular patients during inpatient rehabilitation treatment. Zeitschrift Für Kardiologie. 1996;85(6):418-27. [pmid: 8767366].
Brinkworth GD, Noakes M, Keogh JB, Luscombe ND, Wittert GA, Clifton PM. Long-term effects of a high-protein, low-carbohydrate diet on weight control and cardiovascular risk markers in obese hyperinsulinemic subjects. Int J Obes Relat Metab Disord. 2004;28:661-70. [pmid: 15007396].
Burani J, Longo PJ. Low-glycemic index carbohydrates: an effective behavioral change for glycemic control and weight management in patients with type 1 and 2 diabetes. Diabetes Educ. 2006;32:78-88. [pmid: 16439496].
Burke V, Beilin L, Cutt H, Mansour J, Williams A, Mori T. A lifestyle program for treated hypertensives improves cardiovascular risk factors: A randomized controlled trial. Journal. 2006;7:386.
Burke V, Mori TA, Giangiulio N, Gillam HF, Beilin LJ, Houghton S, Cutt HE, Mansour J, Wilson A. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. Suppl 3. 2002;11:S586-97. [pmid: 12492652].
Burnett Kent F, Taylor C Barr, Agras W Stewart. Ambulatory computer-assisted behavior therapy for obesity: An empirical model for examining behavioral correlates of treatment outcome. Computers in Human Behavior. 92(8):239-248.
Campbell PT, Campbell KL, Wener MH, Wood BL, Potter JD, McTiernan A, Ulrich CM. A yearlong exercise intervention decreases CRP among obese postmenopausal women. Medicine and science in sports and exercise. 2009;41:1533-9. [pmid: 19568208].
Carels Robert A, Douglass Olivia M, Cacciapaglia Holly M, O'Brien William H. An Ecological Momentary Assessment of Relapse Crises in Dieting. Journal of Consulting and Clinical Psychology. 2004;72:341-348. [pmid: 15065966].
Carraca EV, Silva MN, Markland D, et al. Body image change and improved eating self-regulation in a weight management intervention in women. Int J Behav Nutr Phys Act. 2011;8:75. [pmid: 21767360].
Carrier KM, Steinhardt MA, Bowman S. Rethinking traditional weight management programs: a 3-year follow-up evaluation of a new approach. J Psychol. 94(128):517-35.
Chapman Melanie J, Craven Michael J, Chadwick Darren D. Following up Fighting Fit: The long-term impact of health practitioner input on obesity and BMI amongst adults with intellectual disabilities. Journal of Intellectual Disabilities. 2008;12:309-323. [pmid: 19074936].
Chen SY, Chang YH, Hsu HC, et al. One-year efficacy and safety of the telehealth system in poorly controlled type 2 diabetic patients receiving insulin therapy. Telemed J E Health. 2011;17:683-7. [pmid: 21882998].
Clark D, Chrysler L, Perkins A, Keith NR, Willis DR, Abernathy G, Smith F. Screening, referral, and participation in a weight management program implemented in five CHCs. J Health Care Poor Underserved. 2010;21:617-28. [pmid: 20453361].
Collins E, O'Connell S, Jelinek C, Miskevics S, Budiman-Mak E. Evaluation of psychometric properties of Walking Impairment Questionnaire in overweight patients with osteoarthritis of knee. Journal of Rehabilitation Research & Development. 2008;45:559-566. [pmid: 18712641].
Cormier A. Group versus individual dietary instruction in the treatment of obesity. Canadian Journal of Public Health. Revue Canadienne De Santé Publique. 1972;63(4):327-32. [pmid: 5070724].
Cowart LW, Biro DJ, Wasserman T, Stein RF, Reider LR, Brown B. Designing and pilot-testing a church-based community program to reduce obesity among African Americans. ABNF J. 2010;21:4-10. [pmid: 20169806].
Cox TL, Malpede CZ, Desmond RA, Faulk LE, Myer RA, Henson CS, Heimburger DC, Ard JD. Physical activity patterns during weight maintenance following a low-energy density dietary intervention. Obesity (Silver Spring). 2007;15:1226-32. [pmid: 17495199].
Czernichow S, Mennen L, Bertrais S, Preziosi P, Hercberg S, Oppert JM. Relationships between changes in weight and changes in cardiovascular risk factors in middle-aged French subjects: effect of dieting. Int J Obes Relat Metab Disord. 2002;26:1138-43. [pmid: 12119581].
Dahn JR, Fitzpatrick SL, Llabre MM, Apterbach GS, Helms RL, Cugnetto ML, Klaus J, Florez H, Lawler T. Weight Management for Veterans: Examining Change in Weight Before and After MOVE!. Obesity (Silver Spring). 2011;19:977-81. [pmid: 21127474].
Dallow CB, Anderson J. Using self-efficacy and a transtheoretical model to develop a physical activity intervention for obese women. American journal of health promotion : AJHP. 2003;17:373-81. [pmid: 12858617].
Delahanty LM, Meigs JB, Hayden D, Williamson DA, Nathan DM. Psychological and behavioral correlates of baseline BMI in the Diabetes Prevention Program (DPP). Diabetes Care. 2002;25:1992-1998. [pmid: 12401745].
DiBonaventura MD, Chapman GB. The effect of barrier underestimation on weight management and exercise change. Psychol. Health Med. 2008;13:111-122. [pmid: 18066924].
DiBonaventura MC, Chapman GB. The effect of barrier underestimation on weight management and exercise change. Psychology, Health & Medicine. 2008;13:111-122.
Donini ML, Savina C, Castellaneta E, Coletti C, Paolini M, Scavone L, Civale C, Ceccarelli P, Zaninotto S, Tineri M, Grossi G, De Felice MR, Cannella C. Multidisciplinary approach to obesity. Eating and Weight Disorders. 2009;14:23-32. [pmid: 19367137].
Donnelly JE, Jacobsen DJ, Heelan KS, Seip R, Smith S. The effects of 18 months of intermittent vs. continuous exercise on aerobic capacity, body weight and composition, and metabolic fitness in previously sedentary, moderately obese females. Int J Obes Relat Metab Disord. 2000;24:566-72. [pmid: 10849577].
Doucet E, Tremblay A. Body weight loss and maintenance with physical activity and diet. Coron Artery Dis. 98(9):495-501.
Eight-year follow-up results from the Rome Project of Coronary Heart Disease Prevention. Research Group of the Rome Project of Coronary Heart Disease Prevention. Preventive medicine. 86(15):176-91.
Ekelund U, Besson H, Luan J, et al. Physical activity and gain in abdominal adiposity and body weight: prospective cohort study in 288,498 men and women. Am J Clin Nutr. 2011;93:826-35. [pmid: 21346093].
Elbel Russ, Aldana Steve, Bloswick Don, Lyon Joseph L. A pilot study evaluating a peer led and professional led physical activity intervention with blue-collar employees. Work: Journal of Prevention, Assessment & Rehabilitation. 2003;21:199-210.
Epstein LH, Gordy CC, Raynor HA, Beddome M, Kilanowski CK, Paluch R. Increasing fruit and vegetable intake and decreasing fat and sugar intake in families at risk for childhood obesity. Obesity research. 2001;9:171-8. [pmid: 11323442].
Epstein LH, Wing RR, Koeske R, Valoski A. Effects of diet plus exercise on weight change in parents and children. J CONSULT CLIN PSYCHOL. 84(52):429-437.
Epstein Leonard H, Wing Rena R, Koeske Randi, Valoski Alice. Effects of diet plus exercise on weight change in parents and children. Journal of Consulting and Clinical Psychology. 84(52):429-437.
Erfurt JC, Foote A, Heirich MA. Worksite wellness programs: incremental comparison of screening and referral alone, health education, follow-up counseling, and plant organization. American Journal of Health Promotion. 91(5):438-448.
Fanaian M, Laws RA, Passey M, McKenzie S, Wan Q, Davies GP, Lyle D, Harris MF. Health improvement and prevention study (HIPS) - evaluation of an intervention to prevent vascular disease in general practice. BMC family practice. 2010;11:57. [pmid: 20687956].
Finkelstein B, Fryer BA. Meal frequency and weight reduction of young women. The American journal of clinical nutrition. 71(24):465-8.
Finkelstein EA, Zhen C, Nonnemaker J, Todd JE. Impact of targeted beverage taxes on higher- and lower-income households. Arch Intern Med. 2010;170:2028-34. [pmid: 21149762].
Fitz JD, Sperling EM, Fein HG. A hypocaloric high-protein diet as primary therapy for adults with obesity-related diabetes: effective long-term use in a community hospital. Diabetes Care. 83(6):328-33.
Fontaine Kevin R, Cheskin Lawrence J. Optimism and obesity treatment outcomes. Journal of Clinical Psychology. 99(55):141-143.
Foreyt JP, Goodrick GK, Reeves RS, Raynaud AS, Darnell L, Brown AH, Gotto AM. Response of free-living adults to behavioral treatment of obesity: Attrition and compliance to exercise. BEHAV. THER. 93(24):659-669.
Foster GD, Wyatt HR, Hill JO, McGuckin BG, Brill C, Mohammed BS, Szapary PO, Rader DJ, Edman JS, Klein S. A randomized trial of a low-carbohydrate diet for obesity. The New England journal of medicine. 2003;348:2082-90. [pmid: 12761365].
Ghroubi S, Elleuch H, Chikh T, Kaffel N, Abid M, Elleuch MH. Physical training combined with dietary measures in the treatment of adult obesity. A comparison of two protocols. Annals of physical and rehabilitation medicine. 2009;52:394-413. [pmid: 19623684].
Gibbs HD, McQuigg M, Broom J, Brown J, Laws R, Reckless JPD, Noble PA, Kumar S, McCombie EL, Lean MEJ, Lyons GF, Frost GS, Quinn MF, Barth JH, Haynes SM, Finer N, Ross HM, Hole DJ, Montazeri A. A new evidence-based model for weight management in primary care: The counterweight programme. J. Hum. Nutr. Diet. 2004;17:191-208. [pmid: 15139891].
Gilbert S, Garrow JS. A prospective controlled trial of outpatient treatment for obesity. Human nutrition. Clinical nutrition. 83(37):21-9.
Goessens BM, Visseren FL, Sol BG, de Man-van Ginkel JM, van der Graaf Y. A randomized, controlled trial for risk factor reduction in patients with symptomatic vascular disease: the multidisciplinary Vascular Prevention by Nurses Study (VENUS). Eur J Cardiovasc Prev Rehabil. 2006;13:996-1003. [pmid: 17143135].
Goodrick GK, Poston WS 2nd, Kimball KT, Reeves RS, Foreyt JP. Nondieting versus dieting treatment for overweight binge-eating women. J Consult Clin Psychol. 98(66):363-8.
Goodwin P, Esplen MJ, Butler K, Winocur J, Pritchard K, Brazel S, Gao J, Miller A. Multidisciplinary weight management in locoregional breast cancer: results of a phase II study. Breast Cancer Res Treat. 98(48):53-64.
Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity. 2001;25:1154-60. [pmid: 11486790].
Goyenechea E, Holst C, Saris WH, Jebb S, Kafatos A, Pfeiffer A, Handjiev S, Hlavaty P, Stender S, Larsen TM, Astrup A, Martinez JA. Effects of different protein content and glycemic index of ad libitum diets on diabetes risk factors in overweight adults: the DIOGenes multicentre, randomised, dietary intervention trial. Diabetes Metab Res Rev. 2011.
Gurka MJ, Wolf AM, Conaway MR, Crowther JQ, Nadler JL, Bovbjerg VE. Lifestyle intervention in obese patients with type 2 diabetes: impact of the patient's educational background. Obesity (Silver Spring Md.). 2006;14:1085-92.
Hadden DR, Blair ALT, Wilson EA. Natural history of diabetes presenting age 40-69 years: A prospective study of the influence of intensive dietary therapy. Q. J. MED. 86(59):579-598.
Hallfrisch J, Drinkwater DT, Muller DC, Fleg J, Busby-Whitehead MJ, Andres R, Goldberg A. Physical conditioning status and diet intake in active and sedentary older men. NUTR. RES. 94(14):817-827.
Harati Hadi, Hadaegh Farzad, Momenan Amir Abbas, Ghanei Laleh, Bozorgmanesh Mohammad Reza, Ghanbarian Arash, Mirmiran Parvin, Azizi Fereidoun. Reduction in incidence of Type 2 diabetes by lifestyle intervention in a Middle Eastern community. American Journal of Preventive Medicine. 2010;38:628-636. [pmid: 20494239].
Harrison R, Stewart RDH. Trial of a powdered formula diet in treatment of obesity. Br Med J. 63(2):538-40.
Hauner H. Non-drug therapy of obesity. Herz. 2001;26:202-8. [pmid: 11413800].
Haupt E, Herrmann R, Benecke-Timp A, Vogel H, Hilgenfeldt J, Haupt A, Walter C. The KID Study. III: Impact of inpatient rehabilitation on the metabolic control of type I and type II diabetics--a one-year follow-up. Exp Clin Endocrinol Diabetes. 96(104):420-30.
Hauptman J, Lucas C, Boldrin MN, Collins H, Segal KR. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9:160-7. [pmid: 10693734].
Haus G, Hoerr SL, Mavis B, Robison J. Key modifiable factors in weight maintenance: fat intake, exercise, and weight cycling. J Am Diet Assoc. 94(94):409-13. [pmid: 8144808].
Hersey JC, Khavjou O, Strange LB, et al. The efficacy and cost-effectiveness of a community weight management intervention: A randomized controlled trial of the health weight management demonstration. Prev Med. 2012;54:42-9. [pmid: 22001689].
Hertzman Peter. The Cost Effectiveness of Orlistat in a 1-Year Weight-Management Programme for Treating Overweight and Obese Patients in Sweden: A Treatment Responder Approach. PharmacoEconomics. 2005;23:1007-1020. [pmid: 16235974].
Hessert MJ, Gugliucci MR, Pierce HR. Functional fitness: Maintaining or improving function for elders with chronic diseases. Fam. Med. 2005;37:472-476. [pmid: 15988642].
Hey H, Petersen HD, Andersen T, Quaade F. Formula diet with a free additional food choice up to 1,000 kcal (4,2 MJ) compared with an isoenergetic conventional diet in the treatment of obesity. A randomized clinical trial. Ugeskrift for laeger. 86(148):2741-4.
Hjerkinn EM, Sandvik L, Hjermann I, Arnesen H. Effect of diet intervention on long-term mortality in healthy middle-aged men with combined hyperlipidaemia. Journal of internal medicine. 2004;255:68-73. [pmid: 14687240].
Hood CE, Goodhart JM, Fletcher RF, Gloster J, Bertrand PV, Crooke AC. Observations on obese patients eating isocaloric reducing diets with varying proportions of carbohydrate. The British journal of nutrition. 70(24):39-44.
Hsieh C, Wang P, Liu R, Tung S, Chien W, Chen J, Chen C, Kuo M, Hu Y. Orlistat for obesity: benefits beyond weight loss. Diabetes Research & Clinical Practice. 2005;67:78-83. [pmid: 15620437].
Hughes MC, Girolami TM, Cheadle AD, Harris JR, Patrick DL. A lifestyle-based weight management program delivered to employees: examination of health and economic outcomes. J Occup Environ Med. 2007;49:1212-7. [pmid: 17993925].
Iso H, Shimamoto T, Yokota K, Sankai T, Jacobs DR, Komachi Y. Community-based education classes for hypertension control. A 1.5-year randomized controlled trial. Hypertension. 96(27):968-74.
Jackson C, Coe A, Cheater FM, Wroe S. Specialist health visitor-led weight management intervention in primary care: exploratory evaluation. Journal of Advanced Nursing. 2007;58:23-34. [pmid: 17394613].
Jackson M, Ball K, Crawford D. Beliefs about the causes of weight change in the Australian population. Int J Obes Relat Metab Disord. 2001;25:1512-6. [pmid: 11673774].
Jeffery RW, Forster JL, French SA, Kelder SH, Lando HA, McGovern PG, Jacobs DR, Baxter JE. The Healthy Worker Project: a work-site intervention for weight control and smoking cessation. American journal of public health. 93(83):395-401.
Jeffery RW, Gerber WM, Rosenthal BS, Lindquist RA. Monetary contracts in weight control: effectiveness of group and individual contracts of varying size. Journal of consulting and clinical psychology. 83(51):242-8.
Jeffery Robert W, Forster Jean L, French Simone A, Kelder Steven H. The Healthy Worker Project: A work-site intervention for weight control and smoking cessation. American Journal of Public Health. 93(83):395-401.
Kalarchian MA, Marcus MD, Levine MD, Haas GL, Greeno CG, Weissfeld LA, Qin L. Behavioral treatment of obesity in patients taking antipsychotic medications. J Clin Psychiatry. 2005;66:1058-63. [pmid: 16086623].
Kalten MR, Ardito DA, Cimino C, Wylie-Rosett J. A Web-accessible core weight management program. Diabetes Educ. 2000;26:929-36. [pmid: 11912805].
Kalter-Leibovici O, Younis-Zeidan N, Atamna A, Lubin F, Alpert G, Chetrit A, Novikov I, Daoud N, Freedman LS. Lifestyle intervention in obese Arab women: a randomized controlled trial. Archives of Internal Medicine. 2010;170:970-976. [pmid: 20548010].
Kaufman H, Overton G, Leggott J, Clericuzio C. Prader-Willi syndrome: effect of group home placement on obese patients with diabetes. South Med J. 95(88):182-4.
Kellow N. Evaluation of a rural community pharmacy-based Waist Management Project: Bringing the program to the people. Aust. J. Prim. Health. 2011;17:16-22. [pmid: 21616019].
Kew MC. Treatment of obesity in the Bantu: value of a low-carbohydrate diet with and without an appetite suppressant. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde. 70(44):1006-7.
Kirschenbaum Daniel S, Rosengarten Gary G. Meta-monitoring: Case illustrations of a potential 'slump-buster' for self-regulatory problems. Journal of Clinical Psychology in Medical Settings. 94(1):245-254.
Klemsdal TO, Holme I, Nerland H, Pedersen TR, Tonstad S. Effects of a low glycemic load diet versus a low-fat diet in subjects with and without the metabolic syndrome. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2010;20:195-201.
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67:152-62. [pmid: 15649575].
Krummel D, Semmens E, MacBride AM, Fisher B. Lessons learned from the mothers' overweight management study in 4 West Virginia WIC offices. J Nutr Educ Behav. 2010;42:S52-8. [pmid: 20399410].
Kulzer B, Hermanns N, Gorges D, Schwarz P, Haak T. Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32:1143-6. [pmid: 19509014].
Lapointe A, Weisnagel SJ, Provencher V, Begin C, Dufour-Bouchard AA, Trudeau C, Lemieux S. Comparison of a dietary intervention promoting high intakes of fruits and vegetables with a low-fat approach: long-term effects on dietary intakes, eating behaviours and body weight in postmenopausal women. Br J Nutr. 2010;104:1080-90. [pmid: 20482930].
Larsen RN, Mann NJ, Maclean E, Shaw JE. The effect of high-protein, low-carbohydrate diets in the treatment of type 2 diabetes: a 12 month randomised controlled trial. Diabetologia. 2011;54:731-40. [pmid: 21246185].
Laws R, Counterweight Project Team. A new evidence-based model for weight management in primary care: the Counterweight Programme. Journal of human nutrition and dietetics : the official journal of the British Dietetic Association. 2004;17:191-208. [pmid: 15139891].
Laws R. A new evidence-based model for weight management in primary care: the Counterweight Programme. J Hum Nutr Diet. 2004;17:191-208. [pmid: 15139891].
Lee PH, Chang WY, Liou TH, Chang PC. Stage of exercise and health-related quality of life among overweight and obese adults. J Adv Nurs. 2006;53:295-303. [pmid: 16441534].
Levy J, Atkinson AB, Bell PM, McCance DR, Hadden DR. Beta-cell deterioration determines the onset and rate of progression of secondary dietary failure in type 2 diabetes mellitus: The 10-year follow-up of the belfast diet study. Diabetic Med. 98(15):290-296.
Lillis Jason, Hayes Steven C. Measuring avoidance and inflexibility in weight related problems. International Journal of Behavioral Consultation and Therapy. 2008;4:348-354.
Lindgärde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. Journal of Internal Medicine. 2000;248(3):245-54. [pmid: 10971792].
Lindstrom J, Peltonen M, Eriksson JG, Aunola S, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Uusitupa M, Tuomilehto J. Determinants for the effectiveness of lifestyle intervention in the Finnish Diabetes Prevention Study. Diabetes Care. 2008;31:857-862. [pmid: 18252900].
Logue EE, Jarjoura DG, Sutton KS, Smucker WD, Baughman KR, Capers CF. Longitudinal relationship between elapsed time in the action stages of change and weight loss. Obes Res. 2004;12:1499-508. [pmid: 15483215].
Lomasky SJ, D'Eramo G, Shamoon H, Fleischer N. Relationship of insulin secretion and glycemic response to dietary intervention in non-insulin-dependent diabetes. Archives of internal medicine. 90(150):169-72.
London AM, Schreiber ED. A controlled study of the effects of group discussions and an anorexiant in outpatient treatment of obesity. With attention to the psychological aspects of dieting. Annals of internal medicine. 66(65):80-92.
Long CG, Simpson CM, Allott EA. Psychological and dietetic counselling combined in the treatment of obesity: a comparative study in a hospital outpatient clinic. Human nutrition. Applied nutrition. 83(37):94-102.
Look AHEAD Research Group, Wing RR. Long-term effects of a lifestyle intervention on weight and cardiovascular risk factors in individuals with type 2 diabetes mellitus: four-year results of the Look AHEAD trial. Archives of internal medicine. 2010;170:1566-75. [pmid: 20876408].
Lyles T 3rd, Desmond R, Faulk LE, Henson S, Hubbert K, Heimburger DC, Ard JD. Diet variety based on macronutrient intake and its relationship with body mass index. MedGenMed. 2006;8:39. [pmid: 17406172].
MacLaughlin HL, Cook SA, Kariyawasam D, Roseke M, van Niekerk M, Macdougall IC. Nonrandomized trial of weight loss with orlistat, nutrition education, diet, and exercise in obese patients with CKD: 2-year follow-up. Am J Kidney Dis. 2010;55:69-76. [pmid: 19926371].
Maddah M, Karandish M. Gender difference in obesity management among Iranian patients with metabolic syndrome. Int. J. Cardiol. 2011;148:109-110. [pmid: 21310499].
Madsen J, Sallis JF, Rupp JW, Senn KL, Patterson TL, Atkins CJ, Nader PR. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. Patient education and counseling. 93(21):61-9.
Mainie PM, Moore G, Riddell JW, Adgey AA. To examine the effectiveness of a hospital-based nurse-led secondary prevention clinic. Eur J Cardiovasc Nurs. 2005;4:308-13. [pmid: 15993647].
Marks BL, Ward A, Morris DH, Castellani J, Rippe JM. Fat-free mass is maintained in women following a moderate diet and exercise program. Med Sci Sports Exerc. 95(27):1243-51.
Marshall DA, Walizer EM, Vernalis MN. Achievement of heart health characteristics through participation in an intensive lifestyle change program (Coronary Artery Disease Reversal Study). J Cardiopulm Rehabil Prev. 2009;29:84-94. quiz 95-6. [pmid: 19305232].
Marsiaj HI, Catalano C, Sum CF, Home PD, Alberti KG. Management of newly diagnosed non-insulin-dependent (type 2) diabetes mellitus: a retrospective audit. Diabetes Res Clin Pract. 91(12):129-36.
Mata J, Todd PM, Lippke S. When weight management lasts. Lower perceived rule complexity increases adherence. Appetite. 2010;54:37-43. [pmid: 19751781].
Mattila E, Lappalainen R, Parkka J, Salminen J, Korhonen I. Use of a mobile phone diary for observing weight management and related behaviours. J. Telemed. Telecare. 2010;16:260-264. [pmid: 20483880].
McConnon +, Kirk SFL, Ransley JK. Process evaluation of an internet-based resource for weight control: Use and views of an obese sample. Journal of Nutrition Education and Behavior. 2009;41(4):261-7. [pmid: 19508931].
McDoniel SO, Nelson HA, Thomson CA. Employing RMR technology in a 90-day weight control program. Obes Facts. 2008;1:298-304. [pmid: 20054192].
McGuire MT, Wing RR, Klem ML, Hill JO. Behavioral strategies of individuals who have maintained long-term weight losses. Obes Res. 99(7):334-41.
McHugh J, Suggs LS. Online tailored weight management in the worksite: does it make a difference in biennial health risk assessment data?. J Health Commun. 2012;17:278-93. [pmid: 22188131].
McQuigg M, Brown J, Broom J, Laws RA, Reckless JP, Noble PA, Kumar S, McCombie EL, Lean ME, Lyons GF, Frost GS, Quinn MF, Barth JH, Haynes SM, Finer N, Ross HM, Hole DJ. Empowering primary care to tackle the obesity epidemic: the Counterweight Programme. Eur J Clin Nutr. Suppl 1. 2005;59:S93-100. discussion S101. [pmid: 16052202].
McTiernan A, Ulrich CM, Yancey D, Slate S, Nakamura H, Oestreicher N, Bowen D, Yasui Y, Potter J, Schwartz R. The Physical Activity for Total Health (PATH) Study: rationale and design. Medicine and science in sports and exercise. 99(31):1307-12.
McTigue Kathleen M, Conroy Molly B, Hess Rachel, Bryce Cindy L, Fiorillo Anthony B, Fischer Gary S, Milas N Carole, Simkin-Silverman Laurey R. Using the Internet to translate an evidence-based lifestyle intervention into practice. Telemedicine and e-Health. 2009;15:851-858. [pmid: 19919191].
Mekary RA, Willett WC, Hu FB, Ding EL. Isotemporal substitution paradigm for physical activity epidemiology and weight change. Am. J. Epidemiol. 2009;170:519-527. [pmid: 19584129].
Melamed Y, Stein-Reisner O, Gelkopf M, Levi G, Sivan T, Ilievici G, Rosenberg R, Weizman A, Bleich A. Multi-modal weight control intervention for people with persistent mental disorders. Psychiatr Rehabil J. 2008;31:194-200. [pmid: 18194946].
Melchionda N, Besteghi L, Di Domizio S, Pasqui F, Nuccitelli C, Migliorini S, Baraldi L, Natale S, Manini R, Bellini M, Belsito C, Forlani G, Marchesini G. Cognitive behavioural therapy for obesity: One-year follow-up in a clinical setting. Eating and Weight Disorders. 2003;8:188-193. [pmid: 14649781].
Mellin L, Croughan-Minihane M, Dickey L. The Solution Method: 2-year trends in weight, blood pressure, exercise, depression, and functioning of adults trained in development skills. J Am Diet Assoc. 97(97):1133-8. [pmid: 9336560].
Micco Nicci, Gold Beth, Buzzell Paul, Leonard Heather, Pintauro Stephen, Harvey-Berino Jean. Minimal In-Person Support as an Adjunct to Internet Obesity Treatment. Annals of Behavioral Medicine. 2007;33:49-56. [pmid: 17291170].
Miettinen TA, Huttunen JK, Naukkarinen V, Strandberg T, Mattila S, Kumlin T, Sarna S. Multifactorial primary prevention of cardiovascular diseases in middle-aged men Risk factor changes, incidence, and mortality. JAMA : the journal of the American Medical Association. 85(254):2097-102.
Miles JM, Leiter L, Hollander P, Wadden T, Anderson JW, Doyle M, Foreyt J, Aronne L, Klein S. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes care. 2002;25:1123-8. [pmid: 12087008].
Moczar C, Borda F, Farago K, Borgulya G, Braunitzer F, Voros V. Effect of change of life style for cardiovascular risk of overweight and obese population: Egeszseges eletmod hatasa tulsulyos es elhizott betegeken. Orvosi Hetil. 2007;148:65-69.
Mogul HR, Peterson SJ, Weinstein BI, Zhang S, Southren AL. Metformin and carbohydrate-modified diet: a novel obesity treatment protocol: preliminary findings from a case series of nondiabetic women with midlife weight gain and hyperinsulinemia. Heart Dis. 2001;3:285-92. [pmid: 11975807].
Molenaar EA, van Ameijden EJ, Vergouwe Y, Grobbee DE, Numans ME. Effect of nutritional counselling and nutritional plus exercise counselling in overweight adults: a randomized trial in multidisciplinary primary care practice. Family practice. 2010;27:143-50. [pmid: 20026554].
Moore H, Summerbell CD, Greenwood DC, Tovey P, Griffiths J, Henderson M, Hesketh K, Woolgar S, Adamson AJ. Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327:1085. [pmid: 14604931].
Moreno O, Meoro A, Martinez A, Rodriguez C, Pardo C, Aznar S, Lopez P, Serrano J, Boix E, Martin MD, Pico Alfonso AM. Comparison of two low-calorie diets: a prospective study of effectiveness and safety (Structured abstract). Journal of Endocrinological Investigation. 2006;29:633-640. [pmid: 16957412].
Munsch S, Biedert E, Keller U. Evaluation of a lifestyle change programme for the treatment of obesity in general practice. Swiss medical weekly. 2003;133:148-54. [pmid: 12707842].
Munsch Simone, Meyer Andrea H, Margraf Jürgen. Weight control with orlistat in a telephone-counseling program. Swiss Journal of Psychology/Schweizerische Zeitschrift für Psychologie/Revue Suisse de Psychologie. 2007;66:235-241.
Muto Takashi, Yamauchi Keita. Evaluation of a multicomponent workplace health promotion program conducted in Japan for improving employees' cardiovascular disease risk factors. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2001;33:571-577.
Ndetan H, Evans MW Jr, Felini M, Bae S, Rupert R, Singh KP. Chiropractic and medical use of health promotion in the management of arthritis: analysis of the 2006 National Health Interview Survey. J Manipulative Physiol Ther. 2010;33:419-24. [pmid: 20732578].
Neubeck L, Freedman SB, Briffa T, et al. Four-year follow-up of the Choice of Health Options In prevention of Cardiovascular Events randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2011;18:278-86. [pmid: 20606594].
Niebauer J, Hambrecht R, Schlierf G, et al. Five years of physical exercise and low fat diet: effects on progression of coronary artery disease. Journal of Cardiopulmonary Rehabilitation. 1995;15(1):47-64. [pmid: 8529087].
Nielsen JV, Joensson EA. Low-carbohydrate diet in type 2 diabetes: stable improvement of bodyweight and glycemic control during 44 months follow-up. Nutr Metab (Lond). 2008;5:14. [pmid: 18495047].
Nilsson Peter M, Klasson Eva-Birgitta, Nyberg Per. Life-style intervention at the worksite--reduction of cardiovascular risk factors in a randomized study. Scandinavian Journal of Work, Environment & Health. 2001;27:57-62.
Nunn RG, Newton KS, Faucher P. 2.5 years follow-up of weight and Body Mass Index values in the Weight Control for Life! program: a descriptive analysis. Addict Behav. 92(17):579-85.
Nybacka A, Carlstrom K, Stahle A, et al. Randomized comparison of the influence of dietary management and/or physical exercise on ovarian function and metabolic parameters in overweight women with polycystic ovary syndrome. Fertil Steril. 2011;96:1508-13. [pmid: 21962963].
Obarzanek E, Vollmer WM, Lin PH, Cooper LS, Young DR, Ard JD, Stevens VJ, Simons-Morton DG, Svetkey LP, Harsha DW, Elmer PJ, Appel LJ. Effects of individual components of multiple behavior changes: the PREMIER trial. American journal of health behavior. 2007;31:545-60. [pmid: 17555385].
O'Meara S, Glenny AM, Wilson C, Melville A, Sheldon TA. Effective management of obesity. Qual Health Care. 97(6):170-5.
Ovbiosa-Akinbosoye OE, Long DA. Factors associated with long-term weight loss and weight maintenance: Analysis of a comprehensive workplace wellness program. J Occup Environ Med. 2011;53:1236-42. [pmid: 22005396].
Park HA, Lee JS, Kuller LH, Cauley JA. Effects of weight control during the menopausal transition on bone mineral density. J Clin Endocrinol Metab. 2007;92:3809-15. [pmid: 17635939].
Parra-Medina D, Wilcox S, Wilson DK, Addy CL, Felton G, Poston MB. Heart Healthy and Ethnically Relevant (HHER) Lifestyle trial for improving diet and physical activity in underserved African American women. Contemporary clinical trials. 2010;31:92-104. [pmid: 19781665].
Patella MN, Ghiotto C, Pertile R, Fiduccia P, Bozza F, Pluchinotta A, Zanetti L, Zavagno G, Cavestro M, Fedele D. Effects of a nutritional intervention in overweight/obese breast cancer patients. Mediterr. J. Nutr. Metab. 2009;2:21-28.
Pavlou KN, Krey S, Steffee WP. Exercise as an adjunct to weight loss and maintenance in moderately obese subjects. Am J Clin Nutr. 89(49):1115-23.
Pavlou KN, Steffee WP, Lerman RH, Burrows BA. Effects of dieting and exercise on lean body mass, oxygen uptake, and strength. Medicine and science in sports and exercise. 85(17):466-71.
Payne WR, Walsh KJ, Harvey JT, Livy MF, McKenzie KJ, Donaldson A, Atkinson MG, Keogh JB, Moss RS, Dunstan DW, Hubbard WA. Effect of a low-resource-intensive lifestyle modification program incorporating gymnasium-based and home-based resistance training on type 2 diabetes risk in australian adults. Diabetes Care. 2008;31:2244-2250. [pmid: 18796621].
Perri MG, McAdoo WG, McAllister DA, Lauer JB, Yancey DZ. Enhancing the efficacy of behavior therapy for obesity: effects of aerobic exercise and a multicomponent maintenance program. J Consult Clin Psychol. 86(54):670-5.
Perri MG, McAllister DA, Gange JJ, Jordan RC, McAdoo G, Nezu AM. Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 88(56):529-34.
Perri MG, Shapiro RM, Ludwig WW, Twentyman CT, McAdoo WG. Maintenance strategies for the treatment of obesity: an evaluation of relapse prevention training and posttreatment contact by mail and telephone. J Consult Clin Psychol. 84(52):404-13.
Perri Michael G, Nezu Arthur M, McKelvey Wendy F, Shermer Rebecca L, Renjilian David A, Viegener Barbara J. Relapse prevention training and problem-solving therapy in the long-term management of obesity. Journal of Consulting and Clinical Psychology. 2001;69:722-726. [pmid: 11550740].
Peterson Gussie, Abrams David B, Elder John P, Beaudin Paula A. Professional versus self-help weight loss at the worksite: The challenge of making a public health impact. Behavior Therapy. 85(16):213-222.
Pettee Kelley K, Kriska Andrea M, Conroy Molly B, Johnson B Delia, Orchard Trevor J, Goodpaster Bret H, Averbach Frani M, Kuller Lewis H. Discontinuing hormone replacement therapy: Attenuating the effect on CVD risk with lifestyle changes. American Journal of Preventive Medicine. 2007;32:483-489. [pmid: 17533063].
Pleas John. Long-term effects of a lifestyle-change obesity treatment program with minorities. Journal of the National Medical Association. 88(80):747-752.
Quinn Rothacker D. Five-year self-management of weight using meal replacements: comparison with matched controls in rural Wisconsin. Nutrition. 2000;16:344-8. [pmid: 10793302].
Racette SB, Weiss EP, Schechtman KB, Steger-May K, Villareal DT, Obert KA, Holloszy JO. Influence of weekend lifestyle patterns on body weight. Obesity (Silver Spring Md.). 2008;16:1826-30.
Ramirez Elena M, Rosen James C. A comparison of weight control and weight control plus body image therapy for obese men and women. Journal of Consulting and Clinical Psychology. 2001;69:440-446. [pmid: 11495173].
Rapoport L, Clark M, Wardle J. Evaluation of a modified cognitive-behavioural programme for weight management. Int J Obes Relat Metab Disord. 2000;24:1726-37. [pmid: 11126231].
Redenius R, Murphy C, O'Neill E, Al-Hamwi M, Zallek SN. Does CPAP lead to change in BMI?. J Clin Sleep Med. 2008;4:205-9. [pmid: 18595431].
Richard B, Fahimi F, Naderi N. Improving risk factors in diabetic patients participating in a weight management program. South Med J. 2005;98:496-7. [pmid: 15898537].
Rodriguez M, Sanchez Fernandez MD. Effectiveness of a group educational intervention in patients with chronic obstructive pulmonary disease. [Spanish]. Enfermeria Clinica. 2003;13:131-136.
Roesch Scott C, Norman Greg J, Villodas Feion, Sallis James F, Patrick Kevin. Intervention-mediated effects for adult physical activity: A latent growth curve analysis. Social Science & Medicine. 2010;71:494-501. [pmid: 20621747].
Roessler Kirsten Kaya, Ibsen Bjarne. Promoting exercise on prescription: Recruitment, motivation, barriers and adherence in a Danish community intervention study to reduce type 2 diabetes, dyslipidemia and hypertension. Journal of Public Health. 2009;17:187-193.
Rohrer James E, Barnes Darryl E, Adamson Steven C, Altrichter Paul M, Yapuncich Victor P. Limited stair-climbing ability and weight control in family medicine patients. Chronic Illness. 2008;4:183-187. [pmid: 18796507].
Rosenthal B, Marx RD. Modeling influences on the eating behavior of successful and unsuccessful dieters and untreated normal weight individuals. Addictive behaviors. 79(4):215-21.
Sacerdote C, Fiorini L, Rosato R, Audenino M, Valpreda M, Vineis P. Randomized controlled trial: effect of nutritional counselling in general practice. International journal of epidemiology. 2006;35:409-15. [pmid: 16157616].
Saito T, Watanabe M, Nishida J, et al. Lifestyle modification and prevention of type 2 diabetes in overweight Japanese with impaired fasting glucose levels: a randomized controlled trial. Arch Intern Med. 2011;171:1352-60. [pmid: 21824948].
Sakane N, Sato J, Tsushita K, et al. Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011;11:40. [pmid: 21235825].
Schadlich S, Boldemann RD, Blankenburg T, Schutte W. Weight changes under long-term CPAP therapy - A retrospective analysis of 244 patients: Gewichtsveranderung unter langfristiger CPAP-therapie - Eine retrospektive analyse an 244 patienten. Somnologie. 2006;10:15-20.
Schmid TL, Jeffery RW, Onstad L, Corrigan SA. Demographic, knowledge, physiological, and behavioral variables as predictors of compliance with dietary treatment goals in hypertension. ADDICT. BEHAV. 91(16):151-160.
Schmitz K, French SA, Jeffery RW. Correlates of changes in leisure time physical activity over 2 years: the Healthy Worker Project. Preventive Medicine. 97(26):570-579.
Scholz U, Ochsner S, Luszczynska A. Comparing different boosters of planning interventions on changes in fat consumption in overweight and obese individuals: A randomized controlled trial. Int J Psychol. 2012. Epub ahead of print.
Schroder Kerstin EE. Computer-Assisted Dieting: Effects of a Randomized Nutrition Intervention. American Journal of Health Behavior. 2011;35:175-188. [pmid: 21204680].
Schultz MG, Hordern MD, Leano R, et al. Lifestyle change diminishes a hypertensive response to exercise in type 2 diabetes. Med Sci Sports Exerc. 2011;43:764-9. [pmid: 20881877].
Schwartz TL, Jindal S, Simionescu M, Nihalani N, Azhar N, Tirmazi S, Hussein J. Effectiveness of orlistat versus diet and exercise for weight gain associated with antidepressant use: a pilot study. Journal of clinical psychopharmacology. 2004;24:555-6. [pmid: 15349017].
Shearer RS, Kiely JJ. New techniques in office management of obesity. J Int Med Res. 77(5):147-54.
Sichieri R, Moura AS, Genelhu V, Hu F, Willett WC. An 18-mo randomized trial of a low-glycemic-index diet and weight change in Brazilian women. The American journal of clinical nutrition. 2007;86:707-13. [pmid: 17823436].
Silva MN, Markland D, Carraca EV, Vieira PN, Coutinho SR, Minderico CS, Matos MG, Sardinha LB, Teixeira PJ. Exercise autonomous motivation predicts 3-yr weight loss in women. Med Sci Sports Exerc. 2011;43:728-37. [pmid: 20689448].
SILVERSTONE JT, SOLOMON T. THE LONG-TERM MANAGEMENT OF OBESITY IN GENERAL PRACTICE. Br J Clin Pract. 65(19):395-8.
Simkin-Silverman LR, Wing RR, Boraz MA, Kuller LH. Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26:212-20. [pmid: 14644697].
Simkin-Silverman LR, Wing RR, Boraz MA, Meilahn EN, Kuller LH. Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 98(4):255-71.
Singleton Steven P, Neale Anne V, Hess Joseph W, Dupuis Mary H. Behavioral contracting in an urban health promotion project. Evaluation & the Health Professions. 87(10):408-437.
Slentz CA, Bateman LA, Willis LH, et al. Effects of aerobic vs. resistance training on visceral and liver fat stores, liver enzymes, and insulin resistance by HOMA in overweight adults from STRRIDE AT/RT. Am J Physiol Endocrinol Metab. 2011;301:E1033-9. [pmid: 21846904].
Somers TJ, Blumenthal JA, Guilak F, et al. Pain coping skills training and lifestyle behavioral weight management in patients with knee osteoarthritis: A randomized controlled study. Pain. 2012;153(6):1199-209. [pmid: 22503223].
Spring B, Pagoto S, Pingitore R, Doran N, Schneider K, Hedeker D. Randomized controlled trial for behavioral smoking and weight control treatment: effect of concurrent versus sequential intervention. J Consult Clin Psychol. 2004;72:785-96. [pmid: 15482037].
Stalonas PM Jr, Johnson WG, Christ M. Behavior modification for obesity: the evaluation of exercise, contingency management, and program adherence. J Consult Clin Psychol. 78(46):463-9.
Stellfeldt A, Muller MJ, Bode V, Westenhofer J. Behaviour factors and stabilisation of reduced body weight over one year: Verhaltensfaktoren und stabilisierung des reduzierten korpergewichts uber ein jahr. Aktuel. Ernahr. Med. 2000;25:281-288.
Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ (Clinical research ed.). 99(319):943-7. discussion 947-8.
Stewart T, Han H, Allen RH, Bathalon G, Ryan DH, Newton RL Jr, Williamson DA. H.E.A.L.T.H.: efficacy of an internet/population-based behavioral weight management program for the U.S. Army. J Diabetes Sci Technol. 2011;5:178-87. [pmid: 21303642].
Swift Judy Anne, Glazebrook Cris, Anness Abigail, Goddard Rebecca. Obesity-related knowledge and beliefs in obese adults attending a specialist weight-management service: Implications for weight loss over 1. Patient Education and Counseling. 2009;74:70-76. [pmid: 18804936].
Takahata Syozo, Musashi Hirohumi. Formation and long-term maintenance of dietary and exercise habits in persons with mental retardation: Providing daily assistance through living skill support tools. The Japanese Journal of Behavior Analysis. 98(13):2-16.
Taylor CB, Fortmann SP, Flora J, Kayman S, Barrett DC, Jatulis D, Farquhar JW. Effect of long-term community health education on body mass index. The Stanford Five-City Project. Am J Epidemiol. 91(134):235-49.
Teplan V, Schück O, Racek J, et al. Reduction of plasma asymmetric dimethylarginine in obese patients with chronic kidney disease after three years of a low-protein diet supplemented with keto-amino acids: a randomized controlled trial. Wiener Klinische Wochenschrift. 2008;120(15-16):478-85. [pmid: 18820852].
Terry PE, Seaverson EL, Grossmeier J, Anderson DR. Effectiveness of a worksite telephone-based weight management program. Am J Health Promot. 2011;25:186-9. [pmid: 21192748].
The Oslo Diet and Exercise Study (ODES): design and objectives. Controlled clinical trials. 93(14):229-43.
Thomas GN, Macfarlane DJ, Guo B, et al. Health Promotion In Older Chinese: 12-Month Cluster RCT Of Pedometry And Peer Support. Med Sci Sports Exerc. 2011;44:1157-66. [pmid: 22143109].
Thomson CA, Rock CL, Giuliano AR, Newton TR, Cui H, Reid PM, Green TL, Alberts DS, Women's Healthy Eating, &. Living Study Group. Longitudinal changes in body weight and body composition among women previously treated for breast cancer consuming a high-vegetable, fruit and fiber, low-fat diet. European journal of nutrition. 2005;44:18-25. [pmid: 15309460].
Thorndike Anne N, Healey Erica, Sonnenberg Lillian, Regan Susan. Participation and cardiovascular risk reduction in a voluntary worksite nutrition and physical activity program. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2011;52:164-166.
Trueman P, Haynes SM, Felicity Lyons G, Louise McCombie E, McQuigg MS, Mongia S, Noble PA, Quinn MF, Ross HM, Thompson F, Broom JI, Laws RA, Reckless JP, Kumar S, Lean ME, Frost GS, Finer N, Haslam DW, Morrison D, Sloan B. Long-term cost-effectiveness of weight management in primary care. Int J Clin Pract. 2010;64:775-83. [pmid: 20353431].
Uusitupa MI. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Annals of medicine. 96(28):445-9.
Uusitupa M, Laitinen J, Siitonen O, Vanninen E, Pyorala K. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Res Clin Pract. 93(19):227-38.
van Dale D, Saris WH, ten Hoor F. Weight maintenance and resting metabolic rate 18-40 months after a diet/exercise treatment. Int J Obes. 90(14):347-59.
Vogels N, Westerterp-Plantenga MS. Categorical strategies based on subject characteristics of dietary restraint and physical activity, for weight maintenance. Int J Obes (Lond). 2005;29:849-57. [pmid: 15917852].
Vogels N, Westerterp-Plantenga MS. Successful long-term weight maintenance: a 2-year follow-up. Obesity (Silver Spring). 2007;15:1258-66. [pmid: 17495202].
Volpe SL, Kobusingye H, Bailur S, Stanek E. Effect of diet and exercise on body composition, energy intake and leptin levels in overweight women and men. Journal of the American College of Nutrition. 2008;27:195-208. [pmid: 18689550].
Vray M, Joubert JM, Eschwege E, Liard F, Fagnani F, Montestruc F, Fages S, Begaud B. Results from the observational study EPIGRAM: Management of excess weight in general practice and follow-up of patients treated with orlistat: Resultats de l'etude observationnelle EPIGRAM: Prise en charge de l'obesite et du surpoids en medecine generale, suivi de la cohorte traitee par l'orlistat. Therapie. 2005;60:17-24. [pmid: 15929469].
Wadden TA, Stunkard AJ. Controlled trial of very low calorie diet, behavior therapy, and their combination in the treatment of obesity. Journal of consulting and clinical psychology. 86(54):482-8.
Wadden TA, Stunkard AJ, Liebschutz J. Three-year follow-up of the treatment of obesity by very low calorie diet, behavior therapy, and their combination. Journal of consulting and clinical psychology. 88(56):925-8.
Wadden TA, Vogt RA, Andersen RE, Bartlett SJ, Foster GD, Kuehnel RH, Wilk J, Weinstock R, Buckenmeyer P, Berkowitz RI, Steen SN. Exercise in the treatment of obesity: effects of four interventions on body composition, resting energy expenditure, appetite, and mood. Journal of consulting and clinical psychology. 97(65):269-77.
Waleekhachonloet OA, Limwattananon C, Limwattananon S, Gross CR. Group behavior therapy versus individual behavior therapy for healthy dieting and weight control management in overweight and obese women living in rural community. Obes. Res. Clin. Pract. 2007;1:223-232.
Weinsier RL, Johnston MH, Doleys DM, Bacon JA. Dietary management of obesity: evaluation of the time-energy displacement diet in terms of its efficacy and nutritional adequacy for long-term weight control. Br J Nutr. 82(47):367-79.
Weinstein AR, Sesso HD, Lee IM, Rexrode KM, Cook NR, Manson JE, Buring JE, Gaziano JM. The joint effects of physical activity and body mass index on coronary heart disease risk in women. Archives of internal medicine. 2008;168:884-90. [pmid: 18443265].
Weiss EC, Galuska DA, Khan LK, Serdula MK. Weight-control practices among U.S. adults, 2001-2002. Am J Prev Med. 2006;31:18-24. [pmid: 16777538].
Williamson DA, Rejeski J, Lang W, Van Dorsten B, Fabricatore AN, Toledo K, Look AHEAD Research Group. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Archives of internal medicine. 2009;169:163-71. [pmid: 19171813].
Wing RR. Behavioral strategies to improve long-term weight loss and maintenance. Med Health R I. 99(82):123.
Wing Rena R, Epstein Leonard H, Marcus Marsha D, Koeske Randi. Intermittent low-calorie regimen and booster sessions in the treatment of obesity. Behaviour Research and Therapy. 84(22):445-449.
Wirth A, Vogel I, Schömig A, Schlierf G. Metabolic effects and body fat mass changes in obese subjects on a very-low-calorie diet with and without intensive physical training. Annals of Nutrition & Metabolism. 1987;31(6):378-86. [pmid: 3322166].
Wood D, Kotseva K, Connolly S, Jennings C, Mead A, Jones J, Holden A, De Bacquer D, Collier T, De Backer G, Faergeman O. Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999-2012. [pmid: 18555911].
Wood ER. Weight loss maintenance 1 year after individual counseling. J Am Diet Assoc. 90(90):1256-60. [pmid: 2398217].
Woollard J, Burke V, Beilin LJ, Verheijden M, Bulsara MK. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. Journal of cardiovascular risk. 2003;10:31-40. [pmid: 12569235].
Wyld B, Harrison A, Noakes M. The CSIRO Total Wellbeing Diet Book 1: sociodemographic differences and impact on weight loss and well-being in Australia. Public Health Nutr. 2010;13:2105-2110. [pmid: 20392311].
Yancey Antronette K, McCarthy William J, Harrison Gail G, Wong Weng Kee, Siegel Judith M, Leslie Joanne. Challenges in Improving Fitness: Results of a Community-Based, Randomized, Controlled Lifestyle Change Intervention. Journal of Women's Health. 2006;15:412-429.
YOUNG CM, RINGLER I, GREER BJ. Reducing and post-reducing maintenance on the moderate-fat diet; metabolic studies. J Am Diet Assoc. 53(29):890-6.
Young DR, Vollmer WM, King AC, Brown AJ, Stevens VJ, Elmer PJ, Craddick S, Sturtevant DL, Harsha DW, Appel LJ. Can individuals meet multiple physical activity and dietary behavior goals?. American journal of health behavior. 2009;33:277-86. [pmid: 19063649].
Zahouani A, Boulier A, Hespel JP. Short- and long-term evolution of body composition in 1389 obese outpatients following a very low calorie diet (Pro'gram18 VLCD). Acta Diabetol. Suppl 1. 2003;40:S149-50. [pmid: 14618457].
Zapotoczky H, Semlitsch B, Herzog G, Bahadori B, Siebenhofer A, Pieber TR, Zapotoczky HG. A controlled study of weight reduction in type 2 diabetics treated by two reinforcers. Int. J. Behav. Med. 2001;8:42-49.
Zegman M, Baker B. The influence of proximal vs. distal goals on adherence to prescribed calories. Addict Behav. 83(8):319-22.

## No intervention/exposure of interest

U.K. prospective diabetes study 16. Overview of 6 years' therapy of type II diabetes: a progressive disease. U.K. Prospective Diabetes Study Group. Diabetes. 95(44):1249-58.
AbuSabha R, Greene G. Body weight, body composition, and energy intake changes in breastfeeding mothers. J Hum Lact. 98(14):119-24.
Adams Jean, White Martin. Time perspective in socioeconomic inequalities in smoking and body mass index. Health Psychology. 2009;28:83-90. [pmid: 19210021].
Almeida Osvaldo P, Alfonso Helman, et al. A practical approach to assess depression risk and to guide risk reduction strategies in later life. International Psychogeriatrics. 2011;23:280-291. [pmid: 20880427].
Althuizen E, van Poppel MN, Seidell JC, van der Wijden C, van Mechelen W. Design of the New Life(style) study: a randomised controlled trial to optimise maternal weight development during pregnancy. BMC Public Health. 2006;6:168. [pmid: 16800869].
Aspy CB, Mold JW, Thompson DM, Blondell RD, Landers PS, Reilly KE, Wright-Eakers L. Integrating Screening and Interventions for Unhealthy Behaviors into Primary Care Practices. Am. J. Prev. Med. 2008;35:S373-S380. [pmid: 18929984].
Bemelmans W, van Baal P, Wendel-Vos W, Schuit J, Feskens E, Ament A, Hoogenveen R. The costs, effects and cost-effectiveness of counteracting overweight on a population level. A scientific base for policy targets for the Dutch national plan for action. Prev Med. 2008;46:127-32. [pmid: 17822752].
Bhattacharya J, Sood N. Who pays for obesity?. J. Econ. Perspect. 2011;25:139-158. [pmid: 21598459].
Bhattacharya J, Sood N. Who pays for obesity?. J. Econ. Perspect. 2011;25:139-158. [pmid: 21598459].
Bjerkedal T, Brevik JI. Geographic variation in body mass index among Norwegian conscripts born 1967-80: Geografiske variasjoner i kroppsmasseindeks malt ved sesjon for menn fodt i Norge 1967-80. Tidsskr. Nor. Laegeforen. 2001;121:3505-3508. [pmid: 11808008].
Carls GS, Goetzel RZ, Henke RM, Bruno J, Isaac F, McHugh J. The impact of weight gain or loss on health care costs for employees at the Johnson & Johnson Family of Companies. J Occup Environ Med. 2011;53:8-16. [pmid: 21187786].
Carmody TP, Brunner RL, St Jeor ST. Dietary helplessness and disinhibition in weight cyclers and maintainers. Int J Eat Disord. 95(18):247-56.
Chang VW, Christakis NA. Income inequality and weight status in US metropolitan areas. Soc Sci Med. 2005;61:83-96. [pmid: 15847964].
Chen DR, Wen TH. Elucidating the changing socio-spatial dynamics of neighborhood effects on adult obesity risk in Taiwan from 2001 to 2005. Health Place. 2010;16:1248-1258. [pmid: 20832348].
Chen Zhuo, Meltzer David. Beefing up with the Chans: Evidence for the effects of relative income and income inequality on health from the China Health and Nutrition Survey. Social Science & Medicine. 2008;66:2206-2217. [pmid: 18325651].
Choquette Anne C, Lemieux Simone, Tremblay Angelo, Drapeau Vicky, Bouchard Claude, Vohl Marie-Claude, P+_russe Louis. GAD2 gene sequence variations are associated with eating behaviors and weight gain in women from the Quebec family study. Physiology & Behavior. 2009;98:505-510. [pmid: 19686769].
Christiansen E, Swann A, Sorensen TI. Feedback models allowing estimation of thresholds for self-promoting body weight gain. J Theor Biol. 2008;254:731-6. [pmid: 18671981].
Cohen SS, Larson CO, Matthews CE, Buchowski MS, Signorello LB, Hargreaves MK, Blot WJ. Parity and breastfeeding in relation to obesity among black and white women in the southern community cohort study. J Womens Health (Larchmt). 2009;18:1323-32. [pmid: 19743905].
Colditz GA, Coakley E. Weight, weight gain, activity, and major illnesses: The Nurses' Health Study. INT. J. SPORTS MED. SUPPL. 97(18):S162-S170.
Craig CL, Russell SJ, Cameron C. Reliability and validity of Canada's physical activity monitor for assessing trends. Medicine & Science in Sports & Exercise. 2002;34:1462-1467. [pmid: 12218739].
Crawford D, Owen N, Broom D, Worcester M, Oliver G. Weight-control practices of adults in a rural community. Aust N Z J Public Health. 98(22):73-9.
Cropsey KL, McClure LA, Jackson DO, Villalobos GC, Weaver MF, Stitzer ML. The impact of quitting smoking on weight among women prisoners participating in a smoking cessation intervention. Am J Public Health. 2010;100:1442-1448. [pmid: 20558806].
de Fine Olivarius N, Richelsen B, Siersma V, Andreasen AH, Beck-Nielsen H. Weight history of patients with newly diagnosed Type 2 diabetes. Diabet Med. 2008;25:933-41. [pmid: 18959606].
Derosa G, Mugellini A, Ciccarelli L, Fogari R. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clinical therapeutics. 2003;25:1107-22. [pmid: 12809960].
DiBonaventura MC, Chapman GB. The effect of barrier underestimation on weight management and exercise change. Psychology, Health & Medicine. 2008;13:111-122.
Dummer TJ, Kirk SF, Penney TL, et al. Targeting policy for obesity prevention: identifying the critical age for weight gain in women. J Obes. 2012;2012. 934895.
Ebrahimi-Mameghani M, Scott JA, Der G, Lean ME, Burns CM. Changes in weight and waist circumference over 9 years in a Scottish population. Eur J Clin Nutr. 2008;62:1208-14. [pmid: 17622259].
Edwards RD. Public transit, obesity, and medical costs: Assessing the magnitudes. Prev. Med. 2008;46:14-21. [pmid: 18037480].
Eisen SA, Lyons MJ, Goldberg J, True WR. The impact of cigarette and alcohol consumption on weight and obesity. An analysis of 1911 monozygotic male twin pairs. Arch Intern Med. 93(153):2457-63.
Ell K, Katon W, Xie B, Lee PJ, Kapetanovic S, Guterman J, Chou CP. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. 2010;33:706-13. [pmid: 20097780].
Emery SL, Szczypka G, Powell LM, Chaloupka FJ. Public health obesity-related TV advertising: lessons learned from tobacco. Am J Prev Med. 2007;33:S257-63. [pmid: 17884574].
Fitzpatrick P, Fitz-Simon N, Lonergan M, Collins C, Daly L. Heartwatch: the effect of a primary care-delivered secondary prevention programme for cardiovascular disease on medication use and risk factor profiles. Eur J Cardiovasc Prev Rehabil. 2010.
Flint Kelsey M, Gilmour Walleghen, Van Emily L, Kealey Elizabeth H, VonKaenel Sandra, Bessesen Daniel H, Davy Brenda M. Differences in eating behaviors between nonobese, weight stable young and older adults. Eating Behaviors. 2008;9:370-375. [pmid: 18549998].
Forman-Hoffman VL, Richardson KK, Yankey JW, Hillis SL, Wallace RB, Wolinsky FD. Retirement and weight changes among men and women in the health and retirement study. J Gerontol B Psychol Sci Soc Sci. 2008;63:S146-53. [pmid: 18559689].
Forsberg KA, Bj+¦rkman T, Sandman PO, Sandlund M. Influence of a lifestyle intervention among persons with a psychiatric disability: A cluster randomised controlled trial on symptoms, quality of life and sense of coherence. Journal of Clinical Nursing. 2010;19(11-12):1519-28. [pmid: 20384660].
Frank LD, Saelens BE, Powell KE, Chapman JE. Stepping towards causation: do built environments or neighborhood and travel preferences explain physical activity, driving, and obesity?. Soc Sci Med. 2007;65:1898-914. [pmid: 17644231].
Gallant MP, Connell CM. The stress process among dementia spouse caregivers: Are caregivers at risk for negative health behavior change?. Res. Aging. 98(20):267-297.
Gallant MP, Dorn GP. Gender and race differences in the predictors of daily health practices among older adults. Health Educ. Res. 2001;16:21-31. [pmid: 11252281].
Girois Susan B, Kumanyika Shiriki K, Morabia Alfredo, Mauger Elizabeth. A comparison of knowledge and attitudes about diet and health among 35- to 75-year-old adults in the United States and Geneva, Switzerland. American Journal of Public Health. 2001;91:418-424. [pmid: 11236407].
Glasgow RE, Kurz D, King D, et al. Twelve-month outcomes of an Internet-based diabetes self-management support program. Patient Educ Couns. 2012;87:81-92. [pmid: 21924576].
Gropper SS, Newton A, Harrington P, Simmons KP, Connell LJ, Ulrich P. Body composition changes during the first two years of university. Preventive Medicine. 2011;52:20-22. [pmid: 21067706].
Harris TB, Savage PJ, Tell GS, Haan M, Kumanyika S, Lynch JC. Carrying the burden of cardiovascular risk in old age: associations of weight and weight change with prevalent cardiovascular disease, risk factors, and health status in the Cardiovascular Health Study. Am J Clin Nutr. 97(66):837-44.
Haukkala Ari, Uutela Antti, Salomaa Veikko. Depressive symptoms, cynical hostility, and weight change: A 3-year follow-up among middle-aged men and women. International Journal of Behavioral Medicine. 2001;8:116-133.
Haupt E, Herrmann R, Benecke-Timp A, Vogel H, Haupt A, Walter C. The KID Study IV: Effects of inpatient rehabilitation on the frequency of glucose self-monitoring, quality of further primary care, on time being unable to work and on everyday psychic strain of type I and type II diabetics - A one-year follow-up. EXP. CLIN. ENDOCRINOL. DIABETES. 97(105):21-31.
Hawkes AL, Lynch BM, Owen N, Aitken JF. Lifestyle factors associated concurrently and prospectively with co-morbid cardiovascular disease in a population-based cohort of colorectal cancer survivors. European Journal of Cancer. 2011;47:267-276. [pmid: 21074408].
Hawley G, Horwath C, Gray A, Bradshaw A, Katzer L, Joyce J, O'Brien S. Sustainability of health and lifestyle improvements following a non-dieting randomised trial in overweight women. Prev Med. 2008;47:593-9. [pmid: 18817809].
Hays NP, Roberts SB. Aspects of eating behaviors “disinhibition” and “restraint” are related to weight gain and BMI in women. Obesity (Silver Spring). 2008;16:52-8. [pmid: 18223612].
Hertel JK, Johansson S, Sonestedt E, Jonsson A, Lie RT, Platou CG, Nilsson PM, Rukh G, Midthjell K, Hveem K, Melander O, Groop L, Lyssenko V, Molven A, Orho-Melander M, Njolstad PR. FTO, Type 2 Diabetes, and Weight Gain Throughout Adult Life: A Meta-Analysis of 41,504 Subjects From the Scandinavian HUNT, MDC, and MPP Studies. Diabetes. 2011;60:1637-44. [pmid: 21398525].
Holm-Denoma JM, Joiner TE Jr., Vohs KD, Heatherton TF. The “freshman fifteen” (the “freshman five” actually): predictors and possible explanations. Health Psychology. 2008;27:S3-9. [pmid: 18248103].
Hu FB, Willett WC, Li T, Stampfer MJ, Colditz GA, Manson JE. Adiposity as compared with physical activity in predicting mortality among women. New Engl. J. Med. 2004;351:2694-2703. [pmid: 15616204].
Hudzinski LG, Sirois PA. Changes in smoking behavior and body weight after implementation of a no-smoking policy in the workplace. South Med J. 94(87):322-7.
Ilmonen J, Isolauri E, Poussa T, Laitinen K. Impact of dietary counselling and probiotic intervention on maternal anthropometric measurements during and after pregnancy: a randomized placebo-controlled trial. Clin Nutr. 2011;30:156-64. [pmid: 20970896].
Javier Basterra-Gortari F, Forga L, Bes-Rastrollo M, Toledo E, Alfredo Martinez J, Martinez Gonzalez MA. Effect of Smoking on Body Weight: Longitudinal Analysis of the SUN Cohort: Evolucion de los cambios en el peso corporal segun habito tabaquico: analisis longitudinal de la cohorte SUN. Rev. Esp. Cardiol. 2010;63:20-27. [pmid: 20089222].
John U, Meyer C, Rumpf HJ, Schumann A, Dilling H, Hapke U. No considerable long-term weight gain after smoking cessation: evidence from a prospective study. Eur J Cancer Prev. 2005;14:289-95. [pmid: 15902001].
Kalter-Leibovici O, Atamna A, Lubin F, Alpert G, Keren MG, Murad H, Chetrit A, Goffer D, Eilat-Adar S, Goldbourt U. Obesity among Arabs and Jews in Israel: a population-based study. Isr Med Assoc J. 2007;9:525-30. [pmid: 17710784].
Kim Daniel, Kawachi Ichiro, Hoorn Stephen Vander, Ezzati Majid. Is inequality at the heart of it? Cross-country associations of income inequality with cardiovascular diseases and risk factors. Social Science & Medicine. 2008;66:1719-1732. [pmid: 18280021].
Klisiewicz AM, Raal F. Sub-optimal management of type 2 diabetes mellitus - A local audit. J. Endocrinol. Metab. Diabetes S. Afr. 2009;14:13-16.
Knekt P, Laaksonen MA, Raitasalo R, Haaramo P, Lindfors O. Changes in lifestyle for psychiatric patients three years after the start of short- and long-term psychodynamic psychotherapy and solution-focused therapy. European psychiatry : the journal of the Association of European Psychiatrists. 2010;25:1-7. [pmid: 19553088].
Kriska AM, Saremi A, Hanson RL, Bennett PH, Kobes S, Williams DE, Knowler WC. Physical activity, obesity, and the incidence of type 2 diabetes in a high-risk population. Am J Epidemiol. 2003;158:669-75. [pmid: 14507603].
Kritz-Silverstein D, Barrett-Connor E. Long-term postmenopausal hormone use, obesity, and fat distribution in older women. JAMA: Journal of the American Medical Association. 96-97(275):46-49.
Lampert T. Smoking, physical inactivity, and obesity: Associations with social status. Deutsches +Ärzteblatt International. 2010;107(1-2):1-7. [pmid: 20090874].
Larew K, Hunter GR, Larson-Meyer DE, Newcomer BR, McCarthy JP, Weinsier RL. Muscle metabolic function, exercise performance, and weight gain. Med. Sci. Sports Exerc. 2003;35:230-236. [pmid: 12569210].
Leunissen RWJ, Kerkhof GF, Stijnen T, Hokken-Koelega A. Timing and tempo of first-year rapid growth in relation to cardiovascular and metabolic risk profile in early adulthood. J. Am. Med. Assoc. 2009;301:2234-2242.
Li C, Chen S, Lan C, Pan W, Chou H, Bai Y, Tzeng M, Lee M, Lai J. The effects of physical activity, body mass index (BMI) and waist circumference (WC) on glucose intolerance in older people: A nationwide study from Taiwan. Archives of Gerontology & Geriatrics. 2011;52:54-59. [pmid: 20206389].
Littman AJ, Jacobson IG, Boyko EJ, et al. Weight change following US military service. Int J Obes. 2012. Epub ahead of print.
Marsiaj HI, Catalano C, Sum CF, Home PD, Alberti KG. Management of newly diagnosed non-insulin-dependent (type 2) diabetes mellitus: a retrospective audit. Diabetes Res Clin Pract. 91(12):129-36.
Martin LJ, Lee SY, Couch SC, et al. Shared genetic contributions of fruit and vegetable consumption with BMI in families 20 y after sharing a household. Am J Clin Nutr. 2011;94:1138-43. [pmid: 21831991].
Maruhama Y, Abe R, Okuguchi F, Ohneda A. Dietary intake and hyperlipidemia in controlled diabetic outpatients. Diabetes. 77(26):94-9.
Mayer DK, Terrin NC, Menon U, Kreps GL, McCance K, Parsons SK, Mooney KH. Health behaviors in cancer survivors. Oncology Nursing Forum. 2007;34:643-651. [pmid: 17573323].
Mogul HR, Peterson SJ, Weinstein BI, Zhang S, Southren AL. Metformin and carbohydrate-modified diet: a novel obesity treatment protocol: preliminary findings from a case series of nondiabetic women with midlife weight gain and hyperinsulinemia. Heart Dis. 2001;3:285-92. [pmid: 11975807].
Murphy JM, Horton NJ, Burke JD Jr, Monson RR, Laird NM, Lesage A, Sobol AM. Obesity and weight gain in relation to depression: findings from the Stirling County Study. Int J Obes (Lond). 2009;33:335-41. [pmid: 19139752].
Nafziger AN, Lindvall K, Norberg M, Stenlund H, Wall S, Jenkins PL, Pearson TA, Weinehall L. Who is maintaining weight in a middle-aged population in Sweden? A longitudinal analysis over 10 years. BMC Public Health. 2007;7:108. [pmid: 17565692].
Nagasaka S, Ishikawa S, Nakamura T, Kawakami A, Rokkaku K, Hayashi H, Kusaka I, Higashiyama M, Saito T. Association of endogenous insulin secretion and mode of therapy with body fat and serum leptin levels in diabetic subjects. Metabolism. 98(47):1391-6.
Nelson MC, Lust K, Story M, Ehlinger E. Credit card debt, stress and key health risk behaviors among college students. American Journal of Health Promotion. 2008;22:400-407. [pmid: 18677880].
Nelson Melissa C, Lust Katherine, Story Mary, Ehlinger Ed. Alcohol use, eating patterns, and weight behaviors in a university population. American Journal of Health Behavior. 2009;33:227-237. [pmid: 19063644].
Newcomer JW. Metabolic considerations in the use of antipsychotic medications: a review of recent evidence. J Clin Psychiatry. Suppl 1. 2007;68:20-7. [pmid: 17286524].
Noll JG, Zeller MH, Trickett PK, Putnam FW. Obesity risk for female victims of childhood sexual abuse: a prospective study. Pediatrics. 2007;120:e61-7. [pmid: 17606550].
Ojofeitimi EO, Adeyeye AO, Fadiora AO, Kuteyi AO, Faborode TG, Adegbenro CA, Bakare OE, Setiloane K, Towobola KS. Awareness of obesity and its health hazard among women in a University Community. Pak. J. Nutr. 2007;6:502-505.
Park HA, Lee JS, Kuller LH, Cauley JA. Effects of weight control during the menopausal transition on bone mineral density. J Clin Endocrinol Metab. 2007;92:3809-15. [pmid: 17635939].
Pettee Kelley K, Kriska Andrea M, Conroy Molly B, Johnson B Delia, Orchard Trevor J, Goodpaster Bret H, Averbach Frani M, Kuller Lewis H. Discontinuing hormone replacement therapy: Attenuating the effect on CVD risk with lifestyle changes. American Journal of Preventive Medicine. 2007;32:483-489. [pmid: 17533063].
Procter-Gray E, Cobb KL, Crawford SL, Bachrach LK, Chirra A, Sowers M, Greendale GA, Nieves JW, Kent K, Kelsey JL. Effect of oral contraceptives on weight and body composition in young female runners. Medicine & Science in Sports & Exercise. 2008;40:1205-1212. [pmid: 18580398].
Ramos SC, Fonseca FA, Kasmas SH, et al. The role of soluble fiber intake in patients under highly effective lipid-lowering therapy. Nutr J. 2011;10:80. [pmid: 21810257].
Redenius R, Murphy C, O'Neill E, Al-Hamwi M, Zallek SN. Does CPAP lead to change in BMI?. J Clin Sleep Med. 2008;4:205-9. [pmid: 18595431].
Redfern J, McKevitt C, Dundas R, Rudd AG, Wolfe CDA. Behavioral risk factor prevalence and lifestyle change after stroke: a prospective study. Stroke (00392499). 2000;31:1877-1881.
Roderick PJ, Brennan PJ, Meade TW. Do risk factors change in men at high risk of coronary heart disease? Observations on the effect of health promotion in primary care. Journal of cardiovascular risk. 95(2):353-7.
Rogers H, Turner E, Thompson G, Hopkins D, Amiel SA. Hub-and-spoke model for a 5-day structured patient education programme for people with Type 1 diabetes. Diabet. Med. 2009;26:915-920. [pmid: 19719713].
Sandhu MS, Gibson JM, Heald AH, Dunger DB, Wareham NJ. Low circulating IGF-II concentrations predict weight gain and obesity in humans. Diabetes. 2003;52:1403-1408. [pmid: 12765950].
Saunders SA, Wallymhamed M, Macfarlane IA. Improvements in glycaemic control and cardiovascular risk factors in a cohort of patients with type 1 diabetes over a 5-year period. QJM. 2009;102:29-34. [pmid: 18829712].
Schmalz DL. ‘I feel fat’: weight-related stigma, body esteem, and BMI as predictors of perceived competence in physical activity. Obes Facts. 2010;3:15-21. [pmid: 20215791].
Schmid TL, Jeffery RW, Onstad L, Corrigan SA. Demographic, knowledge, physiological, and behavioral variables as predictors of compliance with dietary treatment goals in hypertension. ADDICT. BEHAV. 91(16):151-160.
Sforza E, Addati G, Cirignotta F, Lugaresi E. Natural evolution of sleep apnoea syndrome: A five year longitudinal study. EUR. RESPIR. J. 94(7):1765-1770.
Sohler N, Lubetkin E, Levy J, Soghomonian C, Rimmerman A. Factors associated with obesity and coronary heart disease in people with intellectual disabilities. Soc Work Health Care. 2009;48:76-89. [pmid: 19197767].
Stellman SD, Garfinkel L. Artificial sweetener use and one-year weight change among women. PREV. MED. 86(15):195-202.
Stettler N, Tershakovec AM, Zemel BS, Leonard MB, Boston RC, Katz SH, Stallings VA. Early risk factors for increased adiposity: a cohort study of African American subjects followed from birth to young adulthood. American Journal of Clinical Nutrition. 2000;72:378-383. [pmid: 10919930].
Strazzullo P, D'Elia L, Siani A. Is a trend to reduced sodium intake in the United States concealed by obesity?. Am J Clin Nutr. 2011;93:670-1. author reply 671-2. [pmid: 21248186].
Strik CM, Henry CJ. The role of a low-glycemic-index diet in the management of obesity. Am J Clin Nutr. 2005;81:940-1. author reply 941. [pmid: 15817876].
Suder Agnieszka. Body fatness and its social and lifestyle determinants in young working males from Cracow, Poland. Journal of Biosocial Science. 2009;41:139-154. [pmid: 18442432].
Sundbeck M, Grahn M, Lonngren V, Mansson ON, Rastam L, Lindblad U. Snuff use associated with abdominal obesity in former smokers. Scand. J. Public Health. 2009;37:487-493. [pmid: 19451197].
Suzuki M, Murashima M, Hoerr SL. Body mass and fatness of Japanese college women and relationship to place of residence. Nutrition & Dietetics. 2007;64:159-164.
Tang TS, Funnell MM, Noorulla S, et al. Sustaining short-term improvements over the long-term: results from a 2-year diabetes self-management support (DSMS) intervention. Diabetes Res Clin Pract. 2012;95:85-92. [pmid: 21872962].
Teplan V, Schück O, Racek J, et al. Reduction of plasma asymmetric dimethylarginine in obese patients with chronic kidney disease after three years of a low-protein diet supplemented with keto-amino acids: a randomized controlled trial. Wiener Klinische Wochenschrift. 2008;120(15-16):478-85. [pmid: 18820852].
Teunissen-Beek KF, Dopheide J, Geleijnse JM, et al. Protein supplementation lowers blood pressure in overweight adults: effect of dietary proteins on blood pressure (PROPRES), a randomized trial. Am J Clin Nutr. 2012;95:966-71. [pmid: 22357725].
Timperio A, Crawford DA. Public definitions of success in weight management. Nutrition & Dietetics. 2004;61:215-220.
Truesdale KP, Stevens J, Cai J. The effect of weight history on glucose and lipids: the Atherosclerosis Risk in Communities Study. American Journal of Epidemiology. 2005;161:1133-1143. [pmid: 15937022].
Tsujimoto T, Sairenchi T, Iso H, et al. Impact of obesity on incident hypertension independent of weight gain among nonhypertensive Japanese: the Ibaraki Prefectural Health Study (IPHS). J Hypertens. 2012;30:1122-8. [pmid: 22487734].
Turner RC, Mann JI, Iceton G, et al. UK prospective study of therapies of maturity-onset diabetes. I. Effect of diet, sulphonylurea, insulin or biguanide therapy on fasting plasma glucose and body weight over one year. DIABETOLOGIA. 83(24):404-411.
Tuthill A, McKenna MJ, O'Shea D, McKenna TJ. Weight changes in type 2 diabetes and the impact of gender. Diabestes Obes. Metab. 2008;10:726-732.
van Bruggen Rykel, Gorter Kees J, Stolk Roland P, Verhoeven Rob P, Rutten Guy EHM. Implementation of locally adapted guidelines on type 2 diabetes. Family Practice. 2008;25:430-437. [pmid: 18718886].
Van Den Ham ECH, Kooman JP, Christiaans MHL, Van Hooff JP. Relation between steroid dose, body composition and physical activity in renal transplant patients. Transplantation. 2000;69:1591-1598. [pmid: 10836368].
Van Rompay MI, McKeown NM, Castaneda-Sceppa C, et al. Acculturation and Sociocultural Influences on Dietary Intake and Health Status among Puerto Rican Adults in Massachusetts. J Acad Nutr Diet. 2012;112:64-74. [pmid: 22389874].
van Weel C, Bakx C, van den Hoogen H, Thien T, van den Bosch W. Long-term outcome of cardiovascular prevention: a Nijmegen Academic Family Practices Network study. J Am Board Fam Med. 2006;19:62-8. [pmid: 16492007].
Wannamethee SG, Shaper AG. Alcohol, body weight, and weight gain in middle-aged men. Am. J. Clin. Nutr. 2003;77:1312-1317. [pmid: 12716687].
Watson L, Wilson BP, Alsop J, et al. Weight and glycaemic control in type 2 diabetes: What is the outcome of insulin initiation?. Diabetes Obes Metab. 2011;13:823-31. [pmid: 21481128].
Weidinger KA, Lovegreen SL, Elliott MB, Hagood L, Haire-Joshu D, McGill JB, Brownson RC. How to make exercise counseling more effective: lessons from rural America. J Fam Pract. 2008;57:394-402. [pmid: 18544323].
Weinstock RS, Teresi JA, Goland R, Izquierdo R, Palmas W, Eimicke JP, Ebner S, Shea S. Glycemic control and health disparities in older ethnically diverse underserved adults with diabetes: five-year results from the Informatics for Diabetes Education and Telemedicine (IDEATel) study. Diabetes Care. 2011;34:274-279. [pmid: 21270184].
Wen L, Parchman ML, Linn WD, Lee S. Association between self-monitoring of blood glucose and glycemic control in patients with type 2 diabetes mellitus. American journal of health-system pharmacy : AJHP : official journal of the American Society of Health-System Pharmacists. 2004;61:2401-5. [pmid: 15581263].
Westerterp KR, Plasqui G. Physically active lifestyle does not decrease the risk of fattening. PLoS One. 2009;4:e4745. [pmid: 19270740].
Wheatley D. A new weight-reducing drug with novel properties. Postgraduate medical journal. 82(58):279-81.
Widgren BR, Herlitz H, Jonsson O, Berglund G, Wikstrand J, Andersson OK. Normotensive young men with family histories of hypertension gain weight and decrease their intraerythrocyte sodium content during a 5-year follow-up. J. INTERN. MED. 91(229):217-223.
Wolfe WS, Sobal J, Olson CM, Frongillo EA Jr, Williamson DF. Parity-associated weight gain and its modification by sociodemographic and behavioral factors: a prospective analysis in US women. Int J Obes Relat Metab Disord. 97(21):802-10.
Wyld B, Harrison A, Noakes M. The CSIRO Total Wellbeing Diet Book 1: sociodemographic differences and impact on weight loss and well-being in Australia. Public Health Nutr. 2010;13:2105-2110. [pmid: 20392311].
Yanovski JA, Parikh SJ, Yanoff LB, Denkinger BI, Calis KA, Reynolds JC, Sebring NG, McHugh T. Effects of calcium supplementation on body weight and adiposity in overweight and obese adults: a randomized trial. Ann Intern Med. 2009;150:821-9. W145. 6. [pmid: 19528561].
Zhang Qi, Wang Youfa. Trends in the Association between Obesity and Socioeconomic Status in U.S. Adults: 1971 to 2000. Obesity Research. 2004;12:1622-1632. [pmid: 15536226].

## No comparison group

Abid M, Billington CJ, Nuttall FQ. Thyroid function and energy intake during weight gain following treatment of hyperthyroidism. J. Am. Coll. Nutr. 99(18):189-193.
Absetz P, Oldenburg B, Hankonen N, Valve R, Heinonen H, Nissinen A, Fogelholm M, Talja M, Uutela A. Type 2 diabetes prevention in the real world: three-year results of the GOAL lifestyle implementation trial. Diabetes Care. 2009;32:1418-1420. [pmid: 19401442].
AbuSabha R, Greene G. Body weight, body composition, and energy intake changes in breastfeeding mothers. J Hum Lact. 98(14):119-24.
Ahern AL, Olson AD, Aston LM, Jebb SA. Weight Watchers on prescription: An observational study of weight change among adults referred to Weight Watchers by the NHS. BMC Public Health. 2011;11:434. [pmid: 21645343].
Al-Baghli NA, Al-Ghamdi AJ, Al-Turki KA, El-Zubaier AG, Al-Ameer MM, Al-Baghli FA. Overweight and obesity in the eastern province of Saudi Arabia. Saudi Med J. 2008;29:1319-25. [pmid: 18813420].
Amati Francesca, Barthassat Vincent, Miganne Guy, Hausman Isabelle, Monnin Dominique, Constanza Michael C, Golay Alain. Enhancing regular physical activity and relapse prevention through a 1-day therapeutic patient education workshop: A pilot study. Patient Education and Counseling. 2007;68:70-78. [pmid: 17590304].
Ames SC, Ames GE, Stevens SR, Patten CA, Werch CE, Schroeder DR. Effect of expressive writing as a treatment adjunct for reducing smoking cessation related weight gain in young adult smokers. Subst. Use Misuse. 2008;43:1315-1325. [pmid: 18696370].
Anderson-Bill ES, Winett RA, Wojcik JR. Social cognitive determinants of nutrition and physical activity among web-health users enrolling in an online intervention: the influence of social support, self-efficacy, outcome expectations, and self-regulation. J Med Internet Res. 2011;13:e28. [pmid: 21441100].
Anderson-Bill ES, Winett RA, Wojcik JR, Winett SG. Web-based guide to health: relationship of theoretical variables to change in physical activity, nutrition and weight at 16-months. J Med Internet Res. 2011;13:e27. [pmid: 21447470].
Artinian Nancy T, Schim Stephanie Myers, Vander Wal Jillon S, Nies Mary A. Eating Patterns and Cardiovascular Disease Risk in a Detroit Mexican American Population. Public Health Nursing. 2004;21:425-434. [pmid: 15363023].
Ball K, Burton NW, Brown WJ. A prospective study of overweight, physical activity, and depressive symptoms in young women. Obesity (Silver Spring). 2009;17:66-71. [pmid: 18997676].
Bastiaens Hilde, Sunaert Patricia, Wens Johan, Sabbe Bernard, Jenkins Lutgarde, Nobels Frank, Snauwaert Boris, Van Royen Paul. Supporting diabetes self-management in primary care: Pilot-study of a group-based programme focusing on diet and exercise. Primary Care Diabetes. 2009;3:103-109. [pmid: 19264568].
Bazzano Alicia T, Zeldin Ari S, Diab Ida R, Shihady, Garro Nicole M, Allevato Nathalia A, Lehrer Danise. The Healthy Lifestyle Change Program: A pilot of a community-based health promotion intervention for adults with developmental disabilities. American Journal of Preventive Medicine. 2009;37:S201-S208. [pmid: 19896020].
Bjarnason-Wehrens B, Bott D, Benesch L, Bischoff KO, Buran-Kilian B, Gysan D, Hollenstein U, Mayer-Berger W, Wilkniss R, Sauer G. Long-term results of a three-week intensive cardiac out-patient rehabilitation program in motivated patients with low social status. Clin Res Cardiol. 2007;96:77-85. [pmid: 17160566].
Bobb-Liverpool B, Duff EMW, Bailey EY. Compliance and blood pressure control in women with hypertension. West Indian Med. J. 2002;51:236-240. [pmid: 12632640].
Burani J, Longo PJ. Low-glycemic index carbohydrates: an effective behavioral change for glycemic control and weight management in patients with type 1 and 2 diabetes. Diabetes Educ. 2006;32:78-88. [pmid: 16439496].
Carrier KM, Steinhardt MA, Bowman S. Rethinking traditional weight management programs: a 3-year follow-up evaluation of a new approach. J Psychol. 94(128):517-35.
Chang WC, Hsiao CF, Chang HY, Lan TY, Hsiung CA, Shih YT, Tai TY. Betel nut chewing and other risk factors associated with obesity among Taiwanese male adults. International Journal of Obesity. 2006;30:359-363. [pmid: 16116491].
Charlton KE, Lambert EV, Kreft J. Physical activity, change in blood pressure and predictors of mortality in older South Africans--a 2-year follow-up study. S Afr Med J. 97(87):1124-30.
Chen CK, Chen YC, Huang YS. Effects of a 10-week weight control program on obese patients with schizophrenia or schizoaffective disorder: A 12-month follow up. Psychiatry Clin. Neurosci. 2009;63:17-22. [pmid: 19067997].
Chen YL, Liu YF, Huang CY, Lee SD, Chan YS, Chen CC, Harris B, Kuo CH. Normalization effect of sports training on blood pressure in hypertensives. Journal of sports sciences. 2010;28:361-7. [pmid: 20175014].
Cholewa Scott, Irwin Jennifer D. Project IMPACT: Brief report on a pilot programme promoting physical activity among university students. Journal of Health Psychology. 2008;13:1207-1212. [pmid: 18987094].
Clark Daniel O, Stump Timothy E, Damush Teresa M. Outcomes of an Exercise Program for Older Women Recruited Through Primary Care. Journal of Aging and Health. 2003;15:567-585. [pmid: 12914021].
Cleland VJ, Dwyer T, Venn A. J Physical activity and healthy weight maintenance from childhood to adulthood. Obesity (Silver Spring). 2008;16:1427-33. [pmid: 18421277].
Colucci A, Bianco A, Pomara F, et al. Disease management of type 2 diabetes: A follow-up analysis in a sanitary district of Sicily. Minerva Gastroenterol Dietol. 2011;57:241-6. [pmid: 21769074].
Cowart LW, Biro DJ, Wasserman T, Stein RF, Reider LR, Brown B. Designing and pilot-testing a church-based community program to reduce obesity among African Americans. ABNF J. 2010;21:4-10. [pmid: 20169806].
Cress M Elaine, Lewis Richard D, Flatt William. “Better 'n ever” changes with age: A 20-Year Case Study of Successful Aging. ACSM's Health & Fitness Journal. 2011;15:20-25.
de Fine Olivarius N, Richelsen B, Siersma V, Andreasen AH, Beck-Nielsen H. Weight history of patients with newly diagnosed Type 2 diabetes. Diabet Med. 2008;25:933-41. [pmid: 18959606].
Devine Carol M, Bove Caron F, Olson Christine M. Continuity and change in women's weight orientations and lifestyle practices through pregnancy and the postpartum period: The influence of life course trajectories and transitional events. Social Science & Medicine. 2000;50:567-582. [pmid: 10641808].
Dolfing JG, Dubois EF, Wolffenbuttel BHR, Ten Hoor-Aukema NM, Schweitzer DH. Different cycle ergometer outcomes in severely obese men and women without documented cardiopulmonary morbidities before bariatric surgery. Chest. 2005;128:256-262. [pmid: 16002944].
Dowell AC, Ochera JJ, Hilton SR, Bland JM, Harris T, Jones DR, Katbamna S. Prevention in practice: Results of a 2-year follow-up of routine health promotion interventions in general practice. FAM. PRACT. 96(13):357-362.
Dumith SC, Gigante DP, Domingues MR. Stages of change for physical activity in adults from Southern Brazil: a population-based survey. Int J Behav Nutr Phys Act. 2007;4:25. [pmid: 17555603].
Ellam LD, Fieldman GB, Garlick J, Goldsmith R, Pateman C. Initial training as a stimulus for optimal physical fitness in firemen. ERGONOMICS. 94(37):933-941.
Fitzpatrick P, Fitz-Simon N, Lonergan M, Collins C, Daly L. Heartwatch: the effect of a primary care-delivered secondary prevention programme for cardiovascular disease on medication use and risk factor profiles. Eur J Cardiovasc Prev Rehabil. 2010.
Flinn LB. The results of diet therapy vs insulin in the management of obese diabetics. Del Med J. 78(50):375-80.
Flint Kelsey M, Gilmour Walleghen, Van Emily L, Kealey Elizabeth H, VonKaenel Sandra, Bessesen Daniel H, Davy Brenda M. Differences in eating behaviors between nonobese, weight stable young and older adults. Eating Behaviors. 2008;9:370-375. [pmid: 18549998].
Fowles ER, Walker LO. Correlates of dietary quality and weight retention in postpartum women. Journal of Community Health Nursing. 2006;23:183-197. [pmid: 16863403].
Freak-Poli R, Wolfe R, Peeters A. Risk of cardiovascular disease and diabetes in a working population with sedentary occupations. J Occup Environ Med. 2010;52:1132-7. [pmid: 21063192].
Fries JF, Fries ST, Parcell CL, Harrington H. Health risk changes with a low-cost individualized health promotion program: Effects at up to 30 months. AM. J. HEALTH PROMOT. 92(6):364-371.
Fuemmeler Bernard F, Dedert Eric, McClernon F Joseph, Beckham Jean C. Adverse childhood events are associated with obesity and disordered eating: Results from a U.S. Population-based survey of young adults. Journal of Traumatic Stress. 2009;22:329-333. [pmid: 19588510].
Fulgoni VL 3rd. Current protein intake in America: analysis of the National Health and Nutrition Examination Survey, 2003-2004. Am J Clin Nutr. 2008;87:1554S-1557S. [pmid: 18469286].
Gapp O, Schweikert B, Meisinger C, Holle R. Disease management programmes for patients with coronary heart disease--an empirical study of German programmes. Health Policy. 2008;88:176-85. [pmid: 18442868].
Garden FL, Jalaludin BB. Impact of urban sprawl on overweight, obesity, and physical activity in Sydney, Australia. J Urban Health. 2009;86:19-30. [pmid: 19052877].
Gaullier JM, Halse J, Hoye K, Kristiansen K, Fagertun H, Vik H, Gudmundsen O. Supplementation with conjugated linoleic acid for 24 months is well tolerated by and reduces body fat mass in healthy, overweight humans. J Nutr. 2005;135:778-84. [pmid: 15795434].
Gavish D, Leibovitz E, Elly I, Shargorodsky M, Zimlichman R. Follow-up in a lipid clinic improves the management of risk factors in cardiovascular disease patients. Isr Med Assoc J. 2002;4:694-7. [pmid: 12440233].
Gilson Nicholas D, Puig-Ribera Anna, McKenna Jim, Brown Wendy J, Burton Nicola W, Cooke Carlton B. Do walking strategies to increase physical activity reduce reported sitting in workplaces: A randomized control trial. The International Journal of Behavioral Nutrition and Physical Activity. 2009;6.
Goodwin P, Esplen MJ, Butler K, Winocur J, Pritchard K, Brazel S, Gao J, Miller A. Multidisciplinary weight management in locoregional breast cancer: results of a phase II study. Breast Cancer Res Treat. 98(48):53-64.
Grabowski DC, Campbell CM, Ellis JE. Obesity and mortality in elderly nursing home residents. Journals of Gerontology Series A: Biological Sciences & Medical Sciences. 2005;60A:1184-1189.
Gulliford MC, Mahabir D. A five-year evaluation of intervention in diabetes care in Trinidad and Tobago. Diabetic Med. 99(16):939-945.
Hadden DR, Blair ALT, Wilson EA. Natural history of diabetes presenting age 40-69 years: A prospective study of the influence of intensive dietary therapy. Q. J. MED. 86(59):579-598.
Harb BM, Wonisch M, Brandt D, et al. Long-term risk factor management after inpatient cardiac rehabilitation by means of a structured post-care programme. Eur J Cardiovasc Prev Rehabil. 2011;18:843-9. [pmid: 21450590].
Harralson TL, Emig JC, Polansky M, Walker RE, Cruz JO, Garcia-Leeds C. Un Corazon Saludable: factors influencing outcomes of an exercise program designed to impact cardiac and metabolic risks among urban Latinas. J Community Health. 2007;32:401-12. [pmid: 17940871].
Harris N, Rosenberg A, Jangda S, O'Brien K, Gallagher ML. Prevalence of obesity in International Special Olympic athletes as determined by body mass index. Journal of the American Dietetic Association. 2003;103:235-237. [pmid: 12589332].
Harshman RS, Richerson GT, Hadker N, Greene BL, Brown TM, Foster TS, Turner BH, Skrepnek SH, Doyle JJ. Impact of a hypertension management/health promotion program on commercial driver's license employees of a self-insured utility company. J Occup Environ Med. 2008;50:359-65. [pmid: 18332786].
Haupt E, Herrmann R, Benecke-Timp A, Vogel H, Hilgenfeldt J, Haupt A, Walter C. The KID Study. III: Impact of inpatient rehabilitation on the metabolic control of type I and type II diabetics--a one-year follow-up. Exp Clin Endocrinol Diabetes. 96(104):420-30.
Haus G, Hoerr SL, Mavis B, Robison J. Key modifiable factors in weight maintenance: fat intake, exercise, and weight cycling. J Am Diet Assoc. 94(94):409-13. [pmid: 8144808].
Hessert MJ, Gugliucci MR, Pierce HR. Functional fitness: Maintaining or improving function for elders with chronic diseases. Fam. Med. 2005;37:472-476. [pmid: 15988642].
Hoffman DJ, Policastro P, Quick V, Lee S. Changes in body weight and fat mass of men and women in the first year of college: a study of the “Freshman 15”. Journal of American College Health. 2006;55:41-45. [pmid: 16889314].
Huberty Jennifer L, Vener Jamie, Schulte Laura, Roberts Sara M, Stevens Beth, Ransdell Lynda. Women bound to be active: One year follow-up to an innovative pilot intervention to increase physical activity and self-worth in women. Women & Health. 2009;49:522-539.
Hughes MC, Girolami TM, Cheadle AD, Harris JR, Patrick DL. A lifestyle-based weight management program delivered to employees: examination of health and economic outcomes. J Occup Environ Med. 2007;49:1212-7. [pmid: 17993925].
Jackson C, Coe A, Cheater FM, Wroe S. Specialist health visitor-led weight management intervention in primary care: exploratory evaluation. Journal of Advanced Nursing. 2007;58:23-34. [pmid: 17394613].
Jerome GJ, Rohm Young D, Dalcin A, Charleston J, Anthony C, Hayes J, Daumit GL. Physical activity levels of persons with mental illness attending psychiatric rehabilitation programs. Schizophr. Res. 2009;108:252-257. [pmid: 19157787].
John EJ, Vavra T, Farris K, Currie J, Doucette W, Button-Neumann B, Osterhaus M, Kumbera P, Halterman T, Bullock T. Workplace-based cardiovascular risk management by community pharmacists: impact on blood pressure, lipid levels, and weight. Pharmacotherapy. 2006;26:1511-7. [pmid: 16999661].
Johnson ST, McCargar LJ, Bell GJ, Tudor-Locke C, Harber VJ, Bell RC. Walking faster: distilling a complex prescription for type 2 diabetes management through pedometry. Diabetes Care. 2006;29:1654-1655. [pmid: 16801594].
Katon WJ, Lin EHB, Russo J, Von Korff M, Ciechanowski P, Simon G, Ludman E, Bush T, Young B. Cardiac risk factors in patients with diabetes mellitus and major depression. J. Gen. Intern. Med. 2004;19:1192-1199. [pmid: 15610329].
Kaufman H, Overton G, Leggott J, Clericuzio C. Prader-Willi syndrome: effect of group home placement on obese patients with diabetes. South Med J. 95(88):182-4.
Kenealy TW, Eggleton KS, Robinson EM, Sheridan NF. Systematic care to reduce ethnic disparities in diabetes care. Diabetes Res Clin Pract. 2010;89:256-61. [pmid: 20570383].
KESK-_N G, ENGIN E. DULGERLER &. Eating attitude in the obese patients: the evaluation in terms of relational factors. Journal of Psychiatric & Mental Health Nursing. 2010;17:900-908. [pmid: 21078005].
Kohrt WM, Ehsani AA, Birge SJ Jr. HRT preserves increases in bone mineral density and reductions in body fat after a supervised exercise program. Journal of Applied Physiology. 98(84):1506-1512.
Kourlaba G, Polychronopoulos E, Zampelas A, Lionis C, Panagiotakos DB. Development of a diet index for older adults and its relation to cardiovascular disease risk factors: the Elderly Dietary Index. J Am Diet Assoc. 2009;109:1022-30. [pmid: 19465184].
Lantz Paula M, House James S, Lepkowski James M, Williams David R, Mero Richard P, Chen Jieming. Socioeconomic factors, health behaviors, and mortality: Results from a nationally representative prospective study of US adults. JAMA: Journal of the American Medical Association. 98(279):1703-1708.
LeCheminant JD, Jacobsen DJ, Bailey BW, Mayo MS, Hill JO, Smith BK, Donnelly JE. Effects of long-term aerobic exercise on EPOC. Int J Sports Med. 2008;29:53-8. [pmid: 17879880].
Lee C, Dobson AJ, Brown WJ, Bryson L, Byles J, Warner-Smith P, Young AF. Cohort Profile: The Australian longitudinal study on Women's Health. Int. J. Epidemiol. 2005;34:987-991. [pmid: 15894591].
Lee Yin-Yang, Lin Julia L. The effects of trust in physician on self-efficacy, adherence and diabetes outcomes. Social Science & Medicine. 2009;68:1060-1068. [pmid: 19162386].
LEITH W. Experiences with the Pennington diet in the management of obesity. Can Med Assoc J. 61(84):1411-4.
Li F, Harmer PA, Cardinal BJ, Bosworth M, Acock A, Johnson-Shelton D, Moore JM. Built environment, adiposity, and physical activity in adults aged 50-75. Am J Prev Med. 2008;35:38-46. [pmid: 18541175].
Li F, Harmer P, Cardinal BJ, Bosworth M, Johnson-Shelton D. Obesity and the built environment: does the density of neighborhood fast-food outlets matter?. Am J Health Promot. 2009;23:203-9. [pmid: 19149426].
Lisspers J, Hofman-Bang C, Nordlander R, Ryden L, Sundin O, Ohman A, Nygren A. Multifactorial evaluation of a program for lifestyle behavior change in rehabilitation and secondary prevention of coronary artery disease. Scand Cardiovasc J. 99(33):9-16.
Loeppke R, Nicholson S, Taitel M, Sweeney M, Haufle V, Kessler RC. The impact of an integrated population health enhancement and disease management program on employee health risk, health conditions, and productivity. Popul Health Manag. 2008;11:287-96. [pmid: 19108644].
Logue EE, Jarjoura DG, Sutton KS, Smucker WD, Baughman KR, Capers CF. Longitudinal relationship between elapsed time in the action stages of change and weight loss. Obes Res. 2004;12:1499-508. [pmid: 15483215].
Long DA, Sheehan P. A case study of population health improvement at a Midwest regional hospital employer. Population Health Management. 2010;13:163-173. [pmid: 20521905].
Madsen J, Sallis JF, Rupp JW, Senn KL, Patterson TL, Atkins CJ, Nader PR. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. Patient education and counseling. 93(21):61-9.
Madsen June, Sallis James F, Rupp Joan W, Senn Karen L. Process variables as predictors of risk factor changes in a family health behavior change program. Health Education Research. 93(8):193-204.
Malcolm R, Riddle E, Currey HS, Sexauer JD. Behavior modification in the management of obesity. J S C Med Assoc. 77(73):197-9.
Markey Charlotte N, Markey Patrick M. Relations between body image and dieting behaviors: An examination of gender differences. Sex Roles. 2005;53:519-530.
Marshall DA, Walizer EM, Vernalis MN. Achievement of heart health characteristics through participation in an intensive lifestyle change program (Coronary Artery Disease Reversal Study). J Cardiopulm Rehabil Prev. 2009;29:84-94. quiz 95-6. [pmid: 19305232].
Martin KS, Ferris AM. Food insecurity and gender are risk factors for obesity. Journal of Nutrition Education & Behavior. 2007;39:31-36. [pmid: 17276325].
Matheson FI, Moineddin R, Glazier RH. The weight of place: a multilevel analysis of gender, neighborhood material deprivation, and body mass index among Canadian adults. Soc Sci Med. 2008;66:675-90. [pmid: 18036712].
Mathews G, Alexander J, Rahemtulla T, Bhopal R. Impact of a cardiovascular risk control project for South Asians (Khush Dil) on motivation, behaviour, obesity, blood pressure and lipids. Journal of Public Health. 2007;29:388-397. [pmid: 17673489].
Matsuda M, Akizuki M, Nishimoto O, et al. Cardiovascular risk management with liaison critical path in Japan: its effects on implementation of evidence-based prevention in practice. J Clin Med Res. 2012;4:102-9. [pmid: 22505982].
McConnon A, Kirk SF, Cockroft JE, Harvey EL, Greenwood DC, Thomas JD, Ransley JK, Bojke L. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res. 2007;7:206. [pmid: 18093289].
McLeod AL, Brooks L, Taylor V, Currie PF, Dewhurst NG. Secondary prevention for coronary artery disease. QJM. 2004;97:127-31. [pmid: 14976269].
McTigue Kathleen M, Conroy Molly B, Hess Rachel, Bryce Cindy L, Fiorillo Anthony B, Fischer Gary S, Milas N Carole, Simkin-Silverman Laurey R. Using the Internet to translate an evidence-based lifestyle intervention into practice. Telemedicine and e-Health. 2009;15:851-858. [pmid: 19919191].
Merrill RM, Anderson A, et al. Effectiveness of a worksite wellness program on health behaviors and personal health. J Occup Environ Med. 2011;53:1008-1012. [pmid: 21860328].
Milne Barry J, Belsky Jay, Poulton Richie, Thomson W Murray, Caspi Avshalom, Kieser Jules. Fluctuating asymmetry and physical health among young adults. Evolution and Human Behavior. 2003;24:53-63.
Miyatake N, Takahashi K, Wada J, Nishikawa H, Morishita A, Suzuki H, Kunitomi M, Makino H, Kira S, Fujii M. Daily exercise lowers blood pressure and reduces visceral adipose tissue areas in overweight Japanese men. Diabetes Research & Clinical Practice. 2003;62:149-157. [pmid: 14625129].
Morio B, Barra V, Ritz P, Fellmann N, Bonny JM, Beaufrere B, Boire JY, Vermorel M. Benefit of endurance training in elderly people over a short period is reversible. Eur. J. Appl. Physiol. 2000;81:329-336. [pmid: 10664093].
Mozaffarian D, Marfisi R, Levantesi G, Silletta MG, Tavazzi L, Tognoni G, Valagussa F, Marchioli R. Incidence of new-onset diabetes and impaired fasting glucose in patients with recent myocardial infarction and the effect of clinical and lifestyle risk factors. Lancet. 2007;370:667-75. [pmid: 17720018].
Munsch Simone, Meyer Andrea H, Margraf Jürgen. Weight control with orlistat in a telephone-counseling program. Swiss Journal of Psychology/Schweizerische Zeitschrift für Psychologie/Revue Suisse de Psychologie. 2007;66:235-241.
Muros Molina JJ, Oliveras Lopez MJ, Mayor Reyes M, et al. Influence of physical activity and dietary habits on lipid profile, blood pressure and BMI in subjects with metabolic syndrome. Nutr Hosp. 2011;26:1105-9. [pmid: 22072359].
Murphy JM, Horton NJ, Burke JD Jr, Monson RR, Laird NM, Lesage A, Sobol AM. Obesity and weight gain in relation to depression: findings from the Stirling County Study. Int J Obes (Lond). 2009;33:335-41. [pmid: 19139752].
Neutel CI, Campbell NR. Changes in lifestyle after hypertension diagnosis in Canada. Can J Cardiol. 2008;24:199-204. [pmid: 18340389].
Nishigaki M, Kobayashi K, Abe Y, Seki N, Yokomura T, Yokoyama M, Kazuma K. Preventive behaviour in adult offspring of Type 2 diabetic patients and its relationship to parental advice. Diabet Med. 2008;25:1343-8. [pmid: 19046226].
Nothwehr F, Peterson NA. Healthy eating and exercise: strategies for weight management in the rural midwest. Health Educ Behav. 2005;32:253-63. [pmid: 15749970].
Nunn RG, Newton KS, Faucher P. 2.5 years follow-up of weight and Body Mass Index values in the Weight Control for Life! program: a descriptive analysis. Addict Behav. 92(17):579-85.
Orsega-Smith Elizabeth, Mowen Andrew J, Payne Laura L, Godbey Geoffrey. The Interaction of Stress and Park Use on Psycho-physiological Health in Older Adults. Journal of Leisure Research. 2004;36:232-256.
Ovbiosa-Akinbosoye OE, Long DA. Factors associated with long-term weight loss and weight maintenance: Analysis of a comprehensive workplace wellness program. J Occup Environ Med. 2011;53:1236-1242. [pmid: 22005396].
Payne WR, Walsh KJ, Harvey JT, Livy MF, McKenzie KJ, Donaldson A, Atkinson MG, Keogh JB, Moss RS, Dunstan DW, Hubbard WA. Effect of a low-resource-intensive lifestyle modification program incorporating gymnasium-based and home-based resistance training on type 2 diabetes risk in australian adults. Diabetes Care. 2008;31:2244-2250. [pmid: 18796621].
Phelan Suzanne, Wing Rena R, Raynor Hollie A, Dibello Julia, Nedeau Kim, Peng Wanfeng. Holiday weight management by successful weight losers and normal weight individuals. Journal of Consulting and Clinical Psychology. 2008;76:442-448. [pmid: 18540737].
Pratt DS, Jandzio M, Tomlinson D, Kang X, Smith E. The 5-10-25 challenge: an observational study of a web-based wellness intervention for a global workforce. Disease Management. 2006;9:284-290. [pmid: 17044762].
Rapoport L, Clark M, Wardle J. Evaluation of a modified cognitive-behavioural programme for weight management. Int J Obes Relat Metab Disord. 2000;24:1726-37. [pmid: 11126231].
Read A, Ramwell H, Strorer H, Webber J. A primary care intervention programme for obesity and coronary heart disease risk factor reduction. Br. J. Gen. Pract. 2004;54:272-278. [pmid: 15113494].
Ready AE. Walking program maintenance in women with elevated serum cholesterol. BEHAV. MED. 96(22):23-31.
Reedy Jill, Haines Pamela S, Campbell Marci Kramish. The influence of health behavior clusters on dietary change. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2005;41:268-275.
Richards EL, Riner ME, Sands LP. A social ecological approach of community efforts to promote physical activity and weight management. J Community Health Nurs. 2008;25:179-92. [pmid: 18979329].
Rogers H, Turner E, Thompson G, Hopkins D, Amiel SA. Hub-and-spoke model for a 5-day structured patient education programme for people with Type 1 diabetes. Diabet. Med. 2009;26:915-920. [pmid: 19719713].
Rosmond R, Bj+¦rntorp P. Quality of life, overweight, and body fat distribution in middle-aged men. Behavioral Medicine. 2000;26(2):90-4. [pmid: 11147295].
Sandhu MS, Gibson JM, Heald AH, Dunger DB, Wareham NJ. Low circulating IGF-II concentrations predict weight gain and obesity in humans. Diabetes. 2003;52:1403-1408. [pmid: 12765950].
Schadlich S, Boldemann RD, Blankenburg T, Schutte W. Weight changes under long-term CPAP therapy - A retrospective analysis of 244 patients: Gewichtsveranderung unter langfristiger CPAP-therapie - Eine retrospektive analyse an 244 patienten. Somnologie. 2006;10:15-20.
Schmeiser MD. Expanding wallets and waistlines: the impact of family income on the BMI of women and men eligible for the Earned Income Tax Credit. Health Econ. 2009;18:1277-94. [pmid: 19142860].
Schmitz K, French SA, Jeffery RW. Correlates of changes in leisure time physical activity over 2 years: the Healthy Worker Project. Preventive Medicine. 97(26):570-579.
Singleton Steven P, Neale Anne V, Hess Joseph W, Dupuis Mary H. Behavioral contracting in an urban health promotion project. Evaluation & the Health Professions. 87(10):408-437.
Smith KE, Levine BA, Clement SC, Hu M, Alaoui A, Mun SK. Impact of MYCARETEAM for poorly controlled diabetes mellitus. Diabetes Technology & Therapeutics. 2004;6:828-835. [pmid: 15684636].
Smith Shubulade, Yeomans David Bushe, Chris JP, Eriksson Cecilia, Harrison Tom, Holmes Robert, Mynors-Wallis Laurence, Oatway Helen, Sullivan Gary. A well-being programme in severe mental illness. Reducing risk for physical ill-health: A post-programme service evaluation at 2 years. European Psychiatry. 2007;22:413-418. [pmid: 17765483].
Smith T, Hawks SR. Intuitive eating, diet composition, and the meaning of food in healthy weight promotion. American Journal of Health Education. 2006;37:130-136.
Stellfeldt A, Muller MJ, Bode V, Westenhofer J. Behaviour factors and stabilisation of reduced body weight over one year: Verhaltensfaktoren und stabilisierung des reduzierten korpergewichts uber ein jahr. Aktuel. Ernahr. Med. 2000;25:281-288.
Sutliffe Jay T, Carnot Mary Jo. Cardiovascular risk reduction among college students. Family and Consumer Sciences Research Journal. 2011;39:256-266.
Swift Judy Anne, Glazebrook Cris, Anness Abigail, Goddard Rebecca. Obesity-related knowledge and beliefs in obese adults attending a specialist weight-management service: Implications for weight loss over 1. Patient Education and Counseling. 2009;74:70-76. [pmid: 18804936].
Tang TS, Funnell MM, Brown MB, Kurlander JE. Self-management support in “real-world” settings: an empowerment-based intervention. Patient Educ Couns. 2010;79:178-84. [pmid: 19889508].
Thomas J. Look after yourself: monitoring the effects of a campaign. J Hum Nutr. 79(33):376-82.
Thorndike Anne N, Healey Erica, Sonnenberg Lillian, Regan Susan. Participation and cardiovascular risk reduction in a voluntary worksite nutrition and physical activity program. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2011;52:164-166.
Tredan O, Bajard A, Meunier A, Roux P, Fiorletta I, Gargi T, Bachelot T, Guastalla JP, Lallemand Y, Faure C, Perol D, Bachmann P. Body weight change in women receiving adjuvant chemotherapy for breast cancer: a French prospective study. Clin Nutr. 2010;29:187-91. [pmid: 19713014].
Troumbley Patricia F, Lenz Elizabeth R. Application of Cox's Interaction Model of Client Health Behavior in a weight control program for military personnel: A preintervention baseline. Advances in Nursing Science. 92(14):65-78.
Uusi-Rasi K, Sievanen H, Pasanen M, Oja P, Vuori I. Maintenance of body weight, physical activity and calcium intake helps preserve bone mass in elderly women. Osteoporosis Int. 2001;12:373-379.
Verheijden MW, van Dommelen P, van Empelen P, et al. Changes in self-reported energy balance behaviours and body mass index during a mass media campaign. Fam Pract. 2012;29(Suppl 1):i75-i81. [pmid: 22399561].
Voskuil DW, van Nes JGH, Junggeburt JMC, van de Velde CJH, van Leeuwen FE, de Haes JCJM. Maintenance of physical activity and body weight in relation to subsequent quality of life in postmenopausal breast cancer patients. Ann. Oncol. 2010;21:2094-2101. [pmid: 20357033].
Wall JR, Pyke DA, Oakley WG. Effect of carbohydrate restriction in obese diabetics: relationship of control to weight loss. British medical journal. 73(1):577-8.
Walsh MN, Simpson RJ, Wan GJ, Weiss TW, Alexander CM, Markson LE, Berger ML, Pearson TA. Do disease management programs for patients with coronary heart disease make a difference? Experiences of nine practices. American Journal of Managed Care. 2002;8:937-946. [pmid: 12437309].
Wammes B, Breedveld B, Looman C, Brug J. The impact of a national mass media campaign in The Netherlands on the prevention of weight gain. Public Health Nutr. 2005;8:1250-7. [pmid: 16372920].
Weinsier RL, Johnston MH, Doleys DM, Bacon JA. Dietary management of obesity: evaluation of the time-energy displacement diet in terms of its efficacy and nutritional adequacy for long-term weight control. Br J Nutr. 82(47):367-79.
Weinstock RS, Brooks G, Palmas W, et al. Lessened decline in physical activity and impairment of older adults with diabetes with telemedicine and pedometer use: results from the IDEATel study. Age Ageing. 2011;40:98-105. [pmid: 21081539].
Westerterp KR, Plasqui G. Physically active lifestyle does not decrease the risk of fattening. PLoS One. 2009;4:e4745. [pmid: 19270740].
Wilcox S, Dowda M, Wegley S, Ory MG. Maintenance of change in the Active-for-Life initiative. Am J Prev Med. 2009;37:501-4. [pmid: 19944915].
Witten K, Hiscock R, Pearce J, Blakely T. Neighbourhood access to open spaces and the physical activity of residents: a national study. Prev Med. 2008;47:299-303. [pmid: 18533242].
Wolfe WS, Sobal J, Olson CM, Frongillo EA Jr, Williamson DF. Parity-associated weight gain and its modification by sociodemographic and behavioral factors: a prospective analysis in US women. Int J Obes Relat Metab Disord. 97(21):802-10.
Wong CH, Wong SF, Yusoff AM, Karunananthan S, Bergman H. The effect of later-life health promotion on functional performance and body composition. Aging Clin. Exp. Res. 2008;20:454-460. [pmid: 19039288].

## Study does not report outcomes by exposure

UK Prospective Diabetes Study (UKPDS). VIII. Study design, progress and performance. Diabetologia. 91(34):877-90.
Ahn S, Zhao H, Smith ML, Ory MG, Phillips CD. BMI and lifestyle changes as correlates to changes in self-reported diagnosis of hypertension among older Chinese adults. J. Am. Soc. Hypertens. 2011;5:21-30. [pmid: 21273158].
Anderson-Bill ES, Winett RA, Wojcik JR. Social cognitive determinants of nutrition and physical activity among web-health users enrolling in an online intervention: the influence of social support, self-efficacy, outcome expectations, and self-regulation. J Med Internet Res. 2011;13:e28. [pmid: 21441100].
Ball K, Burton NW, Brown WJ. A prospective study of overweight, physical activity, and depressive symptoms in young women. Obesity (Silver Spring). 2009;17:66-71. [pmid: 18997676].
Ball Kylie, Burton Nicola W, Brown Wendy J. A prospective study of overweight, physical activity, and depressive symptoms in young women. Obesity. 2009;17:66-71. [pmid: 18997676].
Baltrus PT, Lynch JW, Everson-Rose S, Raghunathan TE, Kaplan GA. Race/ethnicity, life-course socioeconomic position, and body weight trajectories over 34 years: the Alameda County Study. Am J Public Health. 2005;95:1595-601. [pmid: 16051936].
Banks E. Cohort profile: The 45 and up study. Int. J. Epidemiol. 2008;37:941-947. [pmid: 17881411].
Brown H, Roberts J. Exercising choice: The economic determinants of physical activity behaviour of an employed population. Soc Sci Med. 2011;73:383-90. [pmid: 21757272].
Brown Wendy J, Trost Stewart G. Life Transitions and Changing Physical Activity Patterns in Young Women. American Journal of Preventive Medicine. 2003;25:140-143. [pmid: 12880882].
Burke Valerie, Beilin Lawrie J, Dunbar Diana, Kevan Melodie. Changes in health-related behaviours and cardiovascular risk factors in young adults: Associations with living with a partner. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2004;39:722-730.
Caan B, Armstrong MA, Selby JV, Sadler M, Folsom AR, Jacobs D, Slattery ML, Hilner JE, Roseman J. Changes in measurements of body fat distribution accompanying weight change. INT. J. OBES. 94(18):397-404.
Campbell PT, Campbell KL, Wener MH, Wood BL, Potter JD, McTiernan A, Ulrich CM. A yearlong exercise intervention decreases CRP among obese postmenopausal women. Medicine and science in sports and exercise. 2009;41:1533-9. [pmid: 19568208].
Caporaso F, Frisch F, Sumida KD. Compromised Bone Health in Non-Obese, Older Women with Low Caloric Intake. J Community Health. 2010.
Carr Lucas J, Bartee R Todd, Dorozynski Chris M, Broomfield James F, Smith Marci L, Smith Derek T. Eight-month follow-up of physical activity and central adiposity: Results from an Internet-delivered randomized control trial intervention. Journal of Physical Activity & Health. 2009;6:444-455. [pmid: 19842458].
Carroll Dianna D, Blanck Heidi M, Serdula Mary K, Brown David R. Obesity, physical activity, and depressive symptoms in a cohort of adults aged 51 to 61. Journal of Aging and Health. 2010;22:384-398. [pmid: 20164412].
Chapman KM, Ham JO, Pearlman RA. Longitudinal assessment of the nutritional status of elderly veterans. J Gerontol A Biol Sci Med Sci. 96(51):B261-9.
Charlton KE, Lambert EV, Kreft J. Physical activity, change in blood pressure and predictors of mortality in older South Africans--a 2-year follow-up study. S Afr Med J. 97(87):1124-30.
Cohen SS, Larson CO, Matthews CE, Buchowski MS, Signorello LB, Hargreaves MK, Blot WJ. Parity and breastfeeding in relation to obesity among black and white women in the southern community cohort study. J Womens Health (Larchmt). 2009;18:1323-32. [pmid: 19743905].
Colucci A, Bianco A, Pomara F, et al. Disease management of type 2 diabetes: A follow-up analysis in a sanitary district of Sicily. Minerva Gastroenterol Dietol. 2011;57:241-6. [pmid: 21769074].
Crawford D, Owen N, Broom D, Worcester M, Oliver G. Weight-control practices of adults in a rural community. Aust N Z J Public Health. 98(22):73-9.
Czernichow S, Mennen L, Bertrais S, Preziosi P, Hercberg S, Oppert JM. Relationships between changes in weight and changes in cardiovascular risk factors in middle-aged French subjects: effect of dieting. Int J Obes Relat Metab Disord. 2002;26:1138-43. [pmid: 12119581].
Folsom AR, Jensen MD, Jacobs DR Jr, Hilner JE, Tsai AW, Schreiner PJ. Serum leptin and weight gain over 8 years in African American and Caucasian young adults. Obes Res. 99(7):1-8.
Ford Denyce S, Goode Carolyn R. African American college students' health behaviors and perceptions of related health issues. Journal of American College Health. 94(42):206-210.
Frable PJ, Dart L, Bradley PJ. Healthy Weigh (El camino saludable) phase 1: a retrospective critical examination of program evaluation. Prev Chronic Dis. 2006;3:A98. [pmid: 16776899].
Ghorob A, Vivas MM, De Vore D, Ngo V, Bodenheimer T, Chen E, Thom DH. The effectiveness of peer health coaching in improving glycemic control among low-income patients with diabetes: protocol for a randomized controlled trial. BMC Public Health. 2011;11:208. [pmid: 21457567].
Gilliland FD, Li YF, Baumgartner K, Crumley D, Samet JM. Physical activity and breast cancer risk in hispanic and non-hispanic white women. Am. J. Epidemiol. 2001;154:442-450. [pmid: 11532786].
Heath Gregory W, Brown David W. Recommended levels of physical activity and health-related quality of life among overweight and obese adults in the United States, 2005. Journal of Physical Activity & Health. 2009;6:403-411. [pmid: 19842453].
Herman Katya M, Craig Cora L, Gauvin Lise, Katzmarzyk Peter T. Tracking of obesity and physical activity from childhood to adulthood: The Physical Activity Longitudinal Study. International Journal of Pediatric Obesity. 2009;4:281-288. [pmid: 19922043].
Jilcott SB, Keyserling TC, Samuel-Hodge CD, Rosamond W, Garcia B, Will JC, Farris RP, Ammerman AS. Linking clinical care to community resources for cardiovascular disease prevention: The North Carolina enhanced WISEWOMAN project. J. Women's Health. 2006;15:569-583.
Kirjonen J, Telama R, Luukkonen R, Kaaria S, Kaila-Kangas L, Leino-Arjas P. Stability and prediction of physical activity in 5-, 10-, and 28-year follow-up studies among industrial employees. Scandinavian Journal of Medicine & Science in Sports. 2006;16:201-208. [pmid: 16643199].
Leitzmann Michael F, Rimm Eric B, Willett Walter C, Spiegelman Donna, Grodstein Francine, Stampfer Meir J, Colditz Graham A, Giovannucci Edward. Recreational physical activity and the risk of cholecystectomy in women. The New England Journal of Medicine. 99(341):777-784.
Li G, Hu Y, Yang W, Jiang Y, Wang J, Xiao J, Hu Z, Pan X, Howard BV, Bennett PH, DA Qing IGT, Diabetes Study. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes research and clinical practice. 2002;58:193-200. [pmid: 12413779].
Littman AJ, Jacobson IG, Boyko EJ, et al. Weight change following US military service. Int J Obes. 2012. Epub ahead of print.
McTiernan A, Tworoger SS, Rajan KB, Yasui Y, Sorenson B, Ulrich CM, Chubak J, Stanczyk FZ, Bowen D, Irwin ML, Rudolph RE, Potter JD, Schwartz RS. Effect of exercise on serum androgens in postmenopausal women: a 12-month randomized clinical trial. Cancer epidemiology, biomarkers & prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2004;13:1099-105.
Mitchell SD, Eide R, Olsen CH, Stephens MB. Body composition and physical fitness in a cohort of US military medical students. J Am Board Fam Med. 2008;21:165-7. [pmid: 18343867].
Mozaffarian D, Marfisi R, Levantesi G, Silletta MG, Tavazzi L, Tognoni G, Valagussa F, Marchioli R. Incidence of new-onset diabetes and impaired fasting glucose in patients with recent myocardial infarction and the effect of clinical and lifestyle risk factors. Lancet. 2007;370:667-75. [pmid: 17720018].
Nafziger AN, Lindvall K, Norberg M, Stenlund H, Wall S, Jenkins PL, Pearson TA, Weinehall L. Who is maintaining weight in a middle-aged population in Sweden? A longitudinal analysis over 10 years. BMC Public Health. 2007;7:108. [pmid: 17565692].
Neutel CI, Campbell NRC. Changes in lifestyle after hypertension diagnosis in Canada. Can. J. Cardiol. 2008;24:199-204. [pmid: 18340389].
Neutel CI, Campbell NR. Changes in lifestyle after hypertension diagnosis in Canada. Can J Cardiol. 2008;24:199-204. [pmid: 18340389].
Nilsson Peter M, Klasson Eva-Birgitta, Nyberg Per. Life-style intervention at the worksite--reduction of cardiovascular risk factors in a randomized study. Scandinavian Journal of Work, Environment & Health. 2001;27:57-62.
Nitzke SA, Voichick SJ, Olson D. Weight Cycling Practices and Long-term Health Conditions in a Sample of Former Wrestlers and Other Collegiate Athletes. J Athl Train. 92(27):257-61.
Pollock ML, Foster C, Knapp D. Effect of age and training on aerobic capacity and body composition of master athletes. J. APPL. PHYSIOL. 87(62):725-731.
Poortinga Wouter. Perceptions of the environment, physical activity, and obesity. Social Science & Medicine. 2006;63:2835-2846. [pmid: 16952415].
Roos E, Sarlio-Lahteenkorva S, Lallukka T. Having lunch at a staff canteen is associated with recommended food habits. Public Health Nutr. 2004;7:53-61. [pmid: 14972072].
Senekal Marjanne, Steyn Nelia Patricia, Mashego Teresa-Ann B, Nel Johanna Helena. Evaluation of body shape, eating disorders and weight management related parameters in black female students of rural and urban origins. South African Journal of Psychology. 2001;31:45-53.
Shai I, Jiang R, Manson JE, Stampfer MJ, Willett WC, Colditz GA, Hu FB. Ethnicity, obesity, and risk of type 2 diabetes in women: a 20-year follow-up study. Diabetes Care. 2006;29:1585-1590. [pmid: 16801583].
Tsujimoto T, Sairenchi T, Iso H, et al. Impact of obesity on incident hypertension independent of weight gain among nonhypertensive Japanese: the Ibaraki Prefectural Health Study (IPHS). J Hypertens. 2012;30:1122-8. [pmid: 22487734].
Ulijaszek SJ. Trends in body size, diet and food availability in the Cook Islands in the second half of the 20th century. Econ. Hum. Biol. 2003;1:123-137. [pmid: 15463968].
Uusi-Rasi K, Sievanen H, Pasanen M, Oja P, Vuori I. Maintenance of body weight, physical activity and calcium intake helps preserve bone mass in elderly women. Osteoporosis Int. 2001;12:373-379.
Voskuil DW, van Nes JGH, Junggeburt JMC, van de Velde CJH, van Leeuwen FE, de Haes JCJM. Maintenance of physical activity and body weight in relation to subsequent quality of life in postmenopausal breast cancer patients. Ann. Oncol. 2010;21:2094-2101. [pmid: 20357033].
Voskuil DW, van Nes JGH, Junggeburt JMC, van de Velde CJH, van Leeuwen FE, de Haes JCJM. Maintenance of physical activity and body weight in relation to subsequent quality of life in postmenopausal breast cancer patients. Ann. Oncol. 2010;21:2094-2101. [pmid: 20357033].
Wall JR, Pyke DA, Oakley WG. Effect of carbohydrate restriction in obese diabetics: relationship of control to weight loss. British medical journal. 73(1):577-8.
Wanner M, Martin-Diener E, Braun-Fahrländer C. Effectiveness of active-online, an individually tailored physical activity intervention, in a real-life setting: randomized controlled trial. Journal of medical Internet research. 2009;11:23.
Weinstein AR, Sesso HD, Lee IM, Rexrode KM, Cook NR, Manson JE, Buring JE, Gaziano JM. The joint effects of physical activity and body mass index on coronary heart disease risk in women. Archives of internal medicine. 2008;168:884-90. [pmid: 18443265].
Zunft HJ, Friebe D, Seppelt B, Widhalm K, Remaut de Winter AM, Vaz de Almeida MD, Kearney JM, Gibney M. Perceived benefits and barriers to physical activity in a nationally representative sample in the European Union. Public Health Nutr. 99(2):153-60.

## Qualitative study

Allan JD. Women who successfully manage their weight. West J Nurs Res. 89(11):657-69. discussion 669-75.
Dietz W. Focus group data pertinent to the prevention of obesity in African Americans. Am J Med Sci. 2001;322:275-8. [pmid: 11721801].
Duckworth WC. Intensive management of type II diabetes. Hosp Pract (Off Ed). 91(26):65-8. 73. 6. 79. 85.
Engler-Stringer R. The domestic foodscapes of young low-income women in Montreal: cooking practices in the context of an increasingly processed food supply. Health Education & Behavior. 2010;37:211-226. [pmid: 19690290].
Liou D, Bauer KD. Exploratory investigation of obesity risk and prevention in Chinese Americans. J Nutr Educ Behav. 2007;39:134-41. [pmid: 17493563].
Managing PraderGÇôWilli syndrome in families: An embodied exploration. Social Science & Medicine. 2011;72(4):460-8. [pmid: 21216515].
O'Dougherty Maureen, Dallman Amber, Turcotte Lucie, Patterson Joan, Napolitano Melissa A, Schmitz Kathryn H. Barriers and motivators for strength training among Women of Color and Caucasian women. Women & Health. 2008;47:41-62.
Roessler Kirsten Kaya, Ibsen Bjarne. Promoting exercise on prescription: Recruitment, motivation, barriers and adherence in a Danish community intervention study to reduce type 2 diabetes, dyslipidemia and hypertension. Journal of Public Health. 2009;17:187-193.
Rohrer James E, Barnes Darryl E, Adamson Steven C, Altrichter Paul M, Yapuncich Victor P. Limited stair-climbing ability and weight control in family medicine patients. Chronic Illness. 2008;4:183-187. [pmid: 18796507].
Thomas J. Look after yourself: monitoring the effects of a campaign. J Hum Nutr. 79(33):376-82.
Thornton PL, Kieffer EC, Salabarria-Pena Y, Odoms-Young A, Willis SK, Kim H, Salinas MA. Weight, diet, and physical activity-related beliefs and practices among pregnant and postpartum Latino women: the role of social support. Matern Child Health J. 2006;10:95-104. [pmid: 16534660].
Vincent Deborah. Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. Journal of the American Academy of Nurse Practitioners. 2009;21:520-527. [pmid: 19845810].
Walsh JR, White AA, Greaney ML. Using focus groups to identify factors affecting healthy weight maintenance in college men. Nutr Res. 2009;29:371-8. [pmid: 19628102].
Whitfield-Brown L, Hamer O, Ellahi B, Burden S, Durrington P. An investigation to determine the nutritional adequacy and individuals experience of a very low fat diet used to treat type V hypertriglyceridaemia. J Hum Nutr Diet. 2009;22:232-8. [pmid: 19504738].
Ziebland S, Robertson J, Jay J, Neil A. Body image and weight change in middle age: a qualitative study. Int J Obes Relat Metab Disord. 2002;26:1083-91. [pmid: 12119574].

## Study population at risk for malnourishment or underweight

Borgonha S, Shetty PS, Kurpad AV. Total energy expenditure & physical activity level in chronically energy deficient Indian males measured by the doubly labelled water technique. Indian J Med Res. 2000;111:138-46. [pmid: 10935321].
Chapman KM, Ham JO, Pearlman RA. Longitudinal assessment of the nutritional status of elderly veterans. J Gerontol A Biol Sci Med Sci. 96(51):B261-9.
Heyn P. The effect of a multisensory exercise program on engagement, behavior, and selected physiological indexes in persons with dementia. Am. J. Alzheimer's Dis. Other Dem. 2003;18:247-251.
Lee P, Greenfield JR, Day RO, Ho KK. Weight maintenance in hospitalized geriatric patients treated with beta-blockers. Journal of the American Geriatrics Society. 2009;57:1125-1126. [pmid: 19490254].
Risonar MG, Rayco-Solon P, Ribaya-Mercado JD, Solon JA, Cabalda AB, Tengco LW, Solon FS. Physical activity, energy requirements, and adequacy of dietary intakes of older persons in a rural Filipino community. Nutr J. 2009;8:19. [pmid: 19409110].
Sharkey JR, Branch LG, Giuliani C, Zohoori M, Haines PS. Nutrient intake and BMI as predictors of severity of ADL disability over 1 year in homebound elders. J Nutr Health Aging. 2004;8:131-9. [pmid: 15129297].
Zhu K, Devine A, Suleska A, Tan CY, Toh CZ, Kerr D, Prince RL. Adequacy and change in nutrient and food intakes with aging in a seven-year cohort study in elderly women. J Nutr Health Aging. 2010;14:723-9. [pmid: 21085900].

## No original data

McPolicy: bringing you the Big Mac society. Lancet. 2010;376:1800.
Obesity prevention and control legal bibliography. J Law Med Ethics. Suppl 1. 2009;37:122-8. [pmid: 19493098].
The Oslo Diet and Exercise Study (ODES): design and objectives. Controlled clinical trials. 93(14):229-43.
Abete I, Astrup A, Mart+¡nez J, Thorsdottir I, Zulet M. Obesity and the metabolic syndrome: role of different dietary macronutrient distribution patterns and specific nutritional components on weight loss and maintenance. Nutrition Reviews. 2010;68(4):214-31. [pmid: 20416018].
Alvaro C, Jackson LA, Kirk S, McHugh TL, Hughes J, Chircop A, Lyons RF. Moving Canadian governmental policies beyond a focus on individual lifestyle: some insights from complexity and critical theories. Health Promotion International. 2011;26:91-99. [pmid: 20709791].
Bestermann WH Jr. Incorporating practical lifestyle management for obesity. J Fam Pract. 2010;59:S3-8. [pmid: 20544055].
Blundell JE. Behaviour modification and exercise in the treatment of obesity. Postgrad Med J. Suppl 3. 84(60):37-49.
Bowerman S. Meal replacements for weight management. Carefully chosen bars and shakes can be valuable. Adv Nurse Pract. 2006;14:37-9. 65. [pmid: 16972486].
Brink PJ. The myth of low-fat diets. West J Nurs Res. 2001;23:561-2. [pmid: 11569329].
Burleson WE. Giving health a place at the table Two years of progress on Minnesota's obesity plan. Minn Med. 2010;93:47-9. [pmid: 20827956].
Cahill A, Lean ME. Review article: malnutrition and maltreatment--a comment on orlistat for the treatment of obesity. Aliment Pharmacol Ther. 99(13):997-1002.
Chaufan C, Hong GH, and Fox P. “Sin-food” taxes and sugar-sweetened beverages--the right policy for the wrong reasons?. Am J Health Promot. 2010;25:87-90. [pmid: 21039287].
Coney S. New Zealand diet causes premature deaths. Lancet. 2003;362:544. [pmid: 12938667].
Crawford D, Owen N. The behavioural epidemiology of weight control. Aust J Public Health. 94(18):143-8.
Creighton R. Fat taxes: the newest manifestation of the age-old excise tax. J Leg Med. 2010;31:123-36. [pmid: 20391035].
Dinneen SF, O' Hara MC, Byrne M, Newell J, Daly L, O' Shea D, Smith D. The Irish DAFNE Study Protocol: A cluster randomised trial of group versus individual follow-up after structured education for type 1 diabetes. Trials. 2009;10:88. [pmid: 19775465].
Doucet E, Tremblay A. Body weight loss and maintenance with physical activity and diet. Coron Artery Dis. 98(9):495-501.
Duckworth WC. Intensive management of type II diabetes. Hosp Pract (Off Ed). 91(26):65-8. 73. 6. 79. 85.
Faulkner G, Cohn T, Remington G. Interventions to reduce weight gain in schizophrenia. Schizophr Bull. 2007;33:654-6. [pmid: 17449900].
Fitzgerald G. Weight management and fitness in the community. J R Soc Health. 96(116):264-5.
Fletcher JM, Frisvold D, Tefft N. Can Soft Drink Taxes Reduce Population Weight?. Contemp Econ Policy. 2010;28:23-35. [pmid: 20657817].
Fore A. Calorie labeling and obesity. Health Aff (Millwood). 2010;29:219. [pmid: 20048380].
Gautier JF, Oppert JM. Role of physical activity in the management of the obese patient. Soins. 2004:9-12. [pmid: 15151085].
Gibney MJ, Flynn A, Livingstone MBE, McCarthy SN. Overweight, obesity and physical activity levels in Irish adults: Evidence from the North/South Ireland Food Consumption Survey. Proc. Nutr. Soc. 2002;61:3-7. [pmid: 12002792].
Gibson SA. Are diets high in non-milk extrinsic sugars conducive to obesity? An analysis from the Dietary and Nutritional Survey of British Adults. J Hum Nutr Diet. 2007;20:229-38. [pmid: 17539875].
Gorton KJ. Seeds sown for first farm bill of 21st century. J Am Diet Assoc. 2001;101:1001. [pmid: 11573749].
Green CG, Klein EG. Promoting active transportation as a partnership between urban planning and public health: the columbus healthy places program. Public Health Rep. Suppl 1. 2011;126:41-9. [pmid: 21563711].
Hawkes N. National obesity strategy: what's the big idea?. BMJ. 2008;337:a2548. [pmid: 19017715].
Hawley JA, Dunstan DW. Overweight and obesity in Australia. Med J Aust. 2008;188:678. discussion 678-9. [pmid: 18513183].
Henderson MJ, Sadlier K, Currie BG. Obesity in older adults. A major contributor to chronicity. Adv Nurse Pract. 2006;14:63-6. [pmid: 16972429].
Huang TT, Glass TA. Transforming research strategies for understanding and preventing obesity. JAMA. 2008;300:1811-3. [pmid: 18854544].
Hunt SM. Nutrition and maintenance of cardiovascular health. J Med Assoc Ga. 80(69):43-5.
Johnson L, Perkin S. An empowering approach to weight management. J R Soc Promot Health. 2008;128:15-6. [pmid: 18274322].
Johnson RK, Yon BA. Weighing in on added sugars and health. J Am Diet Assoc. 2010;110:1296-9. [pmid: 20800119].
Kamerow D. The case of the sugar sweetened beverage tax. BMJ. 2010;341:c3719. [pmid: 20630952].
Keane M. Taxing sugar-sweetened beverages. N Engl J Med. 2010;362:368-9. [pmid: 20112448].
Kennedy RL, Malabu U, Kazi M, Shahsidhar V. Management of obesity in the elderly: too much and too late?. J Nutr Health Aging. 2008;12:608-21. [pmid: 18953458].
Knott J, Cavan D, Kerr D. Transfer of a diabetes education programme to primary care. Journal of Diabetes Nursing. 2005;9:373-376.
Kohli HS. Obesity. Natl Med J India. 2010;23:304. [pmid: 21250589].
Kwatra SG. Physical activity and preventing weight gain in women. JAMA. 2010;303:2475-6. author reply 2476. [pmid: 20571011].
Kwatra SG. Physical activity and preventing weight gain in women. JAMA: Journal of the American Medical Association. 2010;303:2475-2476.
Kyrou Ioannis, Kumar Sudhesh. Weight management in overweight and obese patients with type 2 diabetes mellitus. British Journal of Diabetes & Vascular Disease. 2010;10:274-283.
Lee C, Dobson AJ, Brown WJ, Bryson L, Byles J, Warner-Smith P, Young AF. Cohort Profile: The Australian longitudinal study on Women's Health. Int. J. Epidemiol. 2005;34:987-991. [pmid: 15894591].
Lefebvre RC, Lasater TM, Assaf AR, Carleton RA. Pawtucket Heart Health Program: the process of stimulating community change. Scand J Prim Health Care Suppl. 88(1):31-7.
Lenfant C. Prevention and translation activities. Delivering the goods. Circulation. 94(89):1497-8.
Macera CA, Pate RR, Davis DR. Runners' health habits, 1985- ‘The Alameda 7’ revisited. PUBLIC HEALTH REP. 89(104):341-349.
Mackey DS, Hine RJ. Use the law to address obesity?. J Public Health Policy. 2006;27:433-9. [pmid: 17164808].
Maddah M, Karandish M. Gender difference in obesity management among Iranian patients with metabolic syndrome. Int. J. Cardiol. 2011;148:109-110. [pmid: 21310499].
Margie JD. Dietary management of the patient with hypertension. J S C Med Assoc. 80(76):21-32.
MASTER AM, JONES RJ, PATERSON JC, RUSSEK HI. DIETARY MANAGEMENT OF PATIENTS WITH DEGENERATIVE HEART DISEASE. Dis Chest. 64(45):1-14.
Matus CD, Klaege K. Exercise and weight management. Prim Care. 2007;34:109-16. [pmid: 17481989].
Merchant A, Vatanparast H, Barlas S, Cheskin LJ. Comment on: carbohydrate intake and overweight and obesity among healthy adults. Nutrition in Clinical Practice. 2010;25:680-681.
Mochari H. Lifestyle habits for lipid management. Diabetes Self Manag. 32. 34. 36. 2009;26:30-7. [pmid: 19445068].
More J. Healthy Start: the latest proposals. J Fam Health Care. 2004;14:32-3. [pmid: 15160623].
Nanchen D, Willi C, Peytremann-Bridevaux I. Preventing weight gain after smoking cessation: No miracle solution: Prevenir la prise de poids a l'arret du tabac: Pas de solution miracle. Rev. Med. Suisse. 2009;5:1577. [pmid: 19728455].
Neild P. Nutrition--who cares?. Clin Med. 2005;5:75-6. [pmid: 15745204].
Neira M, and de Onis M. Preventing obesity: a public health priority in Spain. Lancet. 2005;365:1386. [pmid: 15836883].
Newcomer JW. Metabolic considerations in the use of antipsychotic medications: a review of recent evidence. J Clin Psychiatry. Suppl 1. 2007;68:20-7. [pmid: 17286524].
Odoms AM. Dietary approaches for weight management in African Americans. Ethn Dis. 2002;12:S3-34-9. [pmid: 12477152].
Ohlsen R, Treasure J, Pilowsky L. Behavioral management of antipsychotic-induced weight gain. Acta Psychiatr Scand. 2004;109:156. author reply 156. [pmid: 14725601].
O'Meara S, Glenny AM, Wilson C, Melville A, Sheldon TA. Effective management of obesity. Qual Health Care. 97(6):170-5.
Orchard J. Sport is more important to health than most realise. J Sci Med Sport. 2004;7:iv-v. [pmid: 15362307].
Paffenbarger RS Jr., Jung DL, Leung RW, Hyde RT. Physical activity and hypertension: An epidemiological view. ANN. MED. 91(23):319-327.
Paulsen BK. LIFESTEPS: Weight Management Program: a response from a behavioral perspective. J Am Diet Assoc. 87(87):S33-5. [pmid: 3624719].
Peter P, Kumar S. Management of the overweight patient with Type 2 diabetes. Diabet Med. Suppl 4. 2003;20:10-3. [pmid: 12940860].
Phillips B. Your tax dollars at work! or the APPLES trial bears fruit. J Clin Sleep Med. 2008;4:419-20. [pmid: 18853697].
Poehlman ET, Toth MJ, Fonong T. Exercise, substrate utilization and energy requirements in the elderly. Int J Obes Relat Metab Disord. Suppl 4. 95(19):S93-6.
Pomeranz JL, Gostin LO. Improving laws and legal authorities for obesity prevention and control. J Law Med Ethics. Suppl 1. 2009;37:62-75. [pmid: 19493093].
Pratt CA. Findings from the 2007 active living research conference implications for future research. Am J Prev Med. 2008;34:366-8. [pmid: 18374254].
Ransom Montrece McNeill, Greiner Amelia, Kochtitzky Chris, Major Kristin S. Pursuing Health Equity: Zoning Codes and Public Health. Journal of Law, Medicine & Ethics. 2011;39:94-97.
Reslewic S. Eating disorders and obesity. Science. 2003;300:1091. [pmid: 12750498].
Rolls BJ, Bell EA. Dietary approaches to the treatment of obesity. Med Clin North Am. 2000;84:401-18. vi. [pmid: 10793649].
Roof K, Oleru N. Public health: Seattle and King County's push for the built environment. J Environ Health. 2008;71:24-7. [pmid: 18724501].
Salois MJ. Obesity and diabetes, the built environment, and the ‘local’ food economy in the United States, 2007. Econ Hum Biol. 2011.
Sanders OG, Warren TC, Demps-Gaines F, Weaver R, Carson E. Community-based nutrition program aims message at African American females. J Am Diet Assoc. 2002;102:626-7. [pmid: 12008982].
Satia JA, Galanko JA, Neuhouser ML. Food nutrition label use is associated with demographic, behavioral, and psychosocial factors and dietary intake among African Americans in North Carolina. J Am Diet Assoc. 2005;105:392-402. discussion 402-3. [pmid: 15746826].
Schauf GE. Diet and management of obesity. Am J Clin Nutr. 71(24):287-9.
Schmidt CW. Sprawl: the new manifest destiny?. Environ Health Perspect. 2004;112:A620-7. [pmid: 15289182].
Seidner DL. Orlistat for the long-term management of obesity. Curr Gastroenterol Rep. 99(1):316-8.
Simkin-Silverman LR, Wing RR. Weight gain during menopause. Is it inevitable or can it be prevented?. Postgrad Med. 2000;108:47-50. 53. 6. [pmid: 11004935].
Smith J. Healthy America--the opportunity to meet the challenge in our states. J Am Diet Assoc. 2006;106:663-4. [pmid: 16647317].
Smith R. Passing an effective obesity bill. J Am Diet Assoc. 2006;106:1349-50. 1352. 3. [pmid: 16963336].
Spritzer DA. Obesity epidemic migrates east. CMAJ. 2004;171:1159. [pmid: 15534302].
Stich V, Hainer V, Barbes P, De Glisezinsky I, Parizkora J, Crampes F. Physical activity in the prevention and management of obesity. World Rev Nutr Diet. 97(82):219-28.
Strazzullo P, D'Elia L, Siani A. Is a trend to reduced sodium intake in the United States concealed by obesity?. Am J Clin Nutr. 2011;93:670-1. author reply 671-2. [pmid: 21248186].
Strik CM, Henry CJ. The role of a low-glycemic-index diet in the management of obesity. Am J Clin Nutr. 2005;81:940-1. author reply 941. [pmid: 15817876].
Takaizumi K, Harada K, Shibata A, Nakamura Y. Influence of awareness of the Japanese Food Guide Spinning Top on eating behavior and obesity. Asia Pac J Clin Nutr. 2011;20:95-101. [pmid: 21393116].
TALLER H. Dietary management of obesity. Am J Obstet Gynecol. 62(83):62-72.
Trayers T. Game, set and match. J Epidemiol Community Health. 2007;61:371. [pmid: 17479516].
Ulijaszek SJ. Trends in body size, diet and food availability in the Cook Islands in the second half of the 20th century. Econ. Hum. Biol. 2003;1:123-137. [pmid: 15463968].
Van Baal PHM, Van Den Berg M, Hoogenveen RT, Vijgen SMC, Engelfriet PM. Cost-effectiveness of a low-calorie diet and orlistat for obese persons: Modeling long-term health gains through prevention of obesity-related chronic diseases. Value Health. 2008;11:1033-1040. [pmid: 18494748].
Van Buren DJ, Sinton MM. Psychological aspects of weight loss and weight maintenance. J Am Diet Assoc. 2009;109:1994-6. [pmid: 19942015].
Verweij LM, Proper KI, Weel AN, Hulshof CT, van Mechelen W. Design of the Balance@Work project: systematic development, evaluation and implementation of an occupational health guideline aimed at the prevention of weight gain among employees. BMC Public Health. 2009;9:461. [pmid: 20003405].
Wadden TA, McGuckin BG, Rothman RA, Sargent SL. Lifestyle modification in the management of obesity. J Gastrointest Surg. 2003;7:452-63. [pmid: 12763398].
Waine C. Obesity--the challenge ahead. Br J Gen Pract. 2004;54:232-3. [pmid: 15143783].
Wald NJ. Obesity and public health law. N Engl J Med. 2006;355:1283. [pmid: 16998967].
Warren LE, Horwitz BA, Fuller CA. Gravity and body mass regulation. J Gravit Physiol. 97(4):P89-92.
Wasling C. Role of the cardioprotective diet in preventing coronary heart disease. Br J Nurs. 99(8):1239-48.
Weinhaus RS. The management of obesity: some recent concepts. Mo Med. 69(66):719-23 passim.
Willett WC. Reduced-carbohydrate diets: no roll in weight management?. Ann Intern Med. 2004;140:836-7. [pmid: 15148073].
Williams N, Burnie R, Robbe I. Response to: Association of perceived environment with meeting public health recommendations for physical activity in seven European countries. J Public Health (Oxf). 2009;31:306. [pmid: 19244258].
Wilson C. Obesity: Light-to-moderate alcohol consumption may reduce weight gain in middle-aged or older women. Nat Rev Endocrinol. 2010;6:353. [pmid: 20583338].
Wilson N, Watts C, Signal L, Thomson G. Acting upstream to control the obesity epidemic in New Zealand. N Z Med J. 2006;119:U1914. [pmid: 16582975].
Wing RR. Behavioral strategies to improve long-term weight loss and maintenance. Med Health R I. 99(82):123.
Witte F. A clarification about normal body weight. Dtsch Med Wochenschr. 2006;Suppl 1:30-2. [pmid: 17595815].
Wong NN, Cheng-Lai A. Orlistat. Heart Dis. 2000;2:174-81. [pmid: 11728255].
Yates W. Psychological management of obesity. Iowa Med. 92(82):325-6.
Zimmet PZ, James WP. The unstoppable Australian obesity and diabetes juggernaut. what should politicians do?. Med J Aust. 2006;185:187-8. [pmid: 16922660].

## Study of children only

Epstein Leonard H, Wing Rena R, Koeske Randi, Valoski Alice. Effects of diet plus exercise on weight change in parents and children. Journal of Consulting and Clinical Psychology. 84(52):429-437.
Misuraca G, Boncompagni F, Chiatto M, Battista F, Serafini O, Talarico A, Plastina F. A health education program for the prevention of heart diseases carried out in a population in Calabria. Minerva Med. 99(90):385-90.
Power C, Moynihan C. Social class and changes in weight-for-height between childhood and early adulthood. Int J Obes. 88(12):445-53.
Stang JS, Story M, Kalina B. School-based weight management services: perceptions and practices of school nurses and administrators. American Journal of Health Promotion. 97(11):183-185.
Wengreen HJ, Moncur C. Change in diet, physical activity, and body weight among young-adults during the transition from high school to college. Nutr J. 2009;8:32. [pmid: 19624820].

## No human data reported

Warren LE, Horwitz BA, Fuller CA. Gravity and body mass regulation. J Gravit Physiol. 97(4):P89-92.

## Abstract only

Berge JM. What is being served for dinner? Associations between the emotional atmosphere at family meals and health outcomes. Obesity. 2011;19:S130.
Bernstein LE, Gaughan SM. More PHE, more choices: Think healthy. J Inherit Metab Dis. 2011;34:S241.
Braun B, Parker D, Harvey L, Bissen J, Melko C, Xi M. Arthritis-friendly adaptations for weight management and physical activity promotion: Two 12-month interventions. American Public Health Association 134th Annual Meeting & Exposition. Nov 4 2006. Boston,MA. 2006.
Charreire H, Salze P, Casey R, et al. Defining obesogenic neighborhoods: Built environment characteristics in relation with walking and cycling among french middle-aged adults. Obes Rev. 2011;12:40.
Denney-Wilson E, Vagholkar S, Wan Q, et al. Patient characteristics and outcomes of weight management advice in primary care. Obes Res Clin Pract. 2011;5:S19.
Dzien A, Dzien-Bischinger C, Winner H, et al. Physical fitness in elderly - Relationship with regular exercise and nutrition. Eur Geriatr Med. 2011;2:S156.
Geirsdottir OG, Arnarsson A, Briem K, et al. Associations between dietary intake, leisure time physical activity, body composition and physical function in Icelandic elderly. Eur Geriatr Med. 2011;2:S17.
Nilsson P. Metabolic disturbances in primary hypertension: Special focus on nonpharmacological treatment of hyperinsulinemia. Journal. 91.
Petrova S, Duleva V, Ovcharova D, Rangelova L, et al. Food-based dietary guidelines as a basis to reduce risk for overweight and obesity in Bulgarian population. Obes Rev. 2011;12:76.
Qayad MG, Chowdhury PP, Town GM, et al. Sociodemographic differences in body mass index changes among U.S. adults in the behavioral risk factor surveillance system data (BRFSS). Am J Epidemiol. 2011;173:S261.
Rivera Fernando I, Lieberman Leslie Sue, Rivadeneyra Gloria M, Sallas Anita M. Using a social marketing framework to transform an education program: Lessons from the Hispanic Obesity Prevention and Education (PESO) Program. Social Marketing Quarterly. 2010;16:2-17.
Valencia W, Oropesa L, Andrade F, et al. Impact of group exercise on health-related quality of life in overweight/obese older adults. Diabetes. 2011;60:A207.
Vigna L, Agnelli GM, Tirelli AS, et al. Obesita e lavoro: proposta di un modello di intervento multidisciplinare per la prevenzione e sua applicazione in una industria metalmeccanica del Nord Italia. Obesity and work: proposal for a multidisciplinary intervention model for prevention and its application in an engineering plant. Med Lav. 2011;102:275-85. [pmid: 21797044].
Von MacKensen S, Eifrig B, Zaech D, et al. Benefits of a specific aqua-training for adult haemophilia patients - Results of the longitudinal watercise study (WAT-QOL). J Thromb Haemost. 2011;9:924-25.
Williams M, Rush E, Simmons D, et al. Type 2 diabetes and obesity: How effective is a lifestyle intervention at promoting physical activity and nutrition. Obes Res Clin Pract. 2011;5:S26.

## Does not apply to key questions

A new evidence-based model for weight management in primary care: the Counterweight Programme. Journal of Human Nutrition & Dietetics. 2004;17:191-208. [pmid: 15139891].
Adverse events and their association with treatment regimens in the diabetes control and complications trial. Diabetes care. 95(18):1415-27.
U.K. prospective diabetes study 16. Overview of 6 years' therapy of type II diabetes: a progressive disease. U.K. Prospective Diabetes Study Group. Diabetes. 95(44):1249-58.
Ackermann RT, Finch EA, Brizendine E, Zhou H, Marrero DG. Translating the Diabetes Prevention Program into the community. The DEPLOY Pilot Study. American journal of preventive medicine. 2008;35:357-63. [pmid: 18779029].
Ahn S, Zhao H, Smith ML, Ory MG, Phillips CD. BMI and lifestyle changes as correlates to changes in self-reported diagnosis of hypertension among older Chinese adults. J. Am. Soc. Hypertens. 2011;5:21-30. [pmid: 21273158].
Andajani-Sutjahjo S, Ball K, Warren N, Inglis V, Crawford D. Perceived personal, social and environmental barriers to weight maintenance among young women: A community survey. Int J Behav Nutr Phys Act. 2004;1:15. [pmid: 15462679].
Andryukhin A, Frolova E, Vaes B, Degryse J. The impact of a nurse-led care programme on events and physical and psychosocial parameters in patients with heart failure with preserved ejection fraction: a randomized clinical trial in primary care in Russia. Eur J Gen Pract. 2010;16:205-14. [pmid: 21073267].
Bastiaens Hilde, Sunaert Patricia, Wens Johan, Sabbe Bernard, Jenkins Lutgarde, Nobels Frank, Snauwaert Boris, Van Royen Paul. Supporting diabetes self-management in primary care: Pilot-study of a group-based programme focusing on diet and exercise. Primary Care Diabetes. 2009;3:103-109. [pmid: 19264568].
Bhattacharya J, Sood N. Who pays for obesity?. J. Econ. Perspect. 2011;25:139-158. [pmid: 21598459].
Bhattacharya J, Sood N. Who pays for obesity?. J. Econ. Perspect. 2011;25:139-158. [pmid: 21598459].
Blundell JE, Stubbs RJ, Golding C, Croden F, Alam R, Whybrow S, Le Noury J, Lawton CL. Resistance and susceptibility to weight gain: Individual variability in response to a high-fat diet. Physiology & Behavior. 2005;86:614-622. [pmid: 16225895].
Borgonha S, Shetty PS, Kurpad AV. Total energy expenditure & physical activity level in chronically energy deficient Indian males measured by the doubly labelled water technique. Indian J Med Res. 2000;111:138-46. [pmid: 10935321].
Caan BJ, Flatt SW, Rock CL, Ritenbaugh C, Newman V, Pierce JP. Low-energy reporting in women at risk for breast cancer recurrence. Cancer Epidemiol. Biomarkers Prev. 2000;9:1091-1097. [pmid: 11045793].
Caan B, Armstrong MA, Selby JV, Sadler M, Folsom AR, Jacobs D, Slattery ML, Hilner JE, Roseman J. Changes in measurements of body fat distribution accompanying weight change. INT. J. OBES. 94(18):397-404.
Caporaso F, Frisch F, Sumida KD. Compromised Bone Health in Non-Obese, Older Women with Low Caloric Intake. J Community Health. 2010.
Carls GS, Goetzel RZ, Henke RM, Bruno J, Isaac F, McHugh J. The impact of weight gain or loss on health care costs for employees at the Johnson & Johnson Family of Companies. J Occup Environ Med. 2011;53:8-16. [pmid: 21187786].
Chen DR, Wen TH. Elucidating the changing socio-spatial dynamics of neighborhood effects on adult obesity risk in Taiwan from 2001 to 2005. Health Place. 2010;16:1248-1258. [pmid: 20832348].
Chen DR, Wen TH. Elucidating the changing socio-spatial dynamics of neighborhood effects on adult obesity risk in Taiwan from 2001 to 2005. Health Place. 2010;16:1248-1258. [pmid: 20832348].
Choquette Anne C, Lemieux Simone, Tremblay Angelo, Drapeau Vicky, Bouchard Claude, Vohl Marie-Claude, P+_russe Louis. GAD2 gene sequence variations are associated with eating behaviors and weight gain in women from the Quebec family study. Physiology & Behavior. 2009;98:505-510. [pmid: 19686769].
Christiansen E, Swann A, Sorensen TI. Feedback models allowing estimation of thresholds for self-promoting body weight gain. J Theor Biol. 2008;254:731-6. [pmid: 18671981].
Cizza G, Marincola P, Mattingly M, Williams L, Mitler M, Skarulis M, Csako G. Treatment of obesity with extension of sleep duration: a randomized, prospective, controlled trial. Clin Trials. 2010;7:274-85. [pmid: 20423926].
Cleghorn GD, Nguyen M, Roberts B, Duran G, Tellez T, Alecon M. Practice-based interventions to improve health care for Latinos with diabetes. Ethn Dis. 2004;14:S117-21. [pmid: 15682780].
Couper MP, Peytchev A, Strecher VJ, Rothert K, Anderson J. Following up nonrespondents to an online weight management intervention: randomized trial comparing mail versus telephone. Journal of medical Internet research. 2007;9:e16. [pmid: 17567564].
Cropsey KL, McClure LA, Jackson DO, Villalobos GC, Weaver MF, Stitzer ML. The impact of quitting smoking on weight among women prisoners participating in a smoking cessation intervention. Am J Public Health. 2010;100:1442-1448. [pmid: 20558806].
Cruz I, Serna C, Real J, Galindo G, Gasco E, Galvan L. Ischemic heart disease and primary care: identifying gender-related differences. An observational study. BMC Fam Pract. 2008;9:60. [pmid: 18973693].
Dharmasena S, Capps O Jr. Intended and unintended consequences of a proposed national tax on sugar-sweetened beverages to combat the U.S. obesity problem. Health Econ. 2011.
Diller Paul A, Graff Samantha. Regulating Food Retail for Obesity Prevention: How Far Can Cities Go?. Journal of Law, Medicine & Ethics. 2011;39:89-93.
Dowell AC, Ochera JJ, Hilton SR, Bland JM, Harris T, Jones DR, Katbamna S. Prevention in practice: Results of a 2-year follow-up of routine health promotion interventions in general practice. FAM. PRACT. 96(13):357-362.
Dummer TJ, Kirk SF, Penney TL, et al. Targeting policy for obesity prevention: identifying the critical age for weight gain in women. J Obes. 2012;2012. 934895.
Dutton Gareth R, Napolitano Melissa A, Whiteley Jessica A, Marcus Bess H. Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;46:216-221.
Edwards RD. Public transit, obesity, and medical costs: Assessing the magnitudes. Prev. Med. 2008;46:14-21. [pmid: 18037480].
Ell K, Katon W, Xie B, Lee PJ, Kapetanovic S, Guterman J, Chou CP. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. 2010;33:706-13. [pmid: 20097780].
Ellam LD, Fieldman GB, Garlick J, Goldsmith R, Pateman C. Initial training as a stimulus for optimal physical fitness in firemen. ERGONOMICS. 94(37):933-941.
Epstein LH, Dearing KK, Paluch RA, Roemmich JN, Cho D. Price and maternal obesity influence purchasing of low- and high-energy-dense foods. American Journal of Clinical Nutrition. 2007;86:914-922. [pmid: 17921365].
Felber Dietrich D, Ackermann-Liebrich U, Schindler C, Barthelemy JC, Brandli O, Gold DR, Knopfli B, Probst-Hensch NM, Roche F, Tschopp JM, Eckardstein A, Gaspoz JM. Effect of physical activity on heart rate variability in normal weight, overweight and obese subjects: Results from the SAPALDIA study. Eur. J. Appl. Physiol. 2008;104:557-565. [pmid: 18597107].
Ferrario M, Sega R, Chatenoud L, Mancia G, Mocarelli P, Crespi C, Cesana G. Time trends of major coronary risk factors in a northern Italian population (1986-1994). How remarkable are socioeconomic differences in an industrialized low CHD incidence country?. Int. J. Epidemiol. 2001;30:285-291. [pmid: 11369728].
Fleet-Michaliszyn SB, Soreca I, Otto AD, Jakicic JM, Fagiolini A, Kupfer DJ, Goodpaster BH. A prospective observational study of obesity, body composition, and insulin resistance in 18 women with bipolar disorder and 17 matched control subjects. J. Clin. Psychiatry. 2008;69:1892-1900. [pmid: 19026257].
Flinn LB. The results of diet therapy vs insulin in the management of obese diabetics. Del Med J. 78(50):375-80.
Forman-Hoffman VL, Richardson KK, Yankey JW, Hillis SL, Wallace RB, Wolinsky FD. Retirement and weight changes among men and women in the health and retirement study. J Gerontol B Psychol Sci Soc Sci. 2008;63:S146-53. [pmid: 18559689].
Fox M, Thumshirn M, Menne D, Stutz B, Fried M, Schwizer W. The pathophysiology of faecal spotting in obese subjects during treatment with orlistat. Alimentary pharmacology & therapeutics. 2004;19:311-21. [pmid: 14984378].
Fries JF, Fries ST, Parcell CL, Harrington H. Health risk changes with a low-cost individualized health promotion program: Effects at up to 30 months. AM. J. HEALTH PROMOT. 92(6):364-371.
Gaede P, Vedel P, Larsen N, Jensen GV, Parving HH, Pedersen O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. The New England journal of medicine. 2003;348:383-93. [pmid: 12556541].
Gulliford MC, Mahabir D. A five-year evaluation of intervention in diabetes care in Trinidad and Tobago. Diabetic Med. 99(16):939-945.
Harring HA, Montgomery K, Hardin J. Perceptions of body weight, weight management strategies, and depressive symptoms among US college students. J. Am. Coll. Health. 2010;59:43-50. [pmid: 20670928].
Harris TB, Savage PJ, Tell GS, Haan M, Kumanyika S, Lynch JC. Carrying the burden of cardiovascular risk in old age: associations of weight and weight change with prevalent cardiovascular disease, risk factors, and health status in the Cardiovascular Health Study. Am J Clin Nutr. 97(66):837-44.
Haupt E, Herrmann R, Benecke-Timp A, Vogel H, Haupt A, Walter C. The KID Study IV: Effects of inpatient rehabilitation on the frequency of glucose self-monitoring, quality of further primary care, on time being unable to work and on everyday psychic strain of type I and type II diabetics - A one-year follow-up. EXP. CLIN. ENDOCRINOL. DIABETES. 97(105):21-31.
Hawkes AL, Lynch BM, Owen N, Aitken JF. Lifestyle factors associated concurrently and prospectively with co-morbid cardiovascular disease in a population-based cohort of colorectal cancer survivors. European Journal of Cancer. 2011;47:267-276. [pmid: 21074408].
Hays NP, Roberts SB. Aspects of eating behaviors “disinhibition” and “restraint” are related to weight gain and BMI in women. Obesity (Silver Spring). 2008;16:52-8. [pmid: 18223612].
Hays NP, Bathalon GP, McCrory MA, Roubenoff R, Lipman R, Roberts SB. Eating behavior correlates of adult weight gain and obesity in healthy women aged 55-65 y. Am J Clin Nutr. 2002;75:476-83. [pmid: 11864852].
Heyn P. The effect of a multisensory exercise program on engagement, behavior, and selected physiological indexes in persons with dementia. Am. J. Alzheimer's Dis. Other Dem. 2003;18:247-251.
Hlaing W, Nath SD, Huffman FG. Assessing overweight and cardiovascular risks among college students. American Journal of Health Education. 2007;38:83-90.
Hyypp+ñ MT, M+ñki J, Impivaara O, Aromaa A. Leisure participation predicts survival: A population-based study in Finland. Health Promotion International. 2006;21(1):5-12.
Ilmonen J, Isolauri E, Poussa T, Laitinen K. Impact of dietary counselling and probiotic intervention on maternal anthropometric measurements during and after pregnancy: a randomized placebo-controlled trial. Clin Nutr. 2011;30:156-64. [pmid: 20970896].
Ilmonen Johanna, Isolauri Erika, Poussa Tuija, Laitinen Kirsi. Impact of dietary counselling and probiotic intervention on maternal anthropometric measurements during and after pregnancy: A randomized placebo-controlled trial. Clinical Nutrition. 2011;30:156-164. [pmid: 20970896].
Javier Basterra-Gortari F, Forga L, Bes-Rastrollo M, Toledo E, Alfredo Martinez J, Martinez Gonzalez MA. Effect of Smoking on Body Weight: Longitudinal Analysis of the SUN Cohort: Evolucion de los cambios en el peso corporal segun habito tabaquico: analisis longitudinal de la cohorte SUN. Rev. Esp. Cardiol. 2010;63:20-27. [pmid: 20089222].
Jilcott SB, Keyserling TC, Samuel-Hodge CD, Rosamond W, Garcia B, Will JC, Farris RP, Ammerman AS. Linking clinical care to community resources for cardiovascular disease prevention: The North Carolina enhanced WISEWOMAN project. J. Women's Health. 2006;15:569-583.
John U, Meyer C, Rumpf HJ, Schumann A, Dilling H, Hapke U. No considerable long-term weight gain after smoking cessation: evidence from a prospective study. Eur J Cancer Prev. 2005;14:289-95. [pmid: 15902001].
Jones H, Edwards L, Vallis TM, Ruggiero L, Rossi SR, Rossi JS, Greene G, Prochaska JO, Zinman B. Changes in diabetes self-care behaviors make a difference in glycemic control: The diabetes stages of change (DiSC) study. Diabetes Care. 2003;26:732-737. [pmid: 12610030].
Jones-Smith JC, Gordon-Larsen P, Siddiqi A, Popkin BM. Cross-national comparisons of time trends in overweight inequality by socioeconomic status among women using repeated cross-sectional surveys from 37 developing countries, 1989-2007. Am J Epidemiol. 2011;173:667-75. [pmid: 21300855].
Jones-Smith JC, Gordon-Larsen P, Siddiqi A, Popkin BM. Original contribution: Cross-national comparisons of time trends in overweight inequality by socioeconomic status among women using repeated cross-sectional surveys from 37 developing countries, 1989-2007. Am. J. Epidemiol. 2011;173:667-675. [pmid: 21300855].
Kai N, Iwasimizu Y, Sato J, Inoue H, Honda Y, Kitagawa T, Miyazaki M, Sawano M, Yamashita M, Kushiro T, Hinohara S, Doba N. Management problems in continuous care of male patients with mild hypertension with special reference to alcohol-intake. J. MED. SYST. 93(17):183-186.
Kalten MR, Ardito DA, Cimino C, Wylie-Rosett J. A Web-accessible core weight management program. Diabetes Educ. 2000;26:929-36. [pmid: 11912805].
Khare Manorama M, Huber Rachel, Carpenter Ruth Ann, Balmer Pamela W, Bates Nancy J, Nolen Kristen N, Hudson Heather K, Lattyak Rose M, Cursio John F, Loo Ryan K, Farris Rosanne P, Will Julie C. A lifestyle approach for reducing cardiovascular risk factors in underserved women: Design and methods of the Illinois WISEWOMAN program. Journal of Women's Health. 2009;18:409-419.
Khazaal Y, Fr+_sard E, Zimmermann Gg, et al. Eating and weight related cognitions in people with schizophrenia: A case control study. Clinical Practice and Epidemiology in Mental Health. 2006;2.
King Abby C, Marcus Bess, Ahn David, Dunn Andrea L, Rejeski W Jack, Sallis James F, Coday Mace. Identifying subgroups that succeed or fail with three levels of physical activity intervention: The activity counseling trial. Health Psychology. 2006;25:336-347. [pmid: 16719605].
Kirk A, Barnett J, Leese G, Mutrie N. A randomized trial investigating the 12-month changes in physical activity and health outcomes following a physical activity consultation delivered by a person or in written form in Type 2 diabetes: Time2Act. Diabet Med. 2009;26:293-301. [pmid: 19317825].
Knekt P, Laaksonen MA, Raitasalo R, Haaramo P, Lindfors O. Changes in lifestyle for psychiatric patients three years after the start of short- and long-term psychodynamic psychotherapy and solution-focused therapy. European psychiatry : the journal of the Association of European Psychiatrists. 2010;25:1-7. [pmid: 19553088].
Knott J, Cavan D, Kerr D. Transfer of a diabetes education programme to primary care. Journal of Diabetes Nursing. 2005;9:373-376.
Kohrt WM, Ehsani AA, Birge SJ Jr. HRT preserves increases in bone mineral density and reductions in body fat after a supervised exercise program. Journal of Applied Physiology. 98(84):1506-1512.
Koster A, Harris TB, Moore SC, Schatzkin A, Hollenbeck AR, Van Eijk JTM, Leitzmann MF. Joint associations of adiposity and physical activity with mortality. Am. J. Epidemiol. 2009;169:1344-1351. [pmid: 19372216].
Kriska AM, Saremi A, Hanson RL, Bennett PH, Kobes S, Williams DE, Knowler WC. Physical activity, obesity, and the incidence of type 2 diabetes in a high-risk population. Am J Epidemiol. 2003;158:669-75. [pmid: 14507603].
Kuo T, Jarosz CJ, Simon P, Fielding JE. Menu labeling as a potential strategy for combating the obesity epidemic: a health impact assessment. American Journal of Public Health. 2009;99:1680-1686. [pmid: 19608944].
Kwak L, Kremers SP, Werkman A, Visscher TL, van Baak MA, Brug J. The NHF-NRG In Balance-project: the application of Intervention Mapping in the development, implementation and evaluation of weight gain prevention at the worksite. Obes Rev. 2007;8:347-61. [pmid: 17578384].
Lappalainen TJ, Tolppanen A-M, Kolehmainen M, et al. The common variant in the FTO gene did not modify the effect of lifestyle changes on body weight: The Finnish Diabetes Prevention Study. Obesity. 2009;17(4):832-6. [pmid: 19180072].
Larew K, Hunter GR, Larson-Meyer DE, Newcomer BR, McCarthy JP, Weinsier RL. Muscle metabolic function, exercise performance, and weight gain. Med. Sci. Sports Exerc. 2003;35:230-236. [pmid: 12569210].
Lefebvre RC, Lasater TM, Assaf AR, Carleton RA. Pawtucket Heart Health Program: the process of stimulating community change. Scand J Prim Health Care Suppl. 88(1):31-7.
Leitzmann Michael F, Rimm Eric B, Willett Walter C, Spiegelman Donna, Grodstein Francine, Stampfer Meir J, Colditz Graham A, Giovannucci Edward. Recreational physical activity and the risk of cholecystectomy in women. The New England Journal of Medicine. 99(341):777-784.
Leunissen RWJ, Kerkhof GF, Stijnen T, Hokken-Koelega A. Timing and tempo of first-year rapid growth in relation to cardiovascular and metabolic risk profile in early adulthood. J. Am. Med. Assoc. 2009;301:2234-2242.
Leunissen RWJ, Kerkhof GF, Stijnen T, Hokken-Koelega A. Timing and tempo of first-year rapid growth in relation to cardiovascular and metabolic risk profile in early adulthood. J. Am. Med. Assoc. 2009;301:2234-2242.
Li G, Hu Y, Yang W, Jiang Y, Wang J, Xiao J, Hu Z, Pan X, Howard BV, Bennett PH, DA Qing IGT, Diabetes Study. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes research and clinical practice. 2002;58:193-200. [pmid: 12413779].
Lin SJ, Lee KT, Lin KC, Cheng KH, Tsai WC, Sheu SH, Wu MT, Lee CH, Lai WT. Prevalence of prehypertension and associated risk factors in a rural Taiwanese adult population. Int. J. Cardiol. 2010;144:269-273. [pmid: 19223086].
Long DA, Sheehan P. A case study of population health improvement at a Midwest regional hospital employer. Population Health Management. 2010;13:163-173. [pmid: 20521905].
Maddigan Sheri L, Majumdar Sumit R, Johnson Jeffrey A. Understanding the complex associations between patient-provider relationships, self-care behaviours, and health-related quality of life in type 2 diabetes: A structural equation modeling approach. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2005;14:1489-1500.
Maetzel A, Ruof J, Covington M, Wolf A. Economic evaluation of orlistat in overweight and obese patients with type 2 diabetes mellitus. Pharmacoeconomics. 2003;21:501-12. [pmid: 12696990].
Mainie PM, Moore G, Riddell JW, Adgey AA. To examine the effectiveness of a hospital-based nurse-led secondary prevention clinic. Eur J Cardiovasc Nurs. 2005;4:308-13. [pmid: 15993647].
Markey Charlotte N, Markey Patrick M. Relations between body image and dieting behaviors: An examination of gender differences. Sex Roles. 2005;53:519-530.
Mayer DK, Terrin NC, Menon U, Kreps GL, McCance K, Parsons SK, Mooney KH. Health behaviors in cancer survivors. Oncology Nursing Forum. 2007;34:643-651. [pmid: 17573323].
McConnon +, Kirk SFL, Ransley JK. Process evaluation of an internet-based resource for weight control: Use and views of an obese sample. Journal of Nutrition Education and Behavior. 2009;41(4):261-7. [pmid: 19508931].
McLeod AL, Brooks L, Taylor V, Currie PF, Dewhurst NG. Secondary prevention for coronary artery disease. QJM. 2004;97:127-31. [pmid: 14976269].
McTiernan Anne, Sorensen Bess, lrwin Melinda L, Morgan Angela, Yasui Yutaka, Rudolph Rebecca E, Surawicz Christina, Lampe Johanna W, Lampe Paul D, Ayub Kamran, Potter John D. Exercise effect on weight and body fat in men and women. Obesity. 2007;15:1496-1512. [pmid: 17557987].
Melamed Samuel, Shirom Arie, Toker Sharon, Shapira Itzhak. Burnout and Risk of Type 2 Diabetes: A Prospective Study of Apparently Healthy Employed Persons. Psychosomatic Medicine. 2006;68:863-869. [pmid: 17132837].
Meng H, Liebel D, Wamsley BR. Body mass index and the impact of a health promotion intervention on health services use and expenditures. J Aging Health. 2011;23:743-63. [pmid: 21311047].
Mojtahedi MC, Valentine RJ, Arngrimsson SA, Wilund KR, Evans EM. The association between regional body composition and metabolic outcomes in athletes with spinal cord injury. Spinal Cord. 2008;46:192-7. [pmid: 17502877].
Monninkhof EM, Peeters PH, Schuit AJ. Design of the sex hormones and physical exercise (SHAPE) study. BMC public health. 2007;7:232. [pmid: 17767724].
Nederkoorn C, Havermans RC, Giesen JCAH, Jansen A. High tax on high energy dense foods and its effects on the purchase of calories in a supermarket. An experiment. Appetite. 2011;56:760-765.
Niemeier HM, Raynor HA, Lloyd-Richardson EE, Rogers ML, Wing RR. Fast food consumption and breakfast skipping: predictors of weight gain from adolescence to adulthood in a nationally representative sample. J Adolesc Health. 2006;39:842-9. [pmid: 17116514].
Nilsson P. Metabolic disturbances in primary hypertension: Special focus on nonpharmacological treatment of hyperinsulinemia. Journal. 91.
Nitzke SA, Voichick SJ, Olson D. Weight Cycling Practices and Long-term Health Conditions in a Sample of Former Wrestlers and Other Collegiate Athletes. J Athl Train. 92(27):257-61.
Noll JG, Zeller MH, Trickett PK, Putnam FW. Obesity risk for female victims of childhood sexual abuse: a prospective study. Pediatrics. 2007;120:e61-7. [pmid: 17606550].
Normand Matthew P. Increasing physical activity through self-monitoring, goal setting, and feedback. Behavioral Interventions. 2008;23:227-236.
Paffenbarger RS Jr., Kampert JB, Lee IM, Hyde RT, Leung RW, Wing AL. Changes in physical activity and other lifeway patterns influencing longevity. MED. SCI. SPORTS EXERC. 94(26):857-865.
Pahkala K, Heinonen OJ, Lagstr+¦m H, et al. Parental and childhood overweight in sedentary and active adolescents. Scandinavian Journal of Medicine & Science in Sports. 2010;20(1):74-82. [pmid: 19017296].
Parker KB, DeJoy DM, Wilson MG, Bowen HM, Goetzel RZ. Application of the Environmental Assessment Tool (EAT) as a process measure for a worksite weight management intervention. J Occup Environ Med. Suppl 1. 2010;52:S42-51. [pmid: 20061887].
Perkins KA, Marcus MD, Levine MD, D'Amico D, Miller A, Broge M, Ashcom J, Shiffman S. Cognitive-behavioral therapy to reduce weight concerns improves smoking cessation outcome in weight-concerned women. J Consult Clin Psychol. 2001;69:604-13. [pmid: 11550727].
Pisinger C, Jorgensen T. Waist circumference and weight following smoking cessation in a general population:. The Inter99 study. Prev. Med. 2007;44:290-295. [pmid: 17222450].
Poehlman ET, Toth MJ, Fonong T. Exercise, substrate utilization and energy requirements in the elderly. Int J Obes Relat Metab Disord. Suppl 4. 95(19):S93-6.
Pollock ML, Foster C, Knapp D. Effect of age and training on aerobic capacity and body composition of master athletes. J. APPL. PHYSIOL. 87(62):725-731.
Reyes-Garc+¡a V, McDade TW, Molina JL, et al. Social rank and adult male nutritional status: Evidence of the social gradient in health from a foraging-farming society. Social Science & Medicine. 2008;67(12):2107-15. [pmid: 18945532].
Robert SA, Reither EN. A multilevel analysis of race, community disadvantage, and body mass index among adults in the US. Soc Sci Med. 2004;59:2421-34. [pmid: 15474198].
Rowland JL, White GW, Wyatt DA. Analysis of an intervention to reduce or prevent secondary conditions for people with spinal cord injuries. J. Clin. Psychol. Med. Settings. 2006;13:263-271.
Sakane N, Sato J, Tsushita K, et al. Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011;11:40. [pmid: 21235825].
Salyer J, Sneed G, Corley MC. Lifestyle and health status in long-term cardiac transplant recipients. Heart & Lung. 2001;30:445-457. [pmid: 11723449].
Saunders SA, Wallymhamed M, Macfarlane IA. Improvements in glycaemic control and cardiovascular risk factors in a cohort of patients with type 1 diabetes over a 5-year period. QJM. 2009;102:29-34. [pmid: 18829712].
Schmeiser MD. Expanding wallets and waistlines: the impact of family income on the BMI of women and men eligible for the Earned Income Tax Credit. Health Econ. 2009;18:1277-94. [pmid: 19142860].
Sharma L, Cahue S, Song J, Hayes K, Pai YC, and Dunlop D. Physical functioning over three years in knee osteoarthritis: role of psychosocial, local mechanical, and neuromuscular factors. Arthritis Rheum. 2003;48:3359-70. [pmid: 14673987].
Silva MN, Markland D, Vieira PN, et al. Helping overweight women become more active: Need support and motivational regulations for different forms of physical activity. Psychology of Sport and Exercise. 2010;11(6):591-601.
SILVERSTONE JT, SOLOMON T. THE LONG-TERM MANAGEMENT OF OBESITY IN GENERAL PRACTICE. Br J Clin Pract. 65(19):395-8.
Stachowska E, Wesolowska T, Safranow K, Domanski L, Rac M, Dziedziejko V, Ciechanowski K, Chlubek D. Simple dietary interventions reduce the risk factors of atherosclerosis in renal graft recipients. Journal of renal nutrition : the official journal of the Council on Renal Nutrition of the National Kidney Foundation. 2005;15:291-7. [pmid: 16007558].
Stang JS, Story M, Kalina B. School-based weight management services: perceptions and practices of school nurses and administrators. American Journal of Health Promotion. 97(11):183-185.
Tahbaz F, Kreis I, Calvert D. An audit of diabetes control, dietary management and quality of life in adults with type 1 diabetes mellitus, and a comparison with nondiabetic subjects. Journal of Human Nutrition & Dietetics. 2006;19:3-11. [pmid: 16448469].
TALLER H. Dietary management of obesity. Am J Obstet Gynecol. 62(83):62-72.
Tolppanen AM, Pulkkinen L, Kolehmainen M, et al. Tenomodulin is associated with obesity and diabetes risk: The Finnish Diabetes Prevention Study. Obesity. 2007;15(5):1082-8. [pmid: 17495183].
Tranter PJ. Speed kills: the complex links between transport, lack of time and urban health. J Urban Health. 2010;87:155-66. [pmid: 20180154].
Tredan O, Bajard A, Meunier A, Roux P, Fiorletta I, Gargi T, Bachelot T, Guastalla JP, Lallemand Y, Faure C, Perol D, Bachmann P. Body weight change in women receiving adjuvant chemotherapy for breast cancer: a French prospective study. Clin Nutr. 2010;29:187-91. [pmid: 19713014].
Truesdale KP, Stevens J, Cai J. Differences in Cardiovascular Disease Risk Factors by Weight History: The Aerobics Center Longitudinal Study. Obesity (Silver Spring). 2011.
Tylavsky FA, Smith K, Surprise H, Garland S, Yan X, McCammon E, Hudson MM, Pui CH, Kaste SC. Nutritional intake of long-term survivors of childhood acute lymphoblastic leukemia: evidence for bone health interventional opportunities. Pediatr Blood Cancer. 2010;55:1362-9. [pmid: 20981691].
van Bruggen Rykel, Gorter Kees J, Stolk Roland P, Verhoeven Rob P, Rutten Guy EHM. Implementation of locally adapted guidelines on type 2 diabetes. Family Practice. 2008;25:430-437. [pmid: 18718886].
van Weel C, Bakx C, van den Hoogen H, Thien T, van den Bosch W. Long-term outcome of cardiovascular prevention: a Nijmegen Academic Family Practices Network study. J Am Board Fam Med. 2006;19:62-8. [pmid: 16492007].
Verheijden Marieke W, Jans Marielle P, Hildebrandt Vincent H. Hopman-Rock, Marijke. Rates and determinants of repeated participation in web-based behavior change program for healthy body weight and healthy lifestyle. Journal of Medical Internet Research. 2007;9:1-7.
Wallymahmed ME, Morgan C, Gill GV, et al. Nurse-led cardiovascular risk factor intervention leads to improvements in cardiovascular risk targets and glycaemic control in people with Type 1 diabetes when compared with routine diabetes clinic attendance. Diabet Med. 2011;28:373-9. [pmid: 21204963].
Wang Feifei, McDonald Tim, Reffitt Bonnie, Edington Dee W. BMI, Physical Activity, and Health Care Utilization/Costs among Medicare Retirees. Obesity Research. 2005;13:1450-1457. [pmid: 16129728].
Wannamethee SG, Shaper AG. Alcohol, body weight, and weight gain in middle-aged men. Am. J. Clin. Nutr. 2003;77:1312-1317. [pmid: 12716687].
Weinstock RS, Teresi JA, Goland R, Izquierdo R, Palmas W, Eimicke JP, Ebner S, Shea S. Glycemic control and health disparities in older ethnically diverse underserved adults with diabetes: five-year results from the Informatics for Diabetes Education and Telemedicine (IDEATel) study. Diabetes Care. 2011;34:274-279. [pmid: 21270184].
Wen L, Parchman ML, Linn WD, Lee S. Association between self-monitoring of blood glucose and glycemic control in patients with type 2 diabetes mellitus. American journal of health-system pharmacy : AJHP : official journal of the American Society of Health-System Pharmacists. 2004;61:2401-5. [pmid: 15581263].
Widgren BR, Herlitz H, Jonsson O, Berglund G, Wikstrand J, Andersson OK. Normotensive young men with family histories of hypertension gain weight and decrease their intraerythrocyte sodium content during a 5-year follow-up. J. INTERN. MED. 91(229):217-223.
Williams K, Prevost AT, Griffin S, Hardeman W, Hollingworth W, Spiegelhalter D, Sutton S, Ekelund U, Wareham N, Kinmonth AL. The ProActive trial protocol - a randomised controlled trial of the efficacy of a family-based, domiciliary intervention programme to increase physical activity among individuals at high risk of diabetes. BMC Public Health. 2004;4:48. [pmid: 15491494].
Williams L, Germov J, Young A. The effect of social class on mid-age women's weight control practices and weight gain. Appetite. 2011;56:719-725. [pmid: 21333702].
Wing RR, Matthews KA, Kuller LH, Smith D, Becker D, Plantinga PL, Meilahn EN. Environmental and familial contributions to insulin levels and change in insulin levels in middle-aged women. JAMA. 92(268):1890-5.
Wood MD, Fairlie AM, Fernandez AC, Borsari B, Capone C, Laforge R, Carmona-Barros R. Brief motivational and parent interventions for college students: a randomized factorial study. Journal of consulting and clinical psychology. 2010;78:349-61. [pmid: 20515210].
Zemel MB, Shi H, Greer B, Dirienzo D, Zemel PC. Regulation of adiposity by dietary calcium. FASEB J. 2000;14:1132-8. [pmid: 10834935].

## Non-English language

Bjerkedal T, Brevik JI. Geographic variation in body mass index among Norwegian conscripts born 1967-80: Geografiske variasjoner i kroppsmasseindeks malt ved sesjon for menn fodt i Norge 1967-80. Tidsskr. Nor. Laegeforen. 2001;121:3505-3508. [pmid: 11808008].
Coelho MS, Assis MA, Moura EC. Body mass index increase after the age of 20 and associations with risk or protection factors for chronic non-communicable diseases. Arq Bras Endocrinol Metabol. 2009;53:1146-56. [pmid: 20126873].
Crosetto MA, Acosta RS, Asaduroglu AV, Henain Y, Picech V, Ojeda S. Nutritional status in older adults beneficiaries of a social programme with food component implemented in the city of Cordoba. Year 2000. Rev Fac Cien Med Univ Nac Cordoba. 2001;58:29-48. [pmid: 12934259].
Dalmau Llorca MR, García Bernal G, Aguilar Martín C, Palau Galindo A. Group versus individual education for type-2 diabetes patients. Atencion Primaria / Sociedad Española De Medicina De Familia y Comunitaria. 2003;32(1):36-41. [pmid: 12812689].
De Castro ME, Rolim MO, Mauricio TF. Prevention of hypertension and its relation to the lifestyle of workers. [Portuguese]. Acta Paulista de Enfermagem. 2005;18:184-189.
Drygas W, Jegier A, Bednarek-Gejo A, Kwasniewska M, Dziankowska-Zaborszczyk E, Kostka T. Physical activity volume as a key factor influencing obesity and metabolic syndrome prevalence in middle-aged men. Long-term prospective study. Przegl Lek. Suppl 3. 2005;62:8-13. [pmid: 16521910].
Duquet N. Management of overweight persons in the public pharmacy. J Pharm Belg. 2009:39-47. [pmid: 19739527].
Gaede PH, Jepsen PV, Larsen JN, Jensen GV, Parving HH, Pedersen OB. The Steno-2 study. Intensive multifactorial intervention reduces the occurrence of cardiovascular disease in patients with type 2 diabetes. Ugeskrift for laeger. 2003;165:2658-61. [pmid: 12886549].
Gaede PH, Jepsen PV, Larsen JN, Jensen GV, Parving HH, Pedersen OB. The Steno-2 study. Intensive multifactorial intervention reduces the occurrence of cardiovascular disease in patients with type 2 diabetes. Ugeskrift for laeger. 2003;165:2658-61. [pmid: 12886549].
Galvez G. The educational dimension of control of weight. Enfoques Aten Prim. 88(3):19-26.
Gautier JF, Oppert JM. Role of physical activity in the management of the obese patient. Soins. 2004:9-12. [pmid: 15151085].
Gomez Mont F, Ramirez C, Palacios E. Contribution of the General Hospital of the National Medical Center to medicine. V. Management of obesity by complete fasting. I. Influence of dietetic factors in the prolonged fast-breaking syndrome in humans. Gac Med Mex. 67(97):878-84.
Hüppe A, Parow D, Raspe H. Effectiveness and benefit of a screening procedure to identify patients with diabetes mellitus type 2 in need of rehabilitation: a randomised, controlled trial among members of the Hamburg Münchener Health Insurance. Gesundheitswesen (Bundesverband Der Ärzte Des Öffentlichen Gesundheitsdienstes (Germany)). 2008;70(10):590-9. [pmid: 18932120].
Lazic D, Cikac T, Ozvacic Z, Cop R. GP's intervention in changing lifestyle behavior of adipose patients. Acta Med Croatica. 2007;61:7-11. [pmid: 17593634].
Meng K, Cho AJ, Kong SK. A case-control study on risk factors for the major cardiovascular deaths in Korean men: hypertensive disease and cerebrovascular disease. Ingu Pogon Nonjip. 87(7):3-23.
Misuraca G, Boncompagni F, Chiatto M, Battista F, Serafini O, Talarico A, Plastina F. A health education program for the prevention of heart diseases carried out in a population in Calabria. Minerva Med. 99(90):385-90.
Moczar C, Borda F, Farago K, Borgulya G, Braunitzer F, Voros V. Effect of healthy life style in overweight and obese patients. Orv Hetil. 2007;148:65-9. [pmid: 17344121].
Rocha AK, Bos AJ, Huttner E, Machado DC. Prevalence of metabolic syndrome in indigenous people over 40 years of age in Rio Grande do Sul, Brazil. Rev Panam Salud Publica. 2011;29:41-5. [pmid: 21390418].
Rodriguez M, Sanchez Fernandez, MD. Effectiveness of a group educational intervention in patients with chronic obstructive pulmonary disease. [Spanish]. Enfermeria Clinica. 2003;13:131-136.
Rugulies R, Jager A, Benesch L, Siegrist J. Comprehensive lifestyle changes among patients with CHD and the integration of inpatient and outpatient cardiac rehabilitation: First results of a secondary prevention intervention trial. Zeitschrift fur Gesundheitswissenschaften. 96(4):234-247.
Saltiel H. Obesity as a symptom: psychodynamic classification and therapeutic management. Sem Hop. 73(49):3629-38.
Sculati O, Bettoncelli G, Brignoli O, Corgatelli G, Ponti D, Rumi A, Zucchi A. Efficient prevention of overweight and obesity in the experience of family practitioners and “nutrition units” of the public health system in Lombardy. Ann Ig. 2006;18:41-8. [pmid: 16649502].
Serra Majem L, Ribas Barba L, Salvador Castell G, Roman Vinas B, Castell Abat C, Cabezas Pena C, Pastor Ferrer MC, Raido Quintana B, Ngo de la Cruz J, Garcia Alvarez A, Serra Farro J, Salleras Sanmarti L, Taradach Antoni P. Trends in the nutritional status of the Spanish population: results from the Catalan nutrition monitoring system (1992-2003). Rev Esp Salud Publica. 2007;81:559-70. [pmid: 18274358].
Tao LL, Deng YB, Fan XB, Bao QD. Effect of exercise training in patients with impaired glucose tolerance. Zhongguo Linchuang Kangfu. 2004;8:2912-3.
Thommessen MH, Martinsen EW, Arsky GH. Diet and physical activity in Norwegian psychiatric institutions. Tidsskr Nor Laegeforen. 2005;125:3297-9. [pmid: 16327859].
Turnin MC, Bourgeois O, Cathelineau G, Leguerrier AM, Halimi S, Sandre-Banon D, Coliche V, Breux M, Verlet E, Labrousse F, Bensoussan D, Grenier JL, Poncet MF, Tordjmann F, Brun JM, Blickle JF, Mattei C, Bolzonella C, Buisson JC, Fabre D, Tauber JP, Hanaire-Broutin H. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. 2001;27:1.

## Observational Studies

Cummins S, Fagg J. Does greener mean thinner? Associations between neighbourhood greenspace and weight status among adults in England. Int J Obes. 2011;36:1108-13.
Friedenreich CM, Woolcott CG, McTiernan A, et al. Adiposity changes after a 1-year aerobic exercise intervention among postmenopausal women: a randomized controlled trial. Int J Obes. 2011;35:427-35.
Giesen JCAH, Havermans RC, Nederkoorn C, et al. Impulsivity in the supermarket. Responses to calorie taxes and subsidies in healthy weight undergraduates. Appetite. 2012;58:6-10. [pmid: 22019544].
Jakobsen MU, Due KM, Dethlefsen C, et al. Fish consumption does not prevent increase in waist circumference in European women and men. Br J Nutr. 2011:1-8. Epub ahead of print.
Mozaffarian D, Hao T, Rimm EB, et al. Changes in diet and lifestyle and long-term weight gain in women and men. New Engl J Med. 2011;364:2392-2404. [pmid: 21696306].
Sjosten N, Kivimaki M, Singh-Manoux A, et al. Change in physical activity and weight in relation to retirement: the French GAZEL Cohort Study. BMJ Open. 2012;2:e000522.
Streppel MT, de Groot LCPGM, Feskens EJM. Nutrient-rich foods in relation to various measures of anthropometry. Fam Pract. 2012;29:i36-i43. [pmid: 22399554].
Tang TS, Funnell MM, Oh M. Long-lasting effects of a 2-year diabetes self-management (DSMS) intervention: outcomes at 1-year follow-up. Diabetes. 2011;60:A83.
Vergnaud AC, Norat T, Romaguera D, et al. Fruit and vegetable consumption and prospective weight change in participants of the European Prospective Investigation into Cancer and Nutrition-Physical Activity, Nutrition, Alcohol, Cessation of Smoking, Eating Out of Home, and Obesity study. Am J Clin Nutr. 2012;95:184-93. [pmid: 22170373].
Verheijden MW, van Dommelen P, van Empelen P, et al. Changes in self-reported energy balance behaviours and body mass index during a mass media campaign. Fam Pract. 2012;29(Suppl 1):i75-i81. [pmid: 22399561].
Williams PT. Exercise attenuates the association of body weight with diet in 106,737 runners. Med Sci Sports Exerc. 2011;43:2120-6. [pmid: 21502899].

## Other

Dejoy DM, Wilson MG, Padilla HM, et al. Process Evaluation Results From an Environmentally Focused Worksite Weight Management Study. Health Educ Behav. 2011;39:405-418. [pmid: 22002249].
Djuric Z, Ren J, Brown PR, et al. Lifestyle factors associated with serum N-3 fatty acid levels in breast cancer patients. Breast. 2012;21:608-11. [pmid: 22377591].
Fisher EB, Boothroyd RI, Coufal MM, et al. Peer support for self-management of diabetes improved outcomes in international settings. Health Aff. 2012;31:130-9.
Glasgow RE, Kurz D, King D, et al. Twelve-month outcomes of an Internet-based diabetes self-management support program. Patient Educ Couns. 2012;87:81-92. [pmid: 21924576].
McHugh J, Suggs LS. Online tailored weight management in the worksite: does it make a difference in biennial health risk assessment data?. J Health Commun. 2012;17:278-93. [pmid: 22188131].
Merrill RM, Anderson A, Thygerson SM. Effectiveness of a worksite wellness program on health behaviors and personal health. J Occup Environ Med. 2011;53:1008-12. [pmid: 21860328].
Neubeck L, Freedman SB, Briffa T, et al. Four-year follow-up of the Choice of Health Options In prevention of Cardiovascular Events randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2011;18:278-86. [pmid: 20606594].
Nybacka A, Carlstrom K, Stahle A, et al. Randomized comparison of the influence of dietary management and/or physical exercise on ovarian function and metabolic parameters in overweight women with polycystic ovary syndrome. Fertil Steril. 2011;96:1508-13. [pmid: 21962963].
Roumen C, Feskens EJ, Corpeleijn E, et al. Predictors of lifestyle intervention outcome and dropout: the SLIM study. Eur J Clin Nutr. 2011;65:1141-7. [pmid: 21587283].
Saito T, Watanabe M, Nishida J, et al. Lifestyle modification and prevention of type 2 diabetes in overweight Japanese with impaired fasting glucose levels: a randomized controlled trial. Arch Intern Med. 2011;171:1352-60. [pmid: 21824948].
Somers TJ, Blumenthal JA, Guilak F, et al. Pain coping skills training and lifestyle behavioral weight management in patients with knee osteoarthritis: A randomized controlled study. Pain. 2012;53:1199-209. [pmid: 22503223].
Vanwormer JJ, Linde JA, Harnack LJ, et al. Self-Weighing Frequency Is Associated with Weight Gain Prevention over 2 Years Among Working Adults. Int J Behav Med. 2011. Epub ahead of print.