# Screening and Data Abstraction Forms

Appendix C shows all of the data screening forms (Title, abstract, and article level). Inclusion and exclusion criteria used in these forms are described in the body of the report. Data abstraction forms and study quality forms are also illustrated in this appendix.