# Detailed Search Strategies

## PubMed

KQ 1-5

(((“ideal body weight”[mh] OR “normal weight”[tiab] OR overweight[mh] OR overweight[tiab] OR “body mass index”[mh] OR “body mass index”[tiab] OR BMI[tiab] OR “healthy weight”[tiab] OR obesity[mh] OR obesity[tiab] OR obese[tiab]) AND (maintenance[tiab] OR maintain[tiab] OR management[tiab] OR manage[tiab] OR (“weight gain”[tiab] AND prevent*[tiab])) AND (diets[tiab] OR diet[mh] OR diet[tiab] OR “energy intake”[tiab] OR nutrition[tiab] OR exercise[mh] OR exercise[tiab] OR walking[mh] OR walking[tiab] OR walk[tiab] OR running[mh] OR running[tiab] OR run[tiab] OR jogging[tiab] OR jog[tiab] OR biking[tiab] OR bike[tiab] OR aerobics[tiab] OR “resistance training”[mh] OR training[tiab] OR “physical activity”[tiab] OR pharmaceutical[tiab] OR drug[tiab] OR medication[tiab] OR prescription[tiab] OR “orlistat”[Supplementary Concept] OR “orlistat”[tiab] OR behavior[tiab] OR behavioral[tiab])) NOT (“ anorexia nervosa”[mh] OR anorexia[mh] OR anorexia[tiab] OR anorectic[tiab] OR “bulimia nervosa”[mh] OR bulimia[mh] OR bulimia[tiab] OR bulimic[tiab] OR cachexia[mh] OR cachexia[tiab] OR fragility[tiab] OR “gestational weight gain”[tiab])) NOT ((infant[mh] OR infant[tiab] OR child[mh] OR child[tiab] OR children[tiab] OR adolescent[mh] OR adolescent[tiab] OR “teen-age”[tiab] OR pediatric[tiab] OR perinatal[tiab]) NOT (adult[tiab] OR adults[tiab] OR Mother[tiab] OR father[tiab] OR family[tiab] OR parent[tiab] OR men[mh] OR men[tiab] OR women[mh] OR women[tiab])) NOT (animal[mh] NOT human[mh])

KQ 6

(((“ideal body weight”[mh] OR “normal weight”[tiab] OR overweight[mh] OR overweight[tiab] OR “body mass index”[mh] OR “body mass index”[tiab] OR BMI[tiab] OR “healthy weight”[tiab] OR obesity[mh] OR obesity[tiab] OR obese[tiab] OR “body weight”[tiab]) AND ((“weight gain”[tiab] AND (prevent*[tiab] OR reduce[tiab])) OR “health Policy”[mh] OR “built environment”[tiab] OR “environment design”[mh] OR “purchasing behavior”[tiab] OR “purchasing behaviors”[tiab] OR “food labeling”[mh] OR “calorie information”[tiab] OR “calorie labeling”[tiab] OR campaign[tiab] OR Tax*[tiab] OR taxes[mh] OR “income inequality”[tiab])) NOT (“anorexia nervosa”[mh] OR anorexia[mh] OR anorexia[tiab] OR anorectic[tiab] OR “bulimia nervosa”[mh] OR bulimia[mh] OR bulimia[tiab] OR bulimic[tiab] OR cachexia[mh] OR cachexia[tiab] OR fragility[tiab] OR “gestational weight gain”[tiab])) NOT ((infant[mh] OR infant[tiab] OR child[mh] OR child[tiab] OR children[tiab] OR adolescent[mh] OR adolescent[tiab] OR “teen-age”[tiab] OR pediatric[tiab] OR perinatal[tiab]) NOT (adult[tiab] OR adults[tiab] OR Mother[tiab] OR father[tiab] OR family[tiab] OR parent[tiab] OR men[mh] OR men[tiab] OR women[mh] OR women[tiab])) NOT (animal[mh] NOT human[mh])

## Cochrane

#1 | [underlined: MeSH descriptor Overweight explode all trees] | 5928 | [underlined: edit] | [underlined: delete]
#2 | [underlined: MeSH descriptor Body Mass Index explode all trees] | 4326 | [underlined: edit] | [underlined: delete]
#3 | [underlined: MeSH descriptor Obesity explode all trees] | 5628 | [underlined: edit] | [underlined: delete]
#4 | [underlined: “ideal body weight”:ti,ab,kw] | 261 | [underlined: edit] | [underlined: delete]
#5 | [underlined: “normal weight”:ti,ab,kw] | 615 | [underlined: edit] | [underlined: delete]
#6 | [underlined: (overweight):ti,ab,kw] | 2549 | [underlined: edit] | [underlined: delete]
#7 | [underlined: “body mass index”:ti,ab,kw] | 8472 | [underlined: edit] | [underlined: delete]
#8 | [underlined: (BMI):ti,ab,kw] | 3931 | [underlined: edit] | [underlined: delete]
#9 | [underlined: “healthy weight”:ti,ab,kw] | 40 | [underlined: edit] | [underlined: delete]
#10 | [underlined: (obesity):ti,ab,kw] | 7510 | [underlined: edit] | [underlined: delete]
#11 | [underlined: (obese):ti,ab,kw] | 4650 | [underlined: edit] | [underlined: delete]
#12 | [underlined: (#1 OR #2)] | 8660 | [underlined: edit] | [underlined: delete]
#13 | [underlined: (#1 OR #2 OR #3)] | 8693 | [underlined: edit] | [underlined: delete]
#14 | [underlined: (#1 OR #2 OR #3 OR #4)] | 8884 | [underlined: edit] | [underlined: delete]
#15 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5)] | 9219 | [underlined: edit] | [underlined: delete]
#16 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6)] | 9888 | [underlined: edit] | [underlined: delete]
#17 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7)] | 13041 | [underlined: edit] | [underlined: delete]
#18 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8)] | 14024 | [underlined: edit] | [underlined: delete]
#19 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9)] | 14035 | [underlined: edit] | [underlined: delete]
#20 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10)] | 15214 | [underlined: edit] | [underlined: delete]
#21 | [underlined: (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11)] | 15838 | [underlined: edit] | [underlined: delete]
#22 | [underlined: (maintenance):ti,ab,kw] | 14312 | [underlined: edit] | [underlined: delete]
#23 | [underlined: (maintain):ti,ab,kw] | 20748 | [underlined: edit] | [underlined: delete]
#24 | [underlined: (management):ti,ab,kw] | 29637 | [underlined: edit] | [underlined: delete]
#25 | [underlined: (manage):ti,ab,kw] | 5874 | [underlined: edit] | [underlined: delete]
#26 | [underlined: “weight gain”:ti,ab,kw and (prevent*):ti,ab,kw] | 733 | [underlined: edit] | [underlined: delete]
#27 | [underlined: (#22 OR #23)] | 32861 | [underlined: edit] | [underlined: delete]
#28 | [underlined: (#22 OR #23 OR #24)] | 60432 | [underlined: edit] | [underlined: delete]
#29 | [underlined: (#22 OR #23 OR #24 OR #25)] | 64014 | [underlined: edit] | [underlined: delete]
#30 | [underlined: (#22 OR #23 OR #24 OR #25 OR #26)] | 64598 | [underlined: edit] | [underlined: delete]
#31 | [underlined: (#21 AND #30)] | 2583 | [underlined: edit] | [underlined: delete]
#32 | [underlined: MeSH descriptor Diet explode tree 2] | 7951 | [underlined: edit] | [underlined: delete]
#33 | [underlined: (diet):ti,ab,kw] | 18724 | [underlined: edit] | [underlined: delete]
#34 | [underlined: MeSH descriptor Exercise explode all trees] | 8013 | [underlined: edit] | [underlined: delete]
#35 | [underlined: (exercise):ti,ab,kw] | 30192 | [underlined: edit] | [underlined: delete]
#36 | [underlined: MeSH descriptor Walking explode all trees] | 1801 | [underlined: edit] | [underlined: delete]
#37 | [underlined: (walking):ti,ab,kw] | 6274 | [underlined: edit] | [underlined: delete]
#38 | [underlined: MeSH descriptor Running explode all trees] | 952 | [underlined: edit] | [underlined: delete]
#39 | [underlined: (running):ti,ab,kw] | 6902 | [underlined: edit] | [underlined: delete]
#40 | [underlined: “energy intake”:ti,ab,kw] | 3319 | [underlined: edit] | [underlined: delete]
#41 | [underlined: (nutrition):ti,ab,kw] | 7755 | [underlined: edit] | [underlined: delete]
#42 | [underlined: (jogging):ti,ab,kw] | 194 | [underlined: edit] | [underlined: delete]
#43 | [underlined: (biking):ti,ab,kw] | 65 | [underlined: edit] | [underlined: delete]
#44 | [underlined: (aerobics):ti,ab,kw] | 72 | [underlined: edit] | [underlined: delete]
#45 | [underlined: “resistance training”:ti,ab,kw] | 1239 | [underlined: edit] | [underlined: delete]
#46 | [underlined: (training):ti,ab,kw] | 23079 | [underlined: edit] | [underlined: delete]
#47 | [underlined: “physical activity”:ti,ab,kw] | 3847 | [underlined: edit] | [underlined: delete]
#48 | [underlined: (pharmaceutical):ti,ab,kw] | 4832 | [underlined: edit] | [underlined: delete]
#49 | [underlined: (drug):ti,ab,kw] | 278919 | [underlined: edit] | [underlined: delete]
#50 | [underlined: (medication):ti,ab,kw] | 26504 | [underlined: edit] | [underlined: delete]
#51 | [underlined: (prescription):ti,ab,kw] | 3404 | [underlined: edit] | [underlined: delete]
#52 | [underlined: (behavior):ti,ab,kw] | 26437 | [underlined: edit] | [underlined: delete]
#53 | [underlined: (behavioral):ti,ab,kw] | 12644 | [underlined: edit] | [underlined: delete]
#54 | [underlined: (#32 OR #33)] | 19829 | [underlined: edit] | [underlined: delete]
#55 | [underlined: (#32 OR #33 OR #34)] | 26398 | [underlined: edit] | [underlined: delete]
#56 | [underlined: (#32 OR #33 OR #34 OR #35)] | 47458 | [underlined: edit] | [underlined: delete]
#57 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36)] | 48275 | [underlined: edit] | [underlined: delete]
#58 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37)] | 50561 | [underlined: edit] | [underlined: delete]
#59 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38)] | 50769 | [underlined: edit] | [underlined: delete]
#60 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39)] | 55262 | [underlined: edit] | [underlined: delete]
#61 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40)] | 55513 | [underlined: edit] | [underlined: delete]
#62 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41)] | 60671 | [underlined: edit] | [underlined: delete]
#63 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42)] | 60688 | [underlined: edit] | [underlined: delete]
#64 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43)] | 60707 | [underlined: edit] | [underlined: delete]
#65 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44)] | 60714 | [underlined: edit] | [underlined: delete]
#66 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45)] | 60857 | [underlined: edit] | [underlined: delete]
#67 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46)] | 75226 | [underlined: edit] | [underlined: delete]
#68 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47)] | 76076 | [underlined: edit] | [underlined: delete]
#69 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48)] | 80637 | [underlined: edit] | [underlined: delete]
#70 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49)] | 332153 | [underlined: edit] | [underlined: delete]
#71 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50)] | 337997 | [underlined: edit] | [underlined: delete]
#72 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51)] | 338669 | [underlined: edit] | [underlined: delete]
#73 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52)] | 351638 | [underlined: edit] | [underlined: delete]
#74 | [underlined: (#32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53)] | 355196 | [underlined: edit] | [underlined: delete]
#75 | [underlined: (#21 AND #30 AND #74)] | 2215 | [underlined: edit] | [underlined: delete]
#76 | [underlined: MeSH descriptor Anorexia Nervosa explode all trees] | 259 | [underlined: edit] | [underlined: delete]
#77 | [underlined: MeSH descriptor Anorexia explode all trees] | 182 | [underlined: edit] | [underlined: delete]
#78 | [underlined: MeSH descriptor Bulimia Nervosa explode all trees] | 114 | [underlined: edit] | [underlined: delete]
#79 | [underlined: MeSH descriptor Bulimia explode all trees] | 329 | [underlined: edit] | [underlined: delete]
#80 | [underlined: MeSH descriptor Cachexia explode all trees] | 112 | [underlined: edit] | [underlined: delete]
#81 | [underlined: (anorexia):ti,ab,kw] | 1475 | [underlined: edit] | [underlined: delete]
#82 | [underlined: (anorectic):ti,ab,kw] | 127 | [underlined: edit] | [underlined: delete]
#83 | [underlined: (bulimia):ti,ab,kw] | 719 | [underlined: edit] | [underlined: delete]
#84 | [underlined: (bulimic):ti,ab,kw] | 203 | [underlined: edit] | [underlined: delete]
#85 | [underlined: (cachexia):ti,ab,kw] | 198 | [underlined: edit] | [underlined: delete]
#86 | [underlined: (fragility):ti,ab,kw] | 190 | [underlined: edit] | [underlined: delete]
#87 | [underlined: “gestational weight gain”:ti,ab,kw] | 18 | [underlined: edit] | [underlined: delete]
#88 | [underlined: (#76 OR #77)] | 441 | [underlined: edit] | [underlined: delete]
#89 | [underlined: (#76 OR #77 OR #81)] | 1475 | [underlined: edit] | [underlined: delete]
#90 | [underlined: (#76 OR #77 OR #81 OR #82)] | 1571 | [underlined: edit] | [underlined: delete]
#91 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78)] | 1666 | [underlined: edit] | [underlined: delete]
#92 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79)] | 1928 | [underlined: edit] | [underlined: delete]
#93 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83)] | 2160 | [underlined: edit] | [underlined: delete]
#94 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83 OR #84)] | 2175 | [underlined: edit] | [underlined: delete]
#95 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83 OR #84 OR #80)] | 2248 | [underlined: edit] | [underlined: delete]
#96 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83 OR #84 OR #80 OR #85)] | 2306 | [underlined: edit] | [underlined: delete]
#97 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83 OR #84 OR #80 OR #85 OR #86)] | 2496 | [underlined: edit] | [underlined: delete]
#98 | [underlined: (#76 OR #77 OR #81 OR #82 OR #78 OR #79 OR #83 OR #84 OR #80 OR #85 OR #86 OR #87)] | 2514 | [underlined: edit] | [underlined: delete]
#99 | [underlined: (( #21 AND #30 AND #74 ) AND NOT #98)] | 2139 | [underlined: edit] | [underlined: delete]
#100 | [underlined: (infant):ti,ab,kw] | 29797 | [underlined: edit] | [underlined: delete]
#101 | [underlined: (child):ti,ab,kw] | 59501 | [underlined: edit] | [underlined: delete]
#102 | [underlined: (adolescent):ti,ab,kw] | 75425 | [underlined: edit] | [underlined: delete]
#103 | [underlined: (pediatric):ti,ab,kw] | 8793 | [underlined: edit] | [underlined: delete]
#104 | [underlined: (perinatal):ti,ab,kw] | 1683 | [underlined: edit] | [underlined: delete]
#105 | [underlined: (#100 OR #101 OR #102)] | 124337 | [underlined: edit] | [underlined: delete]
#106 | [underlined: (#100 OR #101 OR #102 OR #103)] | 125798 | [underlined: edit] | [underlined: delete]
#107 | [underlined: (#100 OR #101 OR #102 OR #103 OR #104)] | 126500 | [underlined: edit] | [underlined: delete]
#108 | [underlined: (adult):ti,ab,kw] | 273098 | [underlined: edit] | [underlined: delete]
#109 | [underlined: (mother):ti,ab,kw] | 5065 | [underlined: edit] | [underlined: delete]
#110 | [underlined: (father):ti,ab,kw] | 339 | [underlined: edit] | [underlined: delete]
#111 | [underlined: (family):ti,ab,kw] | 11368 | [underlined: edit] | [underlined: delete]
#112 | [underlined: (parent):ti,ab,kw] | 6961 | [underlined: edit] | [underlined: delete]
#113 | [underlined: (men):ti,ab,kw] | 31326 | [underlined: edit] | [underlined: delete]
#114 | [underlined: (women):ti,ab,kw] | 50133 | [underlined: edit] | [underlined: delete]
#115 | [underlined: (#108 OR #109)] | 276145 | [underlined: edit] | [underlined: delete]
#116 | [underlined: (#108 OR #109 OR #110)] | 276202 | [underlined: edit] | [underlined: delete]
#117 | [underlined: (#108 OR #109 OR #110 OR #111)] | 282178 | [underlined: edit] | [underlined: delete]
#118 | [underlined: (#108 OR #109 OR #110 OR #111 OR #112)] | 285730 | [underlined: edit] | [underlined: delete]
#119 | [underlined: (#108 OR #109 OR #110 OR #111 OR #112 OR #113)] | 296642 | [underlined: edit] | [underlined: delete]
#120 | [underlined: (#108 OR #109 OR #110 OR #111 OR #112 OR #113 OR #114)] | 312971 | [underlined: edit] | [underlined: delete]
#121 | [underlined: (#107 AND NOT #120)] | 49769 | [underlined: edit] | [underlined: delete]
#122 | [underlined: (#99 AND NOT #121)] | 2006 | [underlined: edit] | [underlined: delete]
#123 | [underlined: (prevent):ti,ab,kw] | 25951 | [underlined: edit] | [underlined: delete]
#124 | [underlined: (reduce):ti,ab,kw] | 97122 | [underlined: edit] | [underlined: delete]
#125 | [underlined: “weight gain”:ti,ab,kw] | 3595 | [underlined: edit] | [underlined: delete]
#126 | [underlined: (#124 AND ( #123 OR #124 ))] | 97122 | [underlined: edit] | [underlined: delete]
#127 | [underlined: “health policy”:ti,ab,kw] | 678 | [underlined: edit] | [underlined: delete]
#128 | [underlined: “ built environment”:ti,ab,kw] | 6 | [underlined: edit] | [underlined: delete]
#129 | [underlined: MeSH descriptor Environment Design explode all trees] | 45 | [underlined: edit] | [underlined: delete]
#130 | [underlined: “food labeling”:ti,ab,kw] | 29 | [underlined: edit] | [underlined: delete]
#131 | [underlined: (campaign):ti,ab,kw] | 611 | [underlined: edit] | [underlined: delete]
#132 | [underlined: MeSH descriptor Taxes explode all trees] | 30 | [underlined: edit] | [underlined: delete]
#133 | [underlined: (tax*):ti,ab,kw] | 1545 | [underlined: edit] | [underlined: delete]
#134 | [underlined: (#126 OR #127)] | 97738 | [underlined: edit] | [underlined: delete]
#135 | [underlined: (#126 OR #127 OR #128)] | 97744 | [underlined: edit] | [underlined: delete]
#136 | [underlined: (#126 OR #127 OR #128 OR #129)] | 97772 | [underlined: edit] | [underlined: delete]
#137 | [underlined: (#126 OR #127 OR #128 OR #129 OR #130)] | 97793 | [underlined: edit] | [underlined: delete]
#138 | [underlined: (#126 OR #127 OR #128 OR #129 OR #130 OR #131)] | 98256 | [underlined: edit] | [underlined: delete]
#139 | [underlined: (#126 OR #127 OR #128 OR #129 OR #130 OR #131 OR #132)] | 98280 | [underlined: edit] | [underlined: delete]
#140 | [underlined: (#126 OR #127 OR #128 OR #129 OR #130 OR #131 OR #132 OR #133)] | 99645 | [underlined: edit] | [underlined: delete]
#141 | [underlined: (( ( #21 AND #140 ) AND NOT #98 ) AND NOT #121)] | 4632 | [underlined: edit] | [underlined: delete]
#142 | [underlined: (#122 OR #141)] | 5806 | [underlined: edit] | [underlined: delete]

## EMBASE

‘body weight’/exp OR ‘body weight’:ab,ti OR ‘normal weight’:ab,ti OR ‘overweight’:ab,ti OR ‘over weight’:ab,ti OR ‘body mass index’:ab,ti OR ‘body mass’/exp OR ‘bmi’:ab,ti OR ‘healthy weight’:ab,ti OR ‘obesity’/exp OR obesity:ab,ti OR obese:ab,ti AND (‘weight gain’:ab,ti AND (prevent*:ab,ti OR reduc*:ab,ti) OR ‘built environment’:ab,ti OR ‘healthcare policy’/exp OR ‘health care policy’:ab,ti OR ‘health policy’:ab,ti OR ‘environmental planning’/exp OR ‘environmental planning’:ab,ti OR ‘environment design’:ab,ti OR ‘purchasing behavior’:ab,ti OR ‘purchasing behaviors’:ab,ti OR ‘food labeling’:ab,ti OR ‘calorie information’:ab,ti OR ‘calorie labeling’:ab,ti OR campaign:ab,ti OR ‘tax’/exp OR tax*:ab,ti OR ‘income inequality’:ab,ti) NOT (‘anorexia nervosa’/exp OR ‘anorexia nervosa’:ab,ti OR ‘anorexia’/exp OR anorexia:ab,ti OR anorectic:ab,ti OR ‘bulimia’/exp OR bulimia:ab,ti OR bulimic:ab,ti OR ‘cachexia’/exp OR cachexia:ab,ti OR fragility:ab,ti OR ‘gestational weight gain’:ab,ti) NOT (‘infant’/exp OR infant:ab,ti OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR ‘adolescent’/exp OR adolescent:ab,ti OR ‘teen-age’:ab,ti OR pediatric:ab,ti OR perinatal:ab,ti NOT (adult:ab,ti OR adults:ab,ti OR mother:ab,ti OR father:ab,ti OR family:ab,ti OR parent:ab,ti OR ‘men’/exp OR men:ab,ti OR ‘women’/exp OR women:ab,ti)) NOT (‘animal’/exp OR animal:ab,ti NOT (‘human’/exp OR human:ab,ti)) OR (maintenance:ab,ti OR maintain:ab,ti OR management:ab,ti OR (‘weight gain’:ab,ti AND prevent*:ab,ti) AND (‘body weight’/exp OR ‘body weight’:ab,ti OR ‘normal weight’:ab,ti OR ‘overweight’:ab,ti OR ‘over weight’:ab,ti OR ‘body mass index’:ab,ti OR ‘body mass’/exp OR ‘bmi’:ab,ti OR ‘healthy weight’:ab,ti OR ‘obesity’/exp OR obesity:ab,ti OR obese:ab,ti) AND (‘diet’/exp OR diet:ab,ti OR diets:ab,ti OR ‘energy intake’:ab,ti OR nutrition:ab,ti OR ‘exercise’/exp OR exercise:ab,ti OR ‘walking’/exp OR walking:ab,ti OR walk:ab,ti OR running:ab,ti OR run:ab,ti OR jogging:ab,ti OR jog:ab,ti OR biking:ab,ti OR bike:ab,ti OR aerobics:ab,ti OR ‘resistance training’/exp OR ‘resistance training’:ab,ti OR training:ab,ti OR ‘physical activity’:ab,ti OR pharmaceutical:ab,ti OR drug:ab,ti OR medication:ab,ti OR prescription:ab,ti OR ‘tetrahydrolipstatin’/exp OR tetrahydrolipstatin:ab,ti OR orlistat:ab,ti OR behavior:ab,ti OR behavioral:ab,ti) NOT (‘anorexia nervosa’/exp OR ‘anorexia nervosa’:ab,ti OR ‘anorexia’/exp OR anorexia:ab,ti OR anorectic:ab,ti OR ‘bulimia’/exp OR bulimia:ab,ti OR bulimic:ab,ti OR ‘cachexia’/exp OR cachexia:ab,ti OR fragility:ab,ti OR ‘gestational weight gain’:ab,ti) NOT (‘infant’/exp OR infant:ab,ti OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR ‘adolescent’/exp OR adolescent:ab,ti OR ‘teen-age’:ab,ti OR pediatric:ab,ti OR perinatal:ab,ti NOT (adult:ab,ti OR adults:ab,ti OR mother:ab,ti OR father:ab,ti OR family:ab,ti OR parent:ab,ti OR ‘men’/exp OR men:ab,ti OR ‘women’/exp OR women:ab,ti)) NOT (‘animal’/exp OR animal:ab,ti NOT (‘human’/exp OR human:ab,ti)))