# List of Acronyms

Acronym: Definition
ADA: American Diabetes Association
ANOVA: Analysis of variance
BMI: Body mass index
DBP: Diastolic blood pressure
DEER: Diet and Exercise for Elevated Risk
GIS: Geographic Information Systems
HbA_1c_: hemoglobin A_1c_
ODES: Oslo Diet and Exercise Study
PICOTS: Population, intervention, comparators, outcomes, timing, and setting
PREDIMED: Prevencion con Dieta Mediterranea
PREPARE: Pre-diabetes Risk Education and Physical Activity Recommendation
RCT: Randomized clinical trial
SBP: Systolic blood pressure
TOHPII: Trials of Hypertension Prevention Phase II
VA: Veterans Administration
ADA_: American Diabetic Association; kg: kilogram
PA: Physical Activity
SM: Self management
NR: Not Reported
WC: Waist Circumference
CM: Centimeter
ND: Reported no difference between groups without providing values
RCT: Randomized controlled trial
KQ: Key Question