# Results

## Introduction

This chapter presents the results of the systematic review of the literature on primary care management of abnormal uterine bleeding (AUB). We present findings for Key Question 1 (KQ1) beginning with an overview of the content of the literature as a whole, followed by results and detailed analysis organized first by studies addressing irregular uterine bleeding (KQ1A) and then by studies addressing abnormal cyclic uterine bleeding (KQ1B). When there are distinct populations in which the interventions have been studied such as enrollment based on differing criteria, we discuss related data together. Within KQs we present summary information in the order: devices, medications, lifestyle and behavioral interventions, and complementary and alternative medicine. Within a category such as medication, we organize the results from greater number of studies to fewer, and presented the results of placebo controlled trials before direct comparisons. These analyses are followed by review of the studies and supplemental information addressing KQ2, which pertains to harms associated with the interventions identified for KQ1.

Studies also are described in summary tables, generally organized to present particular common outcomes, like change in volume of bleeding, in a single summary in the relevant section of text. Details on quality assessment and individual components of the quality scoring for individual studies can be found in Appendix I. Information about the overall strength of evidence supporting the effectiveness of specific interventions (or lack of utility) is summarized by related outcomes in the Discussion.

## Results of Literature Searches

Searches identified 1,775 titles and abstracts for screening for KQ1. From this broad screening, we reviewed the publication abstracts and identified 219 publications as potentially eligible for inclusion. Following a review of the full text, we identified 39 studies described in 41 publications that met the predetermined criteria for inclusion. Publications from 10 studies addressed KQ1A. Thirty-one publications from 29 studies addressed KQ1B. Overall 6 of these studies were rated as good quality, 10 as fair, and 23 as poor with regard to risk of bias in the findings. Details of the scoring of individual publications are included in Appendix I.

We conducted a separate search and screening process for KQ2. We identified 2,730 titles and abstracts for screening. Of these, 788 references were promoted for full-text review. Using predefined criteria, we found 25 publications that were eligible for inclusion. We received 4 of 17 requested industry packets and obtained package inserts for each KQ1 included drug intervention. See Figures 2 (KQ1) and 3 (KQ2) for a diagram of literature search and screening.

Figure 2 Flow diagram of literature search and screening (KQ1)

KQ = Key Question; RCT = randomized controlled trial

^a^ After duplicates removed.

^b^ Total does not equal number excluded as publications could be excluded for multiple reasons.

The literature flow diagram illustrates the number of citations retrieved from electronic database searches (n=1980) and hand searches (n=0) for Key Questions 1A and 1B. The number of citations retrieved after exclusion of duplicates was 1775. At the level of abstract screening, 1556 citations were excluded. Of 219 citations that were promoted for full-text review the diagram lists the individual reasons for exclusion: not original research (n=23); not an RCT (randomized controlled trial) (n=70); basic science, anatomy, imaging, prevalence, physiology, biomarker/biological mechanism study (n=25); not target population/insufficient data from target population (n=87); bleeding due to structural abnormalities, cancer, medication side effects, systemic disease, or endometrial hyperplasia (n=35); post-menopausal women (n=9); surgical intervention (n=7); contraceptive study (n=24); does not address key question or other (n=122). The diagram notes that the exclusion reason counts do not tally as publications could be excluded for multiple reasons. The figure indicates that the total number of included papers is 41 with 10 for Key Question 1A and 31 for Key Questions 1B.

Figure 3 Flow diagram of literature search and screening (KQ2)

KQ1 = Key Question 1; LNG-IUS = levonorgestrel-releasing intrauterine system; TXA = tranexamic acid; CVR = contraceptive vaginal ring

^a^ Total does not equal number excluded as publications could be excluded for multiple reasons.

^b^ Numbers do not tally as papers could include data on harms for more than one intervention.

The literature flow diagram illustrates the number of citations retrieved from electronic database searches (n=2711), hand searches (n=19) for Key Question 2. The number of citations retrieved after exclusion of duplicates was 2730. At the level of abstract screening, 1942 citations were excluded. Of 788 citations that were promoted for full text review the diagram lists the individual reasons for exclusion: not original research (n=68); did not include data from a population of 1600 or more (n=153); from general population or reporting of harms was not an objective of study (n=24); did not report harms data for an intervention addressed in Key Question 1 (n=527); basic science, anatomy, imaging, prevalence, physiology, biomarker/biological mechanism study (n=3); men only (n=17); post-menopausal women or population aged 65 or older (n=101); other (n=26); unable to obtain (n=4). The diagram notes that these the numbers for these reasons do not tally as publications could be excluded for multiple reasons. The figure indicates that the total number of included papers is 25, of which 9 addressed harms of the levonorgestrel-releasing intrauterine system; 7 addressed harms of a progesterone; 1 addressed harms of tranexamic acid; 3 addressed harms of the contraceptive vaginal ring; and 10 addressed harms of other medications addressed by included publications for Key Question 1A or 1B. A search of systematic reviews related to harms yielded 120 citations, of which 38 were included.

The complete list of excluded papers and exclusion reasons is provided in Appendix K for KQ1 and in Appendix L for KQ2.

## Description of Included Studies

Included studies evaluated 12 different interventions including: levonorgestrel-releasing intrauterine system (LNG-IUS), nonsteroidal anti-inflammatory drugs (NSAIDs), combined oral contraceptives (COCs), tranexamic acid (TXA), contraceptive vaginal ring, metformin, exenatide, progestogens, cabergoline, lifestyle/behavioral changes, acupuncture, and decision aids using at least one comparator or placebo arm. Table 4 includes a complete list of the medications from the included studies. Twenty-one studies were head-to-head comparisons and 14 of the included studies established intervention efficacy by comparison to placebo. Four studies compared the intervention to usual or existing care. The majority of studies (29 studies reported in 31 publications) included in this review recruited women with complaints of abnormal cyclic uterine bleeding (KQ1B). Ten of the included studies targeted women with irregular uterine bleeding (KQ1A). Fourteen studies (36 percent) included some measure of patient reported outcome. Sixteen studies (41 percent) included some measure of symptom resolution or normalization.

Table 4 Medications from studies included in the CER

Medication | Brand Name
Levonorgestrel-releasing intrauterine system | Mirena^®^
Contraceptive vaginal ring | NuvaRing^®^
Antifibrinolytic Agents
Tranexamic acid, oral | Lysteda^®^
Combined Oral Contraceptives, Oral
Estradiol valerate and dienogest, oral | Natazia^®^
Ethinyl estradiol (0.03 mg) and levonorgestrel (0.15 mg), oral | Nordette^®^, Altavera^®^, Levora^®^, Marlissa^®^, Portia^®^ 28
Ethinyl estradiol (0.20 mg) and norethindrone acetate (1.0 mg), oral | Loestrin^®^ 21 1/20, Junel^®^ 1/20, Microgestin^®^ 1/20, Minestrin^®^ 1/20
Norgestimate ethinyl estradiol (triphasic), oral | Ortho Tri-Cyclen^®^, Tri-Sprintec^®^, Tri-Previfem^®^, MonoNessa^®^, Ortho Tri-Cyclen^®^ Lo, Ortho-Cyclen^®^, Sprintec^®^, TriNessa^®^
Progestogens
Dydrogesterone, oral | Gynorest^®^ International brand names: Dabroston, Dufaston, Duphaston^®^, Terolut
Medroxyprogesterone acetate, injectable suspension | Depo-Provera^®^ CI, Depo-subQ Provera 104
Medroxyprogesterone acetate, oral | Provera^®^
Norethisterone/norethindrone, oral | Aygestin^®^
Progesterone, vaginal gel | Crinone^®^
Nonsteroidal Anti-Inflammatory Drugs
Flurbiprofen, oral | Ansaid^®^
Meclofenamate | Meclomen^®^
Mefenamic acid, oral | Ponstel^®^
Naproxen sodium, oral | Naprosyn^®^, Anaprox^®^ DS, Anaprox^®^, Naprosyn^®^ Suspension, EC-Naprosyn^®^, Various OTC brands
Other
Cabergoline, oral | Dostinex^®^
Exenatide, injection | Byetta^®^
Ethamsylate, etamsylate | International brand names: Altodor, Dicinone, Dicynene, Dicynone, Eselin^®^, Ethamsyl, Hemo 141, Hemoced, Impedil
Metformin hydrochloride, oral | Glucophage^®^, Glucophage XR^®^, Fortamet^®^, Glumetza^®^

The duration of the studies included in this review was generally short. Studies addressing KQ1A had a duration of 6 months or less with most (7/10) lasting 3 to 4 months. For KQ1B, study duration ranged from 2 cycles to 2 years. The majority of the studies (22/29) evaluating an intervention for abnormal cyclic bleeding lasted 6 months or less. Two studies that compared the effectiveness of LNG-IUS with COC lasted for 1 year. Of the two studies on the use of decision aids, one included a 1-year followup and the other included a 2-year followup.

We did not identify publications that explicitly focused on reducing heavy menstrual blood loss (MBL) in the context of irregular menses, especially menses with extended intervals between episodes of bleeding. The publications included for KQ1A are focused exclusively on irregular bleeding patterns, most often oligomenorrhea (fewer cycles than normal across months). Studies that met the criteria for inclusion for KQ1A evaluated progestogens (1 study),49 COCs (1 study),50 metformin (4 studies),51-53,54 exenatide (1 study),53 cabergoline (1 study),55 diet (1 study),56 and exercise (1 study),57 and acupuncture (2 studies).57,58 These total to more than 10 since several were direct comparisons. Two studies were good quality,50,55 2 were fair quality,51,58 and 6 were poor quality.49,52-54,56,57

For KQ1B, most of the included studies evaluated LNG-IUS (7 studies),59-65 NSAIDs (13 studies)63,66-77 or TXA (7 studies).66,71,77-81 We identified 5 studies59,61,68,82,83 that evaluated the use of COCs for the management of AUB and 1 study of the contraceptive vaginal ring.84 We found 3 studies85-87 that evaluated decision aids for the management of AUB. Included studies evaluated the effect of these interventions on MBL, quality of life, menstrual cycle patterns, and other clinical and functional outcomes. Among the most common outcome metrics was change in MBL expressed as a percent. This was typically reported as a comparison of post-treatment blood loss to baseline. The alkaline hematin method and the pictorial blood loss assessment chart score were used to measure MBL. The alkaline hematin method, the current gold standard for estimating MBL, requires women to collect their used feminine hygiene products; consequently, it is rarely used outside of a research setting.88,89 The pictorial blood loss assessment chart score is a practical, semi quantitative method of estimating MBL, in which women indicate the type of product used and the degree of saturation using a chart for guiding classification.90-92

For KQ2, we identified 23 publications reporting on harms of the included interventions. We also reviewed and summarized harms reported in the randomized controlled trials (RCTs) from KQ1 and from the package inserts for all products and prescription interventions included in KQ1.

## KQ1A Management of Irregular Uterine Bleeding

### Description of Included Studies

As noted in the description of the overall literature yield for this review, we did not identify publications that explicitly focused on mitigating the heaviness of irregular uterine bleeding. Symptoms like gushing or soaking type bleeding commonly occur in the context of irregular menses, especially menses with extended intervals between episodes of bleeding. The publications available to be included for this KQ focused on improving the regularity of bleeding and enrolled participants with bleeding categorized by the research teams as “dysfunctional uterine bleeding” or irregular bleeding with oligomenorrhea (i.e., fewer cycles than normal).

Studies were included whether or not participants reported menorrhagia (heavy bleeding) as long as the authors reported on the use of the intervention to improve cycle regularity. We did not review the literature on infertility or subfertility resulting from absent or infrequent ovulation, even when it included cycle regularity data. Interventions for fertility treatment in this group, like clomiphene, are distinct from those for symptom management used in primary care settings. Likewise research populations of infertile women likely lack comparability to the broader population of women whose primary complaint is irregular cycles and may include women with subfertility who are seeking treatment for problem bleeding.

Overall 10 studies addressed restoring menstrual regularity in those with irregular uterine bleeding. Three were conducted in the United States,50,53,56 two in Italy,52,55 two in Turkey,49,54 and one each in China,58 Sweden,57 and the United Kingdom.51 The studies ranged in size from 23 to 201 participants and examined the efficacy of metformin (4 studies),51-54 acupuncture (2 studies),57,58 diet and exercise (1 study),56 cabergoline (1 study),55 progestogen (1 study),49 and triphasic birth control pills (1 study).50 Two studies were classified as good quality,50,55 two as fair quality,51,58 and six as poor quality49,52-54,56,57 with respect to risk of bias in the assessment of effectiveness of the intervention of improving cycle regularity. Details of quality scoring for individual publications are included in Appendix I.

Overall these 10 studies, that included women with irregular uterine bleeding, offer incomplete evidence that medications, possibly diet and exercise, and potentially acupuncture may offer some benefit for establishing more predictable menstrual bleeding patterns. They provide no direct evidence about the ability to reduce the heaviness of bleeding or the symptoms and bother associated with intermittent heavy bleeding because quantity of bleeding and patient-reported outcomes other than timing of bleeding were not among the outcomes for these trials.

### Key Points

- Metformin improves regularity of menstrual bleeding in women with polycystic ovarian syndrome (PCOS) when evaluated over months. When combined with exenatide, a newer injectable drug typically used for type 2 diabetes, the effect is greater than either metformin or exenatide alone over 6 months of followup in a single study of 60 women.
- In a very preliminary investigation of cabergoline, a drug typically used for elevated prolactin, three of eight women with PCOS and normal prolactin levels resumed regular cycles while none did in the six-person placebo group.
- Both oral dydrogesterone and vaginal micronized progesterone gel administered on a cyclic schedule had comparable influence on normalizing timing of menses.
- Triphasic norgestimate-ethinyl estradiol birth control pills provided excellent or good control of bleeding abnormalities in 68 percent of those taking active pills compared with 26 percent of those receiving placebo.
- In adolescents both a low-fat, calorie-restricted diet or a carbohydrate-restricted diet along with 30 minutes of anaerobic exercise 3 days a week resulted in more regular menses if the individual lost weight.
- Acupuncture improved cycle regularity in two trials, one in which both acupuncture and exercise (30 minutes 3 days each week) resulted in improvements by 32 weeks compared with placebo. In this study acupuncture provided more rapid relief by 16 weeks than exercise. Another poorly-described study found more individuals “cured” using needle placement specific for mind tranquilizing and menstruation promotion compared with those for delayed menses.
- In summary a number of available interventions appropriate for use in primary care settings have preliminary evidence of effectiveness for increasing the regularity of menses. Only metformin consistently demonstrated benefit across studies and each of these studies enrolled women with oligomenorrhea and PCOS.
- Overall, literature is absent to inform choice of any of these modalities over another.

### Detailed Synthesis

#### Medical Therapies

Seven studies, two conducted in the United States, two in Italy, two in Turkey, and one in the United Kingdom examined medical therapies to improve menstrual interval.49-55 Five included women who met detailed criteria for PCOS51-55 and two included women classified as having dysfunctional uterine bleeding by clinical criteria that are not tightly operationalized but include extended intervals between cycles.49,50 We first present the findings for the RCTs that enrolled women with irregular uterine bleeding and then the data from PCOS trials.

##### Medical Therapies for Irregular Uterine Bleeding

Two studies, one comparing a triphasic oral contraceptive with placebo and one comparing vaginal micronized progesterone (8% gel) with oral dydrogesterone, evaluated medical therapy in women with irregular uterine bleeding (Table 5).

Table 5 Primary outcomes of medical interventions for irregular uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Cycle Control Outcomes
Davis et al., 2000^50^ United States Good | G1: Triphasic norgestimate-ethinyl estradiol oral contraceptive (101) G2: Placebo (100) | - Study population included women with oligomenorrhea, menorrhagia, menometrorrhagia, and polymenorrhea.; - Investigators classified resolution of bleeding abnormalities from diaries as excellent or good in 41.2% and 26.8% of those receiving intervention and 10.5% and 15.8% of those on placebo (p<0.001).; - Women's self-assessments were similar to the investigators' and indicated better outcomes in those receiving the oral contraceptive (p<0.001).
Karakus et al., 2009^49^ Turkey Poor | G1: Vaginal micronized progesterone, 90 mg every other night for 10 days (34) G2: Oral dydrogesterone, 10 mg daily for 10 days (35) | - Both groups achieved comparable regularity of bleeding patterns in the 3 treated cycles observed: 92.6%, 88.9%, and 92.6% in the vaginal group, and 81.5%, 88.9%, and 85.2% in oral group (p>0.5).; - Satisfaction with intervention was comparable between groups (p=0.5).

###### Triphasic Oral Contraceptives

Oral contraceptives over-ride the hypothalamic-pituitary-ovarian axis coordination of ovarian sex steroid production. By providing exogenous estrogen and progestogen, oral contraceptives are intended to regulate cycle control pharmacologically. A single RCT50 evaluated a triphasic norgestimate-ethinyl estradiol preparation compared with placebo among women classified as having dysfunctional uterine bleeding. Triphasic oral contraceptives have three distinct levels of progestogen (norgestimate in this study) and estrogen (ethinyl estradiol) over the course of the 21 days of active pills in a typical 28 day oral contraceptive pill pack, compared with monophasic pills which have the same hormone level provided across all 21 days of active pills.

The researchers randomized 201 women at a 1:1 ratio to receive either the study drug or placebo for three 28-day cycles. Data from 192 patients were included in the outcome analyses. The study enrolled participants with a variety of menstrual concerns including heavy periods, frequent periods, irregular and heavy periods, and rare episodes of bleeding. Investigators did not systematically evaluate for the presence of disorders of hemostasis. The data are provided in aggregate for all participants regardless of their bleeding pattern or primary symptom. The study drug regimen included 0.18 mg norgestimate and 0.035 mg ethinyl estradiol for days 1 to 7, 0.215 mg norgestimate and 0.035 mg ethinyl estradiol for days 8 to 14, 0.25 mg norgestimate and 0.035 mg ethinyl estradiol for days 15 to 21, and inactive tablets for days 22 to 28. The primary efficacy outcomes included the investigator and the subject's overall assessment of improvement in AUB symptoms.

Both the investigator assessments and subject assessments of symptom improvement indicated significant (p<0.001) improvement in cycle control in the study drug group compared with the placebo group. The investigator assessed some level of subject improvement (fair, good, or excellent) in 81.4 percent of triphasic norgestimate ethinyl estradiol-treated patients as compared with 35.8 percent of placebo-treated patients; the proportions of subject-rated improvement were similar to investigator ratings. Among several quality of life measures assessed, improvement over baseline was only observed in physical functioning in the triphasic norgestimate ethinyl estradiol-treated patients compared with their placebo-treated counterparts.

This good quality, multicenter, industry-sponsored trial was conducted in the United States and appears to have been conducted to expand the indication for a particular brand name to include cycle control for women with dysfunctional uterine bleeding. The trial was published in 2000 and was the only study identified that included women with problem bleeding from irregular and closely spaced or rare menses.

###### Progestogens

Prior to menses without ovulation the sequence of biologic events that includes a rise in progesterone and then a precipitous drop does not occur. This is because the literal site of ovulation, the corpus luteum, is responsible for production of progesterone. In the absence of conception, the corpus luteum involutes and ceases production. This rise and fall in progesterone has multiple biological effects on the endometrium which include “organization” that results in a coordinated withdrawal bleed, the menses, after progesterone levels fall. Administration of a progestogen is intended therapeutically to mimic natural production of progesterone and then withdrawal.

A single RCT sought to compare the efficacy of oral dydrogesterone, 10 mg twice daily for 10 days starting on cycle day 15, compared with vaginal micronized progesterone (8 percent gel) applied every other evening from cycle days 17 to 27. Both groups had improvements in cycle regularity compared with their baseline (p value not provided).49 Regular bleeding patterns were observed in more than 89 percent of the three treated cycles in the vaginal administration group, and more than 82 percent of the oral group. Improvement in bleeding patterns was comparable for both groups (p>0.5). Satisfaction with the intervention was also comparable across groups.

##### Medical Therapies for PCOS

Three medical therapies (metformin, exenatide, and cabergoline) were evaluated in five trials that enrolled women with PCOS (Table 6). We present the findings from the study of cabergoline followed by findings from four studies that evaluated metformin or exenatide. In summary, each of the studies of medical therapies reported findings that favor the medical intervention for establishing more predictable cycles in women with PCOS. No medication was effective for all participants though several exceeded 80 percent of those on active therapy achieving improvements in cycle regularity. The number and size of studies is small and overall the quality is fair to poor with one small pilot study of good quality design and implementation but limited by lack of statistical power.

Table 6 Primary outcomes of medical interventions for irregular uterine bleeding in women with PCOS

Author, Year Country Quality | Comparison Groups (n) | Key Cycle Control Outcomes
Paoletti et al., 1995^55^ Italy Good | G1: Cabergoline, 0.5 mg each week (8) G2: Placebo (6) | 3 of 8 women receiving cabergoline resumed regular cycles. 5 of 8 had onset of menses within 32 to 37 days of treatment initiation. Among women receiving placebo 3 had no menses and 3 had menstrual cycles that were widely separated in time. (No statistical comparisons are provided.)
Fleming et al., 2002^51^ United Kingdom Fair | G1: Metformin, 850 mg twice a day (45) G2: Placebo (47) | Mean time to first ovulation was shorter with metformin (23.6 days) than placebo (41.8 days) (p=0.02). Total ovulation events where higher among women receiving metformin over 16 weeks (p=0.59). Pregnancy rate not different among those who desired to conceive (4 of 23 in G1 and 1 of 19 in G2).
Oner and Muderriss 2011^54^ Turkey Poor | G1: Metformin, 500 mg 3 times a day (50) G2: N-acetyl-cysteine, 600 mg 3 times a day (50) | Menstrual regularity improved significantly (p≤0.05) from baseline in G1 (from 17% to 47%) and G2 (from 29% to 53%). There was no significant difference in improvement from baseline between G1 and G2.
Elkind-Hirsch et al., 2008^53^ United States Poor | G1: Exenatide, 10 mcg twice a day (20) G2: Metformin, 500 mg twice a day (20) G3: Both (20) | The combination of exenatide and metformin was superior to either medication alone for improving menstrual frequency. Women taking both had 80% of menses predicted for a normal pattern, compared with 57% (G1) and 49% (G2).
Moghetti et al., 2000^52^ Italy Poor | G1: Metformin, 500 mg twice a day (11)^a^ G2: Placebo (12)^a^ | Study enrolled women with fewer than 6 menses per year and followed for 26 weeks. “Menstrual frequency” improved with metformin compared with placebo (p=0.002).

a total n=23; exact group size not specified.

###### Cabergoline

Cabergoline is a dopamine agonist used in treatment of pituitary adenomas, which are benign hormone producing growths in the pituitary often producing elevated prolactin levels. Mechanism of effectiveness for restoring cycles in PCOS may include amplifying dopamine neurotransmitter actions in the central nervous system resulting in hypoprolactinemia and lower levels of hormone signals that increase androgen production by the ovary.55

One good quality RCT55 conducted in Italy evaluated cabergoline for improving menstrual cyclicity. In this preliminary study of 14 women, authors compared time to onset of menses and regularity of cycle in women treated with cabergoline (0.5 mg per week) with women receiving placebo. No statistical comparisons are reported, only the summary that five of the eight women receiving cabergoline had menses with three of them resuming regular cycles over 4 months. All women taking placebo had either no cycles (n=3) or widely spaced cycles (n=3).

###### Metformin and Exenatide

Metformin, the most common choice for initial type 2 diabetes management, reduces liver glucose production and increases uptake and use of glucose in other tissues throughout the body. Because relative insulin resistance is one of the manifestations of PCOS, metformin is believed to disrupt this part of the syndrome by improving insulin response. Exenatide, a newer agent for treatment of type 2 diabetes introduced in 2005, is administered by subcutaneous injection. This drug promotes increased insulin release in response to blood glucose and it dampens glucagon activity. Glucagon is the natural hormone which promotes glucose release from storage in the liver. It is often administered as a second agent to improve glycemic control in those with type 2 diabetes. As metformin, it may improve the relative insulin resistance seen in PCOS.

One British51 and one Italian52 RCT evaluated metformin compared with placebo for improving menstrual cycle regularity among women with PCOS defined by rare or absent menstrual cycles, and hyperandrogenic chronic anovulation. The larger trial in the United Kingdom enrolled 82 women and randomly assigned them to an 850 mg dose twice a day. As with typical administration the dose was initiated at a lower level and increased over a week to reduce risk of gastrointestinal distress. Over the course of 16 weeks those on metformin ovulated sooner, an average of 18.2 days earlier (p=0.02), than those receiving placebo. Those on metformin also had a higher total number of ovulatory events (p=0.059). The Italian study (n=23), used a metformin dose of 500 mg 3 times a day (also after a ramp up) and reported “menstrual frequency” improved (p=0.002), without additional definitions of the outcome.

A poor quality trial (n=100)54 in Turkey compared metformin (500 mg 3 times a day) to N-acetyl-cysteine (600 mg 3 times a day) for improving menstrual regularity in women with PCOS. Menstrual regularity improved significantly (p≤0.05) from baseline in both groups with no significant difference in improvement between groups.

A third trial in the United States compared three arms with 20 participants in each: metformin (500 mg twice each day), exenatide (10 mcg twice a day), and both.53 Participants were followed for 6 months. The primary outcome for this trial was the proportion of menses achieved over time compared with what would be a predicted normal pattern. For instance a woman predicted to have six menses over 6.5 months would have a menstrual index of 50 percent if she in fact had only three menses over that time. Women taking metformin had 57 percent of expected menstrual bleeds and those on placebo had 49 percent. Those taking both metformin and exenatide had 80 percent of the predicted normal number of menses which was a significant advantage in effectiveness.

#### Behavioral Interventions

A single, poor quality study in teens with PCOS in the United States (n=24), attempted to examine the influence of diet and exercise on restoration of normal menses (Table 7).56

Table 7 Primary outcomes of behavioral interventions for irregular uterine bleeding in women with PCOS

Author, Year Country Quality | Comparison Groups (n) | Key Cycle Control Outcomes
Ornstein et al., 2011^56^ United States Poor | G1: Hypocaloric low-fat diet (12) G2: Carbohydrate restriction without caloric or fat targets (12) | Both groups were asked to complete 30 minutes of aerobic exercise 3 times per week. Both lost similar amounts of weight over 12 weeks. Menstrual patterns are not reported by group. Amount of weight loss correlated with menstrual regularity.

##### Diet and Exercise

The rationale for examining the effects of diet and exercise is based on similar effects to the diabetes medications studied. Exercise improves glucose utilization and insulin sensitivity. Likewise diet, with even modest weight loss, can improve insulin response. The study advised girls in both intervention groups to spend 30 minutes in aerobic activity 3 times each week. One arm was instructed in how to keep a hypocaloric diet, consisting of less than 40 grams per day of fat. The other group was instructed in how to follow a low-carbohydrate (i.e., no more than 20 grams per day) diet without specific calorie targets or fat restriction. Among the 16 who completed the study, both groups lost comparable amounts of weight over 12 weeks, an average of 6.5 percent of bodyweight. The authors did not report menstrual patterns by diet treatment group; they report only that degree of weight loss correlated with menstrual regularity (r= −0.2, p=0.001).56

#### Complementary and Alternative Medicine

Two trials, one of fair quality58 and another of poor quality,57 report on use of acupuncture for menstrual regularity among women with oligomenorrhea from PCOS and dysfunctional uterine bleeding, respectively (Table 8).

Table 8 Primary outcomes of acupuncture for irregular uterine bleeding

Author, Year Country Population Quality | Comparison Groups (n) | Key Cycle Control Outcomes
Cai and Wu, 2009^58^ China Dysfunctional uterine bleeding Fair | G1: Acupuncture at points for mind tranquilizing and menstruation promotion (23) G2: Routine acupuncture points for delayed menses (17) | Based on self-reported scores, 67% of G1 were classified as cured compared with 19% of G2 over 3 cycles. 25% of G1 classified as markedly relieved compared with 19% of G2. There were no failures in G1 and 19% in G2 (p<0.05).
Jedel et al., 2011^57^ Sweden PCOS Poor | G1: Low-frequency electroacupuncture (33) G2: Brisk exercise at least 30 minutes 3 days per week (34) G3: No active intervention (17) | Electroacupuncture achieved greater improvement in regularity (+146% from baseline) compared with G2 (58% improvement) and G3 (17% worsening). All comparisons p<0.05 at 16 weeks. By 32 weeks, electroacupuncture (+121% increase in cycle regularity) and exercise (+42%) were comparable and both superior to no intervention (−17%).

PCOS = polycystic ovarian syndrome

##### Acupuncture

The smaller study (n=40)58 inadequately describes inclusion criteria specifying only that women were clinically diagnosed with dysfunctional uterine bleeding, and likewise operationalizes outcomes loosely by classifying participants as “cured” or not without providing a definition of what characteristics of the menstrual pattern or bleeding constituted a cure. The intervention of interest to the investigators was acupuncture for mind tranquilizing and menstruation promotion compared with a more conventional selection of needle sites used for delayed menses. Over three cycles more women were classified as cured using the mind-tranquilizing and menstruation promoting method (67% vs.19%); more women classified symptoms as markedly relieved, and there were no failures in the intervention compared with the usual approach arm (19%,, p<0.05).

The larger, poor quality study done in Sweden (n=84)57 randomized participants to low-frequency electroacupuncture for a total of 14 treatments, brisk exercise 30 minutes 3 times each week, or no active intervention. At 16 weeks electroacupuncture achieved greater improvement in menstrual regularity, defined as a ratio of the number of observed versus expected cycles. Women began the study with a ratio of 0.28 menses per expected cycle and improved in the electroacupuncture group to 0.69 menses per expected cycle a 146-percent increase in cycle regularity when compared with either exercise (58% improvement) or no active intervention (17% worsening) at 16 weeks. By 32 weeks, electroacupuncture (121% increase in cycle regularity) and exercise (42% increase in cycle regularity) were comparable and both superior to no intervention (17% decrease in cycle regularity).

## KQ1B Management of Abnormal Cyclic Bleeding

### Description of Included Studies

We identified 31 publications representing 29 studies addressing primary care interventions for the management of abnormal cyclic uterine bleeding. Most of the studies that qualified for inclusion evaluated the LNG-IUS (7 studies),59-65 NSAIDs (13 studies),63,66-77 or TXA (7 studies).66,71,77-81 We identified five studies59,61,68,82,83 that evaluated use of COCs for the management of AUB and one study of the contraceptive vaginal ring.84 We found three studies85-87 that evaluated decision aids for the management of AUB. The total number of interventions addressed is greater than the number of studies because of direct comparisons between one or more interventions within single studies. Included studies described interventions appropriate for primary care and compared these interventions to another intervention (16 studies), placebo (9 studies), or usual care (4 studies). The results are summarized below and details for each study are presented in the Evidence Table (Appendix J).

### Levonorgestrel-Releasing Intrauterine System (Mirena^®^)

#### Key Points

- LNG-IUS is associated with a clinically significant reduction in MBL ranging from 70 to 87 percent in studies lasting up to 1 year. However, there are no controlled longer-term followup studies.
- In comparison to progestogens, combined hormonal pills, and NSAIDs, LNG-IUS provided greater reduction in MBL.
- No head-to-head comparisons of LNG-IUS versus TXA were assessed. An indirect comparison of the percentage reduction and volume reduction in MBL suggests that LNG-IUS has a greater effect than TXA.

#### Detailed Synthesis

The LNG-IUS is an intrauterine, long-term, progestogen-only method of contraception licensed for 5 years of use. The system must be inserted and removed by a qualified practitioner, including primary care providers. The LNG-IUS has a T-shaped plastic frame with a rate-limiting membrane on the vertical stem that releases a daily dose of 20 micrograms of levonorgestrel into the endometrial space. The effects of the LNG-IUS are local and hormonal, including prevention of endometrial proliferation. The LNG-IUS is also licensed for the management of idiopathic menorrhagia or heavy menstrual bleeding.

Seven RCTs of LNG-IUS were included (Table 9).59-65 The number of study participants ranged from 39 to 165. The total number of women assigned to LNG-IUS was 275; study endpoint outcome measures were reported for 255.

Table 9 Primary outcomes of LNG-IUS for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Outcomes
Kaunitz et al., 2010^60^ United States, Canada, Brazil Fair | G1: LNG-IUS (82) G2: MPA,10 mg daily for 10 days of each cycle (83) | - Median reduction in MBL (alkaline hematin) was −128.7 ml in G1 compared with −17.8 ml in G2 after 6 cycles (p<0.001).; - Higher proportion of women with successful treatment (defined as MBL<80 ml and 50% or greater reduction in MBL from baseline) in G1 (84.8%) compared with G2 (22.2%) (p<0.001).
Irvine et al., 1998^64^ United Kingdom Fair | G1: LNG-IUS (22) G2: Norethisterone, 5 mg 3 times daily on cycle day 5 to 26 (22) | - MBL decreased significantly in both groups after 3 cycles (94% reduction for G1 and 87% reduction for G2).; - More women in G1 (76%) wished to continue treatment after 3 months as compared with G2 (22%).
Shaaban et al., 2011^59^ Egypt Poor | G1: LNG-IUS (56) G2: Low-dose COC, 30 mcg ethinyl estradiol and 150 mcg levonorgestrel (56) | - MBL assessed by alkaline hematin method significantly (p<0.001) decreased in both groups from baseline.; - Greater reduction in MBL measured by alkaline hematin method at 12 months in G1 (87.4 ± 11.3%) compared with G2 (34.9 ± 76.9%) (p=0.01).; - PBLAC scores decreased more in G1 (86.6 ± 17.0%) compared with G2 (2.5 ± 93.2%) at 12 months (p<0.001).; - Women in G1 had significant improvements in ferritin and hemoglobin at 12 months.; - Fewer bleeding days per year in G1 (34.5 ± 12.0) compared with G2 (65.1 ± 15.3) (p<0.001).
Endrikat et al., 2009^61^ Canada Poor | G1: LNG-IUS (20) G2: COC, 1 mg norethindrone acetate and 20 mcg ethinyl estradiol (19) | - PBLAC score decreased significantly (p<0.001) in both groups at 12 months.; - The MBL median score decreased more in G1 (from 228 to 13, −83% mean change) compared with G2 (from 290 to 72, mean change −68%) (p=0.002).; - Proportion of women with successful treatment (defined as MBL score<100 at 12 months) higher in G1 (80%) compared with G2 (37%) (p<0.009).; - Mean hemoglobin levels increased in both groups from baseline (p<0.001).
Kucuk and Ertan, 2008^62^ Turkey Poor | G1: LNG-IUS (44) G2: DMPA, single shot (44) G3: MPA, 5 mg daily (44) | - More women in G1 (86%) with successful treatment compared with G2 (75%) or G3 (68%).; - PBLAC scores, days of menstrual bleeding, and hemoglobin improved in all 3 groups from baseline.; - Mean MBL scores at 6 months were lower in G1 (77) compared with G2 (146) and G3 (154) (p<0.01).
Reid and Virtanen-Kari, 2005^63^ United Kingdom Poor | G1: LNG-IUS (25) G2: Mefenamic acid, 500 mg 3 times per day for first 4 days of cycle (26) | - MBL significantly reduced in both groups from baseline.; - After 6 months median MBL was 5 ml in G1 compared with 100 ml in G2 (p<0.001).
Lahteenmaki et al., 1998^65^ Finland Poor | G1: LNG-IUS (28) G2: Usual care (28) | - Proportion of women cancelling hysterectomy was 64% in G1 vs. 14.3% in G2 (p<0.001).

COC = combined oral contraceptive; DMPA = depot medroxyprogesterone; LNG-IUS = levonorgestrel-releasing intrauterine system; MBL = menstrual blood loss; MPA = medroxyprogesterone; PBLAC = pictorial blood loss assessment chart

Criteria for participation varied among the studies. Three trials assessed MBL using the alkaline hematin method for study entry and required that women have a mean MBL of 80 ml or more for at least one63,64 or two 60 cycles prior to randomization. One study required that study participants report a pictorial blood loss assessment chart score greater than 100 for two consecutive cycles. For one trial, the inclusion criterion was self-defined as “heavy menstrual bleeding”, although mean MBL and pictorial blood loss assessment scores were reported at baseline.59 For one trial the inclusion criterion was intention to undergo hysterectomy for AUB not due to a fibroid greater than 3 cm.65 In one trial, the authors did not adequately describe the inclusion criteria, although organic causes were excluded.62 Baseline median and mean MBL values differed among the studies.

The target intervention was the same for all seven trials: LNG-IUS (52 mg levonorgestrel, initial release rate 20 mcg per 24 hours). The comparator differed among the 7 trials. Two trials compared LNG-IUS to a COC, including continuous daily ethinyl estradiol (30 mcg)/levonorgestrel (150 mcg)59 and cyclic monthly norethindrone acetate (1 mg)/ethinyl estradiol (20 mcg) for days 1 to 21.^61^ Three trials compared LNG-IUS with a progestogen: single intramuscular injection of depot medroxyprogesterone acetate (DMPA) on the first day of the cycle,62 oral tablet of medroxyprogesterone acetate (MPA; 5 mg) daily starting on the first day of the cycle,62 oral MPA (10 mg) daily for 10 days each cycle starting on cycle day 16,^60^ and norethisterone (5 mg) 3 times daily from cycle day 5 to 26 for three cycles.64 One trial compared LNG-IUS with oral mefenamic acid (500 mg) 3 times daily for first 4 days of each cycle.63 One trial assigned the patients in the control group to continue their preexisting medical treatment for excessive uterine bleeding or symptoms of dysmenorrhea, or both.65

The primary outcome of six of the LNG-IUS studies was change in blood loss. The alkaline hematin method was used to measure MBL in four trials.59,60,63,64 One of these four reported both mean and median MBL.60 Two studies only reported median MBL63,64 and one study only reported mean MBL.59 Two trials used the pictorial blood loss assessment score for the primary outcome measure.61,62 Two trials used the pictorial blood loss assessment chart as a secondary outcome measure.59,63 One study reported the proportion of women who cancelled their prior decision to undergo hysterectomy as the primary outcome measure.65

The timing of the summative outcome measure reporting varied among the trials. One trial reported after one menstrual cycle.64 Three trials reported after three menstrual cycles.60,63,64 Four trials reported after six menstrual cycles.60,62,63,65 Two trials reported after 12 months.59,61

The setting varied: one trial was conducted in three countries (Brazil, Canada, and the United States);60 two trials were conducted in the United Kingdom;63,64 the remainder of studies were conducted in Egypt,59 Canada,61 Turkey,62 and Finland.65 Two studies were assessed as fair quality,60,64 and five were of poor quality related to inadequate allocation concealment, lack of blinding of participants and assessors, and selective outcome reporting.59,61-63,65 Details of quality scoring for individual publications are included in Appendix I.

#### Description of Results

##### Outcome Measures

All but one of the LNG-IUS studies reported MBL using the alkaline hematin method or pictorial blood loss assessment score as the primary outcome. Four trials59,60,63,64 used the alkaline hematin method to measure MBL and four trials used the pictorial blood loss assessment chart to estimate blood loss.59,61-63 Two studies also reported treatment success as an outcome, defined as MBL less than 80 ml60 or pictorial blood assessment score less than 100.^61^ One trial reported the proportion of women who cancelled their prior decision to undergo hysterectomy as the primary outcome measure.65 Other outcome measures reported in the studies of LNG-IUS included total bleeding and spotting days, hemoglobin, ferritin, treatment failure, and menorrhagia severity score.

##### Menstrual Blood Loss

###### Reduction Expressed as a Percent

Three studies reported the percent reduction in MBL from baseline (Table 10). A fair quality multicenter trial with 165 participants compared LNG-IUS with oral MPA administered during the luteal phase of the cycle and reported a mean reduction in MBL of 71 percent (SD ± 88%) in the LNG-IUS group compared with 22 percent (SD ± 36%) in the MPA group at the 6-month interval (p<0.001).60 In a small fair quality RCT conducted in the United Kingdom,64 the change in MBL was comparable between groups after 3 months of treatment with a 94-percent reduction in MBL for LNG-IUS users and an 87-percent reduction in MBL among women taking norethisterone.

Table 10 Percent change in blood loss from baseline in studies of LNG-IUS

Author, Year | Comparator | LNG-IUS Group | Comparator Group | LNG-IUS vs. Comparator
Kaunitz et al., 2010^60^ | MPA^a^ | −70.8 | −21.5 | p<0.001
Irvine et al., 1998^64^ | Norethisterone^b^ | −94.0 | −87.0 | p=NS
Shaaban et al., 2011^59^ | COC, continuous^c^ | −87.4 | −34.9 | p=0.013

COC = combined oral contraceptive; MPA = medroxyprogesterone

a Oral medroxyprogesterone acetate (10 mg) once daily for 10 consecutive days starting on day 16 in each cycle.

b 5 mg 3 times daily from day 5 to 26 of the cycle over three cycles.

c Ethinyl estradiol (30 mcg) and levonorgestrel (150 mcg).

A trial conducted in Egypt with 112 participants compared LNG-IUS with continuous combined ethinyl estradiol (30 mcg) and levonorgestrel (150 mcg; continuous COC) and reported an 87-percent (SD ± 12%) reduction in mean MBL in the LNG-IUS group compared with a 35-percent (SD ± 77%) reduction in the COC group at the 12-month interval (p=0.013).59

###### Reduction Expressed as a Volume

Four studies reported the absolute reduction in MBL from baseline (Table 11). The multicenter trial with 165 participants reported a statistically significant (p<0.001) reduction in median MBL after six menstrual cycles with LNG-IUS (128.8 ml) compared with those receiving MPA (17.8 ml).60

Table 11 Change in blood loss volume from baseline in studies of LNG-IUS

Author, Year | Comparator | LNG-IUS Group | Comparator Group | LNG-IUS vs. Comparator
Kaunitz et al., 2010^60^ | MPA | −128.8 ml | −17.8 ml | p<0.001
Irvine et al., 1998^64^ | Norethisterone | −104.0 ml | −94.0 ml | p=NS
Shaaban et al., 2011^59^ | COC, continuous | −255.6 ml | −156.1 ml | p<0.001
Reid and Virtanen–Kari, 2005^63^ | Mefenamic acid | −117.0 ml | −21.0 ml | p<0.001

COC = combined oral contraceptive; MPA = medroxyprogesterone

a Oral medroxyprogesterone acetate (10 mg) once daily for 10 consecutive days starting on day 16 in each cycle.

b 5 mg 3 times daily from day 5 to 26 of the cycle over three cycles.

c Ethinyl estradiol (30 mcg) and levonorgestrel (150 mcg).

The United Kingdom trial with 44 participants and 3 months duration reported similar reductions (p=NS) in median MBL for the LNG-IUS group (104 ml) and the norethisterone group (94 ml).64

The trial conducted in Egypt with 112 participants that compared LNG-IUS with continuous COC reported a statistically significant (p<0.001) reduction in mean MBL after 12 menstrual cycles with LNG-IUS (255.6 ml) compared with those receiving COC (156.1 ml).59 A trial conducted in the United Kingdom with 51 participants that compared continuous LNG-IUS with mefenamic acid for the first 4 days of each cycle reported a statistically significant (p<0.001) difference in reduction in median MBL after six menstrual cycles with LNG-IUS (117 ml) compared with those receiving mefenamic acid (21 ml ).63 The same study reported a statistically significant reduction in median pictorial blood loss assessment chart score: a 215 point reduction after six cycles with LNG-IUS compared with a 74-point reduction with mefenamic acid (p<0.001).63

##### Pictorial Blood Loss Assessment Chart Score

Four studies reported change in pictorial blood loss assessment chart score from baseline. A poor quality Canadian trial with 39 participants compared LNG-IUS with 20 mcg ethinyl estradiol and 1 mg norethindrone acetate (cyclic COC) and reported an 83-percent reduction in the mean pictorial blood loss assessment chart score in the LNG-IUS group (median scores declined from 228 to 12) compared with a 68-percent reduction in the cyclic COC group (median scores declined from 290 to 72) at 12 months.61

Another poor quality Turkish study of 132 women compared LNG-IUS use with either a single intramuscular injection of DMPA or with daily oral MPA. After 6 menstrual cycles, the LNG-IUS users had a mean score reduction of 210 compared with a reduction of 138 in the DMPA group (p<0.01), and a 76-point reduction in the MPA group (p<0.01). No significant difference was reported in the reductions in the pictorial blood loss assessment chart score between DMPA and MPA.62

The pictorial blood loss assessment was used in two trials that also measured MBL using the alkaline hematin method. One study reported a reduction in the mean pictorial blood loss assessment chart score of 90 percent (SD ± 12%) in the LNG-IUS group at the 6-month interval compared with a reduction of 42 percent (SD ± 54%) in the COC group.59 At 12 months, the mean scores declined by 275 (87%) for LNG-IUS users compared with only 51 (3%) for the women taking COCs.59 In another study, the change in median pictorial blood assessment scores from baseline was significantly greater (p<0.001) in the LNG-IUS group from 240 (range, 91 to 545) to 25 (range, 0 to 401) compared with the mefenamic acid group from 233 (range, 77 to 469) to 159 (range, 50 to 307) after six cycles of treatment. 63

##### Treatment Success

Three studies reported the percent of women with successful treatment; however the definition of success differed among the trials. The fair quality multicenter trial with 165 participants that compared LNG-IUS with oral MPA reported a 85 percent (67/79) success rate in the LNG-IUS group at the 6-month interval, compared with a 22 percent (18/81) success rate in the MPA group (p<0.001).60 Treatment success was defined as MBL less than 80 ml at the end of study and 50 percent or greater reduction in MBL from baseline.60

The poor quality Canadian trial with 39 participants that compared LNG-IUS with cyclic COC reported a treatment success of 80 percent (16/20) in the LNG-IUS group at the 12-month interval compared with 37 percent (7/19) in the cyclic COC group (p<0.009).61 Treatment success was defined as a pictorial blood loss assessment chart score less than 100 at 12 months.61

The poor quality Turkish study that compared LNG-IUS with DMPA injection or oral MPA use reported treatment success rates of 86 percent, 75 percent, and 68 percent, respectively.62 The criterion for determining treatment response was a pictorial assessment bleeding score less than 185 and stabilization or increase in hemoglobin levels.62

##### Total Bleeding Days and Total Spotting Days

The trial conducted in Egypt with 112 participants that compared LNG-IUS with continuous COC did not report baseline days of bleeding or spotting. The study did report that the endpoint number of bleeding days, adjusted for 1-year duration was 34.5 ± 12.0 for the LNG-IUS group and 65.1 ± 15.3 for the continuous COC group (p<0.001). The study also reported that the endpoint number of spotting days, adjusted for 1-year duration, was not different between the two groups.59

The trial conducted in Turkey with 132 participants that compared LNG-IUS with either a single intramuscular injection of DMPA or with daily oral MPA reported a statistically significant decrease in mean bleeding days after six menstrual cycles with all three interventions. No significant difference was reported in the decrease in bleeding days between LNG-IUS and DMPA and MPA.62

##### Hemoglobin

The trial conducted in Turkey with 132 participants that compared LNG-IUS with either a single intramuscular injection of DMPA or with daily oral MPA reported a statistically significant increase in hemoglobin after six menstrual cycles with all three interventions. The mean hemoglobin score was increased by 0.8 g/dl in the LNG-IUS group compared with 0.5 g/dl with DMPA (p<0.05) and compared with 0.6 g/dL with MPA (p<0.05). No significant difference was reported in the increase in hemoglobin between DMPA and MPA.62

The trial conducted in Egypt with 112 participants that compared LNG-IUS with continuous COC reported a statistically significant (p<0.001) increase in hemoglobin for the LNG-IUS group (1.2 g/dl) compared with the continuous COC group (−0.4 g/dl).59 The United Kingdom trial with 44 participants reported no significant differences in hemoglobin changes over 3 months.64 The Canadian trial with 39 participants that compared LNG-IUS with cyclic COC reported no significant differences in hemoglobin changes.61

##### Ferritin

The trial conducted in Egypt with 112 participants that compared LNG-IUS with continuous COC reported a statistically significant (p<0.001) increase in ferritin for the LNG-IUS group (56.7 mcg/dl) compared with the continuous COC group (−34.3 mcg/dl).59 The United Kingdom trial with 44 participants and 3 months duration reported no significant differences in ferritin changes.64

##### Treatment Failure

The trial conducted in Egypt with 112 participants that compared LNG-IUS with continuous COC defined treatment failure as initiation of an alternative medical treatment or need for surgery or expulsion of the LNG-IUS. The trial reported a statistically significant (p=0.007) lower failure rate for the LNG-IUS group compared with the continuous COC group (hazard ratio= 0.30; 95% CI, 0.14 to 0.73).59

##### Proportion of Women Who Cancelled Hysterectomy

An open randomized multicenter study conducted in Finland with 56 women aged 33 to 49 scheduled to undergo hysterectomy for treatment of excessive uterine bleeding reported that 64 percent (95% CI, 44 to 81%) of women in the LNG-IUS group compared with 14 percent (95% CI, 4 to 33%) of women in the control group (continued current medical treatment) had cancelled their decision to undergo hysterectomy after 6 months (p<0.001).65

#### Head-to-Head Comparisons

##### LNG-IUS Versus COC

Both the trial that compared LNG-IUS to continuous COC (daily 30 mcg of ethinyl estradiol and 150 mcg levonorgestrel)59 and the trial that compared LNG-IUS to cyclic COC ( 1 mg norethindrone acetate and 20 mcg ethinyl estradiol for days 1 to 21)61 found that LNG-IUS was superior to COC for blood loss reduction expressed as a percent (83 to 90% reduction in mean pictorial blood loss assessment chart score for LNG-IUS compared with 42 to 68% for COC). One trial reported superiority of LNG-IUS for blood loss expressed as volume, total bleeding days, treatment failure, hemoglobin, and ferritin level.59 One of the trials reported superiority of LNG-IUS for achieving blood loss below the definition of heavy menstrual bleeding.61

##### LNG-IUS Versus Progestogens

The only outcome measure used by all three trials that compared progestogens to LNG-IUS was MBL reduction by volume.60,62,64 Two trials reported that LNG-IUS significantly reduced MBL compared with progestogens, including oral MPA (10 mg daily for 10 days starting on cycle day 16^60^ or 5 mg daily starting on cycle day 1^62^) and DMPA (single injection of on cycle day 1).62 A third trial reported no significant difference between LNG-IUS and norethisterone (5 mg 3 times daily from cycle day 5 to cycle day 26 for three cycles) for reducing MBL.64 The trials used different progestogen formulations and different measures of blood loss.60,62,64 One of the trials comparing LNG-IUS to oral MPA reported significantly greater treatment success, reduction in blood loss as a percentage, and women achieving blood loss less than the definition of heavy menstrual bleeding in the LNG-IUS group.60

##### LNG-IUS Versus Mefenamic Acid

A single trial reported significantly greater reduction in MBL for LNG-IUS (117 ml) compared with mefenamic acid (500 mg 3 times daily for first 4 days of cycle; 21 ml).63

###### Prevention of Hysterectomy

A single poor quality trial reported significantly more (p<0.001) women cancelled their decision to undergo hysterectomy in the LNG-IUS group (64%; 95% CI, 44 to 81%) compared with women who continued current medical treatment (14%; 95% CI, 4 to 33%).65

### Contraceptive Vaginal Ring

#### Key Points

- A single RCT reported that the contraceptive vaginal ring was as effective as norethisterone for improving bleeding.
- More women who were randomized to the vaginal ring were satisfied with treatment compared with women randomized to norethisterone.
- More women in the vaginal ring group elected to continue treatment than in the oral medication group.

#### Detailed Synthesis

We identified a single RCT of fair quality that compared the efficacy of the contraceptive vaginal ring to norethisterone in 95 women with abnormal cyclic uterine bleeding (Table 12). The study was conducted in Egypt among women with a pictorial blood loss assessment chart score over 185. The primary outcome measure was MBL after three cycles of treatment assessed using the pictorial blood loss assessment chart score. Other outcome measures included duration of menses, hemoglobin, ferritin, and quality of life.

Table 12 Primary outcomes of contraceptive vaginal ring for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Outcomes
Abu Hashim et al., 2012^84^ Egypt Fair | G1: Contraceptive vaginal ring, 15 mcg of ethinyl estradiol and 120 mcg etonogestrel inserted between day 1 and 5 of cycle and used for 3 weeks/cycle (48) G2: Norethisterone acetate tablets,5 mg 3 times daily on days 5 to 26 (47) | - Mean PBLAC score declined significantly (p<0.001) from baseline after 3 cycles for G1 (from 288 to 90) and G2 (from 302 to 92).; - Mean hemoglobin levels increased from baseline for both G1 (p=0.02) and G2 (p=0.03).; - Duration of menses was significantly shorter (p<0.001) for both G1 and G2.; - More women in G1 (71%) than in G2 (42.5%) were satisfied with treatment.; - More women in G1 (77%) than in G2 (25.5%) elected to continue treatment.

PBLAC = pictorial blood loss assessment chart; MBL = menstrual blood loss

The treatments were equally effective, reducing the patient-reported bleeding score by 67 percent in the contraceptive vaginal ring group and by 70 percent in the norethisterone group.84

### Nonsteroidal Anti-Inflammatory Drugs

#### Key Points

- The most commonly studied NSAID was mefenamic acid; other NSAIDs included naproxen, meclofenamate, and flurbiprofen.
- Overall, NSAIDs demonstrated significant reductions in MBL (20 to 49 percent) compared with baseline and were significantly more effective than placebo, but many women still have objective menorrhagia after treatment. Variability in treatment response with NSAIDs is considerable, including some individuals with increases in MBL with treatment.
- Comparing individual NSAIDs, there were no significant differences found in reductions of MBL between mefenamic acid and naproxen.
- In one RCT, LNG-IUS was significantly more effective at reducing MBL compared with mefenamic acid.
- In two trials, TXA had significantly greater reductions in MBL compared with either flurbiprofen or mefenamic acid.
- There were no significant differences between NSAIDs and either norethisterone, low-dose COC, ethamsylate, or an older progesterone-impregnated intrauterine coil in 5 trials.
- Studies were mostly of short duration with most lasting from 2 to 3 cycles.
- No studies examined quality of life, sexual function, fertility, or time to conception as an outcome. Quality of life needs further attention since most women will be offered treatment based on complaints/perception rather than objective measurement.
- NSAIDs are also effective against menstrual-related abdominal pain and cramping.

#### Detailed Synthesis

We identified 13 unique studies from 14 publications that examined the use of NSAIDs for abnormal cyclic uterine bleeding (Table 13). Seven were parallel group RCTs63,66,67,69,70,74,77 and six were randomized, crossover trials.68,71-73,75,76 Trials were conducted in seven different countries: Australia,68,76 Canada,73 India,69,77 the Netherlands,67 Sweden,71 United Kingdom,63,66,70,74,75 and the United States.72 The number of participants in each trial ranged from 19 to 110 with crossover trials ranging from 14 to 69. One study was assessed as good quality,72 three were assessed as fair quality,67,75,76 and nine were assessed as poor quality.63,66,68-71,73,74,77 Details of quality scoring for individual publications are included in Appendix I.

Table 13 Primary outcomes of NSAIDs for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Outcomes
Vargyas et al., 1987^72^ United States Good | G1^a^: Meclofenamate, 100 mg 3 times daily for 2 cycles followed by placebo for 2 cycles (15) G2: Placebo for 2 cycles, followed by meclofenamate for 2 cycles (17) | - Mean MBL during meclofenamate cycles (69.0 ± 6.3 ml) was significantly less than baseline (141.6 ± 15.9 ml) and during placebo cycles (135.6 ± 11.3 ml) (p<0.0001).; - Mean number of bleeding days was shorter during meclofenamate cycles (4.8 ± 0.2) than during placebo cycles (5.4 ± 0.18) (p<0.0003).; - Median hemoglobin, hematocrit, and serum ferritin levels did not change during the study.
Van Elijkeren et al., 1992^67^ Netherlands Fair | G1: Mefenamic acid, 500 mg 3 times daily (6) G2: Placebo (5) | - Mean MBL decreased 40% in G1 from baseline mean 108 ml to 65 ml (p=0.01) compared with increase in G2 from 151 ml to 189 ml (p=0.46).; - Patients were scheduled for hysterectomy.
Hall et al., 1987^75^ United Kingdom Fair | G1: Mefenamic acid 500 mg every 8 hrs. in phase 1 and naproxen in phase 2 (19)^a^ G2: Naproxen 550 mg loading dose followed by 275 mg every 6 hrs. in phase 1 followed by mefenamic acid in phase 2 (19)^a^ | - Treatment with mefenamic acid and naproxen reduced bleeding by average of 47 and 46% respectively.
Fraser et al., 1981, 1984^76,93^ Australia Fair | G1: Mefenamic acid, 500 mg 3 times daily for 2 cycles followed by placebo for 2 cycles (38)^a^ G2: Placebo for 2 cycles followed by mefenamic acid (31)^a^ | - Mefenamic acid significantly reduced mean MBL (28%) compared with placebo (p<0.001).; - Reductions were greater (30%) among women with MBL >80 ml at baseline (p<0.001).; - Only 30 out of 69 women had measured blood loss >80 ml during placebo cycles.
Najam et al., 2010^77^ India Poor | G1: TXA, 500 mg and mefenamic acid, 250 mg 3 times daily (55) G2: TXA, 500 mg 3 times daily (55) | - The mean PBLAC score in G1 declined from 246 to 100 at 6 months (p<0.01) and in G2 from 250 to 125 (p=NS).; - Hemoglobin levels significantly increased in both groups, from 8.6 to 12.3 in G1 (p=0.016) and from 9.5 to 12.0 in G2 (p=0.04).
Reid and Virtanen-Kari, 2005^63^ United Kingdom Poor | G1: LNG-IUS (25) G2: Mefenamic acid 500 mg 3 times daily for first 4 days of cycle (26) | - MBL significantly reduced in both groups from baseline but after 6 months median MBL was 5 ml in G1 compared with 100 ml in G2 (p<0.001).
Bonnar and Sheppard, 1996^66^ Ireland Poor | G1: Mefenamic acid, 500 mg (25) G2: TXA, 1 g (27) G3: Ethamsylate, 500 mg (29) | - TXA reduced MBL by 54% (mean decreased from 164 ml to 75 ml) and mefenamic acid reduced MBL by 20% (from 186 ml to 148 ml). Ethamsylate did not reduce MBL.; - Mean MBL for women in G1 remained >80 ml after 3 treatment cycles (148 ml; range, 138 to 168 ml).; - 77% in G2 and 74% in G1 wished to continue treatment.; - Improvement in dysmenorrheal was reported by 19% in G1, 13% in G2 and 4% in G3.
Fraser and McCarron, 1991^68^ Australia Poor | G1: Mefenamic acid, 500 mg every 6 to 8 hrs. for 2 cycles; naproxen, 500 mg at onset followed by 250 mg every 6 to 8 hrs. for 2 cycles (15)^a^ G2: Mefenamic acid, 500 mg every 6 to 8 hrs. for 2 cycles; low-dose COC (ethinyl estradiol 30 mcg and levonorgestrel 150 mcg) for 2 cycles (15)^a^ | - Mefenamic acid reduced MBL by 38% in G2 (p=0.002) and by 20% in G1 (p=0.198).; - Women treated with low-dose COC had 43% reduction in MBL (p<0.001).; - Naproxen resulted in a 12% reduction in MBL (p=0.079).
Grover et al., 1990^69^ India Poor | G1: Mefenamic acid, 500 mg, every 8 hours (40)^a^ G2: Placebo (40)^a^ | - 86% of women in G1 reported relief of menorrhagia compared with 20% in G2 (p<0.001).; - Mean bleeding days in G1 reduced from 9.7 ± 3.1 to 4.1 ± 0.6.
Cameron et al., 1990^70^ Scotland Poor | G1: Mefenamic acid, 500 mg 3 times daily (17) G2: Norethisterone, 5 mg twice daily (15) | - Median blood loss was significantly reduced in both groups from 123 ml to 81 ml in G1 (p<0.001) and from 109 ml to 92 in G2 (p<0.002).; - Median percentage reduction in blood loss was 24% for G1 and 20% for G2 (p>0.1).; - 52% of women in G1 and 67% in G2 still had menorrhagia after 2 months of treatment.
Andersch et al., 1988^71^ Sweden Poor | G1: Flurbiprofen, 100 mg twice daily for 2 cycles followed by TXA for 2 cycles (15)^a^ G2: TXA, 1.5 g 3 times daily on days 1 to 3 and 1 g twice daily on days 4 to 5 for 2 cycles followed by flurbiprofen for 2 cycles (15)^a^ | - Both treatments significantly reduced MBL (p<0.01).; - Reduction in MBL was 53% with TXA compared with 24% for flurbiprofen (p<0.01).; - Mean MBL reduced to 155 ± 33 ml with TXA and 223 ± 44 ml for flurbiprofen (baseline MBL was 295 ± 52 ml).; - Hemoglobin did not change with either treatment.
Tsang et al., 1987^73^ Canada Poor | G1: Mefenamic acid, 500 mg at onset followed by 250 mg every 6 hrs. for 3 to 5 days for 2 cycles followed by placebo (14)^a^ G2: Placebo for 2 cycles followed by mefenamic acid for 2 cycles (14)^a^ | - 8/10 women experienced reduction in MBL while taking mefenamic acid compared with placebo (p<0.05).
Cameron et al., 1987^74^ United Kingdom Poor | G1: Mefenamic acid, 500 mg 3 times daily (8) G2: Norethisterone, 5 mg twice daily (8) G3: Progesterone-impregnated intrauterine coil releasing 65 mcg daily (8) | - Median MBL reduced in G1 from 68 to 47 ml (p=0.05) and in G3 from 71 to 45 ml (p<0.05).; - Median MBL was unchanged in G2 (94 to 110 ml).

COC = combined oral contraceptive; LNG-IUS = levonorgestrel-releasing intrauterine system; MBL = menstrual blood loss; NS = not significant; PBLAC = pictorial blood assessment chart; TXA = tranexamic acid

a Crossover study.

Studies used different inclusion criteria for defining menorrhagia. Six trials used the objective alkaline hematin method with MBL more than 80 ml as criteria for inclusion.63,66,67,70,71,75 Two trials used the alkaline hematin method with MBL more than 50 to 60 ml,72,74 one study used a combination of subjective and objective assessments of MBL more than 80 ml,73 and four trials used either subjective criteria or did not define heavy menstrual bleeding for inclusion into the trial.68,69,76,77 Some studies required women to have regular cycles.63,67,68,72,73,77 Most studies excluded populations who had underlying disease or intrauterine device (IUD) use. One study76 included patients with IUD (n=6), fibroids (n=2), Von Willebrand disease (n=1) and reported changes in MBL separately for women with ovulatory menorrhagia from those with underlying disease. Another study also included patients with IUDs (n=7) in the eligible patient population.72 Patients ranged in age from 14 to 51 years of age.

The target intervention differed among the 13 studies. For each NSAID, dose and duration did not vary greatly. The most commonly studied NSAID, mefenamic acid, was used in 11 trials.63,66-70,73-77 The usual dose of mefenamic acid was 500 mg 3 times a day starting at the onset of menses for duration of 5 days or until cessation of menses. One study initiated mefenamic acid 5 days prior to onset of menses through cessation.67 Another trial used a slightly different regimen with 500 mg at onset of menses followed by 250 mg every 6 hours for 3 to 5 days.73 One study included mefenamic acid at 250 mg 3 times a day from onset menses for 5 days in conjunction with TXA 500 mg 3 times a day for the same 5-day period.77 One trial studied meclofenamate at a dose of 100 mg 3 times a day from onset of menses for duration of 6 days or until cessation of menses.72 Naproxen was studied in two trials with initial loading doses of 500 to 550 mg then 250 to 275 mg every 6 hours for 5 days or until 24 hours after cessation of heavy bleeding.68,75 Flurbiprofen was studied in one trial at a dose of 100 mg twice a day from onset of menses for duration of 5 days.71

The comparator differed among the 13 studies. Mefenamic acid was compared with placebo in four studies, two RCTs67,69 and two crossover trials.73,76 One crossover trial compared meclofenamate to placebo.72 Two crossover trials compared mefenamic acid to naproxen68,75 for two cycles. One of these crossover trials also used low-dose COC with 30 mcg ethinyl estradiol and 150 mcg levonorgestrel given daily for 21 days for two cycles.68 Two RCTs used norethisterone 5 mg twice daily from day 19 to 26 of the cycle70 or days 15 to 25 of the cycle74 for two cycles. Two RCTs used progesterone-releasing intrauterine systems, including the LNG-IUS that releases 20 mcg of levonorgestrel per day for six cycles63 and an older progesterone-impregnated intrauterine coil that releases 65 mcg of progesterone daily for two cycles.74 One RCT compared mefenamic acid (500 mg every 8 hours) with TXA (1 gram every 6 hours) and ethamsylate (500 mg every 6 hours) for the first 5 days of menses for three cycles.66 One crossover trial compared flurbiprofen (100 mg twice a day for 5 days) with 1.5 grams of TXA (3 times a day for the first 3 days of menses and 1 gram on days 4 to 5) for two cycles.71 One RCT compared a combination of mefenamic acid (250 mg per day) and TXA (500 mg 3 times a day) to TXA alone from day 1 to 5 of menses for three cycles.77

Duration of treatment ranged from one67 to six63 menstrual cycles, with the majority consisting of two68,70-76 to three66,69,77 cycles.

The primary outcome for most studies (11/13) was MBL measured with the alkaline hematin method.63,66-68,70-76 Seven studies reported mean MBL66-68,71-73,76 and four studies reported median MBL.63,70,74,75 One small, placebo-controlled crossover trial73 measured MBL but only reported the proportion of women who experienced reductions in MBL during the treatment cycles. One trial used the pictorial blood loss assessment chart score77 as the primary outcome measure for blood loss and a second trial of NSAIDS used the pictorial blood loss assessment chart as a secondary outcome measure.63 One trial reported the percentage of patients relieved of menorrhagia,69 however the method of measurement was not provided. Other outcomes studied included duration of bleeding,66,69,70,72,75,76 number of pads/tampons used,66,69,72,75 and total menstrual fluid loss.63 One trial examined patient satisfaction.66 No studies examined quality of life, sexual function, fertility, or time to conception as an outcome.

#### Description of Results

##### Outcome Measures

All studies of NSAIDs examined bleeding outcomes. Eleven studies used the alkaline hematin method for an objective measure of MBL. Two trials used the pictorial blood loss assessment chart to assess blood loss.63,77 One study69 reported relief of menorrhagia for which methods were not provided.

Although we aimed to collect data on measures of quality of life, sexual function, fertility and time to conception, none of the 13 clinical trials reported on these outcomes. One study reported patient satisfaction based on participants' wish to continue treatment at the end of the study.66

##### MBL

###### Reduction Expressed as a Percent

Four trials of fair to good quality reported statistically significant reductions in MBL compared with baseline, ranging from 40 to 49 percent among those who received one to two treatment cycles of NSAIDs, including mefenamic acid, naproxen, or meclofenamate (Table 14).67,72,75,76

Table 14 Percent change in blood loss from baseline in studies of NSAIDs

Author, Year | NSAID | Comparator | NSAID Group | Comparator Group | NSAID vs. Comparator Group
Vargyas et al., 1987^72^ | Meclofenamate | Placebo | −48.9 | −9.2 | p<0.0001
Van Elijkeren et al., 1992^67^ | Mefenamic acid | Placebo | −40.0 | NR | NR
Hall et al., 1987^75^ | Mefenamic acid | Naproxen | −47.0 | −46.0 | NS
Fraser et al., 1981, 1984^76,93^ | Mefenamic acid | Placebo | NR | NR | p<0.001
Reid and Virtanen-Kari,2005^63^ | Mefenamic acid | LNG-IUS | −23.0 | −95.0 | p<0.001
Bonnar and Sheppard,1996^66^ | Mefenamic acid | TXA | −20.0 | −54.0 | p<0.05
Bonnar and Sheppard,1996^66^ | Mefenamic acid | Ethamsylate | −20.0 | 0 | p<0.001
Fraser and McCarron, 1991^68^ | Mefenamic acid | Naproxen | −20.0 | −12.0 | NS
Fraser and McCarron, 1991^68^ | Mefenamic acid | COC^a^ | −38.0 | −43.0 | NS
Cameron et al., 1990^70^ | Mefenamic acid | Norethisterone | −24.0 | −20.0 | NS
Andersch et al., 1988^71^ | Flurbiprofen | TXA | −24.0 | −53.0 | p<0.01

COC = combined oral contraceptive; LNG-IUS = levonorgestrel-releasing intrauterine system; TXA = tranexamic acid; NS = nonsignificant

a 30 mcg ethinyl estradiol and 150 mcg levonorgestrel.

A good quality crossover trial conducted in the United States,72 randomized 32 women with MBL more than 60 ml to meclofenamate or placebo for 2 treatment cycles. Seven (21%) participants were using an IUD. Significantly (p<0.0001) greater reductions in MBL were reported among those receiving meclofenamate (48.9 ± 3.7%) compared with those receiving placebo (9.2 ± 5.3%). During treatment, the change in MBL associated with meclofenamate ranged from −42 ± 3 percent in cycle 1 to −56 ± 8 percent in cycle 3.

A small, fair quality, RCT conducted in the Netherlands,67 randomized women scheduled for a hysterectomy due to subjective menorrhagia to either mefenamic acid 500 mg (n=6) or placebo (n=5) 3 times daily starting 5 days before expected menses to cessation of bleeding for 1 treatment cycle. Eligible participants had regular cycles, no IUD, and MBL more than 80 ml. Those receiving mefenamic acid had greater reductions (40%, p=0.01) in mean MBL from baseline compared with placebo where a nonsignificant increase (25%) in MBL was reported,

A randomized, double-blind crossover fair quality trial conducted in the United Kingdom75 compared naproxen (550 mg at onset of menses then 275 mg every 6 to 8 hours for 5 days) to mefenamic acid among 38 women with MBL more than 80 ml for 2 treatment cycles. Patients with pelvic inflammation, fibroids, or other local disease were excluded. There were no significant differences in mean MBL reduction between the two groups receiving mefenamic acid (46% and 47%) and the two groups receiving naproxen (44% and 48%). Reductions in MBL compared with baseline were statistically significant (p<0.001) in both the groups receiving mefenamic acid and naproxen.

One crossover RCT of fair quality conducted in Australia and published in two papers76,93 randomized 85 women with menorrhagia to mefenamic acid or placebo for two cycles. Overall there was a 28-percent reduction in mean MBL among those who received mefenamic acid compared with those who received placebo (p<0.001). There was a 30-percent reduction (p<0.001) in blood loss among those with MBL more than 80 ml at baseline (n=30) but a 28-percent increase in blood loss among those with MBL more than 35 ml at baseline (n=14).

Six poor quality trials also reported significantly reduced MBL compared with baseline levels (Table 14). One poor quality RCT conducted in the United Kingdom63 compared 51 participants randomized to either mefenamic acid or to LNG-IUS. Both LNG-IUS and mefenamic acid significantly (p<0.005) reduced MBL compared with baseline; however, the study reported a greater reduction in median MBL among those treated with LNG-IUS (95%) compared with those receiving mefenamic acid (23%) after six cycles of treatment.

One RCT66 conducted in Ireland randomized women to either TXA (n=27), mefenamic acid (n=25), or ethamsylate (n=29) for three cycles. The study reported a 54-percent reduction in mean MBL from baseline for those receiving TXA (p<0.001), a 20-percent reduction for those receiving mefenamic acid (p<0.001), and no reduction for those receiving ethamsylate.

A small crossover trial71 conducted in Sweden compared TXA to flurbiprofen for two treatment cycles. A greater reduction in mean MBL from baseline was reported among those receiving TXA (53%) compared with those receiving flurbiprofen (24%).

One RCT conducted in the United Kingdom70 examined the efficacy of mefenamic acid compared with norethisterone among 32 participants with MBL more than 80 ml for 2 cycles. Median percent change in blood loss volume was not significantly different between mefenamic acid (−24%; range, 5 to −83%) and norethisterone (−20%; range, 2 to −53%). Median MBL with treatment was 81 ml (range, 22 to 193 ml) for those receiving mefenamic acid and 92 ml (range, 43 to 189 ml) for those receiving norethisterone. One patient treated with mefenamic acid had an increase in blood loss.

One crossover trial68 conducted in Australia examined the efficacy of mefenamic acid compared with low-dose COC (30 mcg ethinyl estradiol and 150 mcg levonorgestrel given daily for 21 days) in one group and mefenamic acid compared with naproxen in another group, each for two cycles among women with a clinical history of menorrhagia. There was no significant difference in reduction of mean MBL between those receiving mefenamic acid (38%) and those receiving low-dose COC (43%) or between those receiving mefenamic acid (20%) and those receiving naproxen (12%).

###### Reduction Expressed as a Volume

In four trials of fair to good quality,67,72,75,76 treatment with meclofenamate, mefenamic acid or naproxen reduced MBL compared with baseline (Table 15). Mean or median MBL after treatment ranged from 65 to 77 ml. Mefenamic acid and naproxen were comparable in effectiveness.75

Table 15 Change in blood loss volume from baseline in studies of NSAIDs

Author, Year | NSAID | Comparator | NSAID Group | Comparator Group | NSAID vs. Comparator Group
Vargyas et al., 1987^72^ | Meclofenamate | Placebo | -72.6 | -6.0 | p<0.0001
Van Elijkeren et al., 1992^67^ | Mefenamic acid | Placebo | -43.0 | +38.0 | NR
Hall et al., 1987^75^ | Mefenamic acid | Naproxen | -57.5 | -57.0 | p=NS
Fraser et al., 1981, 1984^76^ | Mefenamic acid | Placebo | NR | NR | p<0.001
Reid and Virtanen-Kari,2005^63^ | Mefenamic acid | LNG-IUS | -21.0 | -117.0 | p<0.001
Bonnar and Sheppard,1996^66^ | Mefenamic acid | TXA | -43.0 | -89.0 | p<0.05
Bonnar and Sheppard,1996^66^ | Mefenamic acid | Ethamsylate | -43.0 | +8.0 | p<0.05
Fraser and McCarron, 1991^68^ | Mefenamic acid | Naproxen | -26.0 | -15.5 | p=NS
Fraser and McCarron, 1991^68^ | Mefenamic acid | COC^a^ | -38.1 | -43.2 | p=NS
Cameron et al., 1990^70^ | Mefenamic acid | Norethisterone | -42.0 | -17.0 | p=NS
Andersch et al., 1988^71^ | Flurbiprofen | TXA | -72.0 | -140.0 | p<0.01
Cameron et al., 1987^74^ | Mefenamic acid | Norethisterone | -38.0 | -21.0 | NR
Cameron et al., 1987^74^ | Mefenamic acid | Progesterone-impregnated intrauterine coil | -38.0 | -19.0 | NR

COC = combined oral contraceptive; LNG-IUS = levonorgestrel-releasing intrauterine system; NSAID = nonsteroidal anti-inflammatory drug; NR = not reported; NS = nonsignificant

a Ethinyl estradiol (30 mcg)/levonorgestrel (150 mcg).

A good quality crossover trial conducted in the United States randomized 32 women to meclofenamate or placebo for 2 cycles. There was a significantly greater reduction in mean MBL from baseline with meclofenamate (72.6 ml) compared with placebo (6.0 ml).72

A small fair quality RCT conducted in the Netherlands randomized women scheduled for a hysterectomy due to subjective menorrhagia to mefenamic acid (n=6) or placebo (n=5). There was a significant reduction in mean MBL from baseline in the treatment group (43 ml, p=0.01) compared with a 38-ml increase in MBL in the placebo group.67

A fair quality crossover trial conducted in the United Kingdom compared naproxen to mefenamic acid among 38 women with MBL more than 80 ml for 2 treatment cycles. Median reductions in blood volume from baseline for mefenamic acid ranged from 54 ml to 61 ml (p<0.001) and the reduction for naproxen ranged from 52 to 62 ml (p<0.001) over 2 treatment cycles. There were no significant differences in reductions in MBL between mefenamic acid and naproxen.75

A fair quality crossover RCT conducted in Australia reported greater reductions in mean MBL among those receiving mefenamic acid (18.8 ml) for 2 treatment cycles compared with those receiving placebo. Among the women with MBL more than 80 ml at baseline (n=30), there was a significant (p<0.001) reduction in mean MBL (33.6 ml) among those receiving mefenamic acid compared with those receiving placebo.76

Six poor quality studies reported similar findings; NSAIDS significantly reduced MBL compared with baseline (Table 15). In a poor quality RCT conducted in the United Kingdom with 51 women,63 MBL was reduced by 21 ml in those receiving mefenamic acid compared with baseline; however, the women in the LNG-IUS group reported significantly greater reductions in blood loss volume (117 ml, p<0.001) from baseline.

In an RCT conducted in Ireland,66 81 women were randomized to either TXA (n=27), mefenamic acid (n=25), or ethamsylate (n=29) for three cycles. Compared with baseline, those receiving TXA had an 89 ml reduction in MBL, those receiving mefenamic acid reported a 43 ml reduction, and those receiving ethamsylate reported an increase in MBL of 8 ml. Those receiving TXA had a 46 ml greater reduction in MBL compared with those receiving mefenamic acid (p<0.05) and those receiving mefenamic acid had a 51 ml greater reduction in MBL compared with those receiving ethamsylate; however, mean MBL (148 ml; range, 138 to 168 ml) after 3 cycles of treatment with mefenamic acid remained more than 80 ml.

In a crossover trial conducted in Australia, 68 there were no differences in absolute reductions in MBL volume between mefenamic acid and low-dose COC (30 mcg ethinyl estradiol and 150 mcg levonorgestrel given daily for 21 days) or between mefenamic acid compared with naproxen. Reductions in blood loss volume compared with baseline were reported for both those receiving mefenamic acid (38.1 ml, p=0.002) and those receiving COC (43.2 ml, p<0.001). In the other group, there were nonsignificant reductions in MBL from baseline for mefenamic acid (26 ml) and naproxen (15.5 ml).

In one RCT conducted in the United Kingdom,70 median MBL was reduced after 2 cycles of mefenamic acid from 123 ml (range, 86 to 237 ml) to 81 ml (range, 22 to 193 ml), a reduction of 42 ml (p<0.001) and was significantly reduced with norethisterone from 109 ml (range, 81 to 236 ml) to 92 ml (range, 43 to 189 ml), a reduction of 17 ml (p<0.002), but there was no significant difference in reductions between mefenamic acid and norethisterone.

A small crossover trial71 conducted in Sweden that compared TXA with flurbiprofen for two treatment cycles, reported significantly (p<0.01) greater reductions in mean MBL from baseline for TXA (140 ml, p<0.01) compared with the change in MBL from baseline for flurbiprofen (72 ml, p<0.01).

In another small RCT conducted in the United Kingdom,74 median MBL was significantly reduced after two cycles of treatment with mefenamic acid (n=6), 38 ml reduction (median 47 ml; range, 39 to 210 ml) from baseline (85 ml; range, 68 to 169 ml), p=0.05, and was significantly reduced with a progesterone-impregnated intrauterine coil (n=7), 19 ml reduction (median 45 ml; range, 31 to 77 ml) from baseline (median 64 ml; range, 56 to 164 ml, p<0.05). However, there was no significant reduction in median MBL after two cycles of norethisterone (21 ml; median 110 ml; range, 18 to 187 ml).

##### Pictorial Blood Loss Assessment Chart Score

One poor quality RCT conducted in India77 randomized 110 women with menorrhagia to a combination of TXA and mefenamic acid or TXA alone for three treatment cycles. The pictorial blood loss assessment chart score was lowered by 146 points (59%, p<0.01) from baseline in those receiving mefenamic acid plus TXA and by 125 points (50%, p=NS) from baseline in those receiving TXA alone. In a poor quality RCT conducted in the United Kingdom,63 women receiving mefenamic acid reported a 74-point reduction (p<0.001) in the median pictorial blood loss assessment chart score from baseline.

##### Relief of Menorrhagia

Improvement in the subjective relief of menorrhagia with NSAIDs was reported in two trials.66,69 One RCT conducted in India69 randomized 80 women with subjectively defined, cyclic, heavy bleeding to either mefenamic acid or placebo for three cycles. Relief of menorrhagia was significantly greater among those receiving mefenamic acid (86%) compared with those receiving placebo (20%). Another trial66 reported that most women (57%) who received mefenamic acid thought their blood loss was less after three treatment cycles compared with baseline. A small, placebo-controlled crossover trial conducted in Canada73 randomized women to 2 cycles each of mefenamic acid and placebo and reported that 8 of the 10 women who competed the study experienced reductions in MBL during the mefenamic acid cycles compared with their placebo cycles (p<0.05).

##### Duration of Bleeding and Total Menstrual Fluid Loss

Duration of bleeding (in days) was reported in six trials of NSAIDs.66,69,70,72,75,76 In two trials, one fair and one good quality, the duration of menstrual blood flow was shorter among those receiving either meclofenamate72 or mefenamic acid76 compared with placebo. Another fair quality study reported that both mefenamic acid and naproxen reduced the mean number of bleeding days.75

Two poor quality RCTs reported a significantly shorter duration of bleeding during mefenamic treatment cycles compared with pretreatment cycles,69,70 but there was no change with norethisterone.70 In one poor quality, three-arm trial66 of mefenamic acid, TXA, and ethamsylate, there was no difference in duration of menstrual bleeding between treatment arms. In one poor quality study,63 total menstrual fluid loss was significantly less at cycle 3 and cycle 6 compared with baseline among women receiving mefenamic acid.

##### Hemoglobin

In two trials,71,72 hemoglobin concentrations did not increase during treatment with NSAIDs. In a good quality, crossover trial conducted in the United States, the median hemoglobin, hematocrit, and ferritin levels were unchanged compared with baseline.72 In a crossover trial conducted in Sweden,71 hemoglobin concentration during control cycles was no different from hemoglobin concentration during treatment. In the RCT in India,77 mean hemoglobin increased significantly in the group receiving combined mefenamic acid and TXA (12.3 g/dl) and in the group receiving TXA alone (12.0 g/dl).

##### Head-to-Head Comparisons

###### Mefenamic Acid Versus Naproxen

Two crossover trials compared mefenamic acid to naproxen.68,75 There were no differences in reduction of MBL between mefenamic acid and naproxen.

One fair quality crossover trial75 conducted in the United Kingdom compared naproxen to mefenamic acid among 38 women with MBL more than 80 ml for 2 treatment cycles. Primary outcomes were mean MBL using the alkaline hematin method. Both mefenamic acid and naproxen reduced median MBL by 46 to 47 percent and 44 to 48 percent, respectively, compared with baseline. The median reductions in MBL volume from baseline for mefenamic acid ranged from 54 ml to 61 ml (p<0.001); the reduction for naproxen ranged from 52 to 62 ml (p<0.001) over two treatment cycles. There were no differences in reductions in MBL between mefenamic acid and naproxen.

One poor quality crossover trial68 conducted in Australia randomized 30 women with a clinical history of menorrhagia to either mefenamic acid or naproxen for 2 cycles. The same dose of mefenamic acid was compared with oral contraceptives in a second group (see section below). The primary outcome was MBL measured by the alkaline hematin method. Mefenamic acid reduced mean MBL by 20 percent compared with baseline (p=NS). Naproxen reduced mean MBL by 12 percent compared with baseline (p=NS) with no significant differences in reductions between mefenamic acid and naproxen. Despite these reductions, the majority of women receiving NSAIDs still had objective menorrhagia after treatment. There was considerable variability in response to both NSAIDs, with some women experiencing increases in MBL during treatment with NSAIDs.

###### Mefenamic Acid Versus Progesterone-Releasing Intrauterine Systems

Two poor quality RCTs conducted in the United Kingdom examined the efficacy of mefenamic acid compared with progesterone-releasing intrauterine systems. One studied the continuous LNG-IUS,63 and the other studied an older progesterone-impregnated intrauterine coil that releases 65 mcg of progesterone daily.74 Both trials used objective measures of MBL (alkaline hematin method) for inclusion criteria, but with slightly different volumes (more than 80 ml63 and more than 50 ml74) to assess MBL outcomes.

One RCT with 51 participants63 reported a statistically significant greater reduction in median MBL from baseline in the women with LNG-IUS (117 ml) compared with the women receiving mefenamic acid (21 ml) after six cycles of treatment. Significantly greater (p<0.001) reductions in the median pictorial blood loss assessment chart score and total menstrual fluid loss were also reported with LNG-IUS compared with mefenamic acid. Despite significant reductions with mefenamic acid, most patients still had objective MBL more than 80 ml.

One small RCT74 reported reductions in median MBL after two cycles of treatment with both mefenamic acid (n=6), with a reduction of 21 ml (median 47 ml; range, 39 to 210 ml) from baseline (85 ml; range, 68 to 169 ml; p=0.05), and with the progesterone-impregnated intrauterine coil (n=7) with a reduction of 19 ml (median 45 ml; range, 31 to 77 ml) from baseline (median 64 ml; range, 56 to 164 ml; p<0.05). No statistics for head-to-head comparisons were reported.

##### NSAIDs Versus TXA

Two poor quality trials compared NSAIDs with TXA.66,71 Both trials reported that women receiving TXA had significantly greater reductions in mean MBL compared with either mefenamic acid or flurbiprofen over three cycles.

One RCT66 conducted in Ireland, randomized 81 women with MBL more than 80 ml to either TXA (n=27), mefenamic acid (n=25), or ethamsylate (n=29) for three cycles. There was a significant reduction in mean MBL from baseline over three treatment cycles for two of three treatment arms: 54 percent (p<0.001) for TXA and 20 percent (p<0.001) for mefenamic acid. The absolute change in MBL compared with baseline was −89 ml with TXA, −43 ml with mefenamic acid, and +8 ml with ethamsylate.

One small randomized crossover trial71 conducted in Sweden compared TXA to flurbiprofen in 15 women with MBL more than 80 ml. The trial reported a statistically significant reduction in mean MBL (53%) in the group receiving TXA (53%) compared with the group receiving flurbiprofen (24%). Absolute reductions in blood loss volume from baseline were greater for TXA (140 ml) compared with flurbiprofen (72 ml).

##### TXA Plus Mefenamic Acid Versus TXA Alone

One poor quality RCT conducted in India77 randomized 110 women with menorrhagia (not objectively defined) to a combination of TXA and mefenamic acid or to TXA alone. After three treatment cycles, the pictorial blood loss assessment chart score was reduced in those receiving mefenamic acid plus TXA (59%, p<0.01) and in those receiving TXA alone (50%, p=NS). No statistics for head-to-head comparisons were reported.

##### Mefenamic Acid Versus Norethisterone

Two poor quality RCTs conducted in the United Kingdom examined the efficacy of mefenamic acid compared with norethisterone. 70,74 Both trials examined the same dose and duration of mefenamic acid (500 mg 3 times daily on cycle days 1 to 5) and the same dose of norethisterone (5 mg twice per day) but given during slightly different cycle days, (days 19 to 26^70^ vs. days 15 to 25^74^). Both trials used the alkaline method for MBL measurement for inclusion (50 to 80 ml) and outcome criteria.

One RCT70 reported no difference in reductions of median MBL among those receiving 2 treatment cycles of mefenamic acid (n=17) compared with those receiving norethisterone (n=15). With either treatment, the majority of women still had MBL more than 80 ml. In the other small RCT,74 no statistics for head-to-head comparisons were reported. Compared with baseline, median MBL was reduced after treatment with mefenamic acid (n=6) by 38 ml and by 21 ml (p=NS) among those receiving norethisterone (n=6). Median MBL with treatment was 47 ml (range, 39 to 210 ml) with mefenamic acid and 110 ml (range, 24 to 222 ml) with norethisterone.

##### Mefenamic Acid Versus Low-Dose COC

One poor quality crossover trial68 conducted in Australia examined the efficacy of mefenamic acid compared with low-dose COC with 30 mcg ethinyl estradiol and 150 mcg levonorgestrel given daily for 21 days among 30 women with a clinical history of menorrhagia. There were no differences between mefenamic acid and COC in reductions in mean MBL (38% vs. 43%) or absolute reductions in MBL volume (38 ml vs. 43 ml).

### Tranexamic Acid

#### Key Points

- Women taking TXA at a dose of 1.95 to 4.5 grams per day for 4 to 5 days from the onset of bleeding experienced a clinically significant reduction in MBL, ranging from 26 percent to 54 percent in studies lasting up to 1 year. However, there are no long-term followup studies.
- In comparison to progestogens, combined hormonal pills, and NSAIDs, TXA appeared to provide greater reduction in MBL. No head-to-head comparisons of TXA versus LNG-IUS were assessed.
- The number of reports of side-effects and adverse effects was generally not significantly different between TXA and the comparator.
- Although no thromboembolic events were reported in any of the included TXA studies, there are concerns about the possible increased risk of thromboembolic events in particular women. The Food and Drug Administration (FDA) has issued precautions and contra-indications.

#### Detailed Synthesis

TXA is a competitive inhibitor of plasminogen activation, thereby acting as an antifibrinolytic agent. TXA does not appear to affect platelet numbers or aggregation but acts to reduce the breakdown of fibrin in a preformed clot. Because menstrual bleeding involves liquefaction of clotted blood from the spiral endometrial arterioles, a reduction in this process is the putative mechanism of reduced menstrual bleeding.

Seven RCTs of TXA were identified (Table 16).66,71,77-81 One study compared TXA alone to TXA plus mefenamic acid, and is discussed in the NSAIDs section above.77 For the six other studies of TXA, study population ranged from 15^71^ to 304.^81^ The total number of women randomized to TXA was 475. The total number of women assigned to TXA for whom study endpoint outcome measures were collected, including intention to treat missing data protocols, was 460.

Table 16 Primary outcomes of TXA for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Outcomes
Lukes et al., 2010^78^ United States Good | G1: TXA 1.3 g 3 times daily up to 5 days per cycle (123) G2: Placebo (73) | - Mean reduction in MBL measured by the alkaline hematin method after 6 cycles was greater in G1 compared with G2 (p<0.001).; - Proportion of women with at least 50 ml reduction in MBL was 56% in G1 and 19% in G2 (p<0.0001).; - Women in G1 reported improvements in quality of life (measured by the Menorrhagia Impact Score) compared with G2 (p<0.01).
Freeman et al., 2011^81^ Fair | G1: TXA 3.9 g per day for up to 5 days of menstrual bleeding (118) G2: TXA 1.95 g per day for up to 5 days of menstrual bleeding (117) G3: Placebo (69) | - Mean MBL was significantly reduced during treatment compared with baseline for G1 (26%) and for G2 (39%).; - The reduction in mean MBL was significantly greater in the group receiving the higher TXA dose (G2).
Preston et al., 1995^80^ United Kingdom Fair | G1: TXA 1 g 4 times daily for 4 days (25) G2: Norethisterone 5 mg twice a day on days 19 to 26 (21) | - Mean reduction in MBL from baseline was 45% for G1 (p<0.0001); mean MBL increased in G2 (p=NS).; - Fourteen (56%) women in G1 and 2 (9.5%) women in G2 achieved MBL<80 ml.
Kriplani et al., 2006^79^ India Poor | G1: TXA 500 mg 4 times daily for 5 days (50) G2: MPA 10 mg twice daily days 5 to 25 (50) | - Both groups had significant (p<0.005) reductions in PBLAC scores after 3 months and mean reduction in blood loss was 60.3% in G1 and 57.7% in G2.; - Hemoglobin levels rose in both groups (p<0.05 for both).; - Three women in G1 (6.1%) and 13 (28.9%) in G2 did not respond to treatment (p=0.003).
Bonnar and Shepard, 1996^66^ Ireland Poor | G1: TXA 1 g every 6 hrs. (27) G2: Ethamsylate 500 mg every 6 hrs. (29) G3: Mefenamic acid 500 mg every 8 hrs. (25) | - Women in G1 had blood loss reduction of 54% compared with 20% for women in G3.; - No reduction in blood loss for G2.
Andersch et al., 1988^71^ Sweden Poor | G1: TXA for 2 cycles followed by flurbiprofen for 2 cycles (15)^a^ G2: Flurbiprofen for 2 cycles followed by TXA for 2 cycles (15)^a^ | - MBL was significantly reduced during treatment with flurbiprofen and TXA.; - MBL was significantly (p<0.01) lower during treatment with TXA compared with flurbiprofen.

MBL = menstrual blood loss; PBLAC = pictorial blood assessment chart

a Crossover study.

For five of the trials, the bleeding criterion for study entry was a mean MBL (assessed using the alkaline hematin method) of at least 80 ml for two or three cycles prior to randomization.66,71,78,80,81 A sixth trial used the pictorial blood loss assessment chart score greater than 100 to enroll participants.79 The mean MBL at baseline was similar for four of the trials (range, 153 to 186 ml).66,78,80,81 The mean MBL at baseline was 295 ml for one trial.71

The intervention dosage differed among the six trials. The TXA administration protocols for each menstrual cycle were: 1.95 grams per day or 3.9 grams per day for up to 5 days,81 2 grams per day for 5 days,79 3.9 grams per day for up to 5 days,78 4 grams per day for 4 days,80 4 grams per day for 5 days,66 4.5 grams per day for 3 days and then 2 grams per day for 2 days.71

Two of the studies were placebo-controlled.78,81The comparator differed across the other four trials and included: oral MPA for 20 days,79 oral norethisterone for 7 days,80 mefenamic acid for 5 days,66 ethamsylate for 5 days,66 and flurbiprofen for 5 days.71

The primary outcome of the trials was change in blood loss (absolute volume or percent) or change in pictorial blood loss assessment chart score. The alkaline hematin method was used to assess MBL in five trials.66,71,78,80,81 The absolute change in mean blood loss from baseline and percent change were reported in five studies.66,71,78,80,81 Three of these four reported mean MBL,71,78,80 and three reported median MBL.66,78,80 One trial used the pictorial blood loss assessment chart, which is a validated chart that helps participants more uniformly report bleeding as represented by the degree of saturation of sanitary pads and tampons, for the outcome measure.79

The timing of the summative outcome measure reporting varied among the trials. Two trials reported after two menstrual cycles.71,80 Two trials reported after three menstrual cycles.66,81 Two trials reported after six menstrual cycles.78,79

The setting varied: two trials were conducted in the United States,78,81 three in Europe,66,71,80 and one in India.79 Overall one study was assessed as good quality,78 two were fair quality,80,81 and three were poor quality.66,71,79 Details of quality scoring for individual publications are included in Appendix I.

#### Description of Results

##### Outcome Measures

The alkaline hematin method for MBL was used as an outcome measure in 5 of the TXA trials.66,71,78,80,81 One poor quality trial used the pictorial blood loss assessment chart to assess blood loss, with menorrhagia defined by a pictorial blood loss assessment chart score of 100 or greater.79 Other outcome measures included hemoglobin level, treatment success, and quality of life.

##### MBL

###### Reduction Expressed as a Percent

In five studies (one good quality, two fair quality, and two poor quality), TXA was associated with significant reductions in MBL ranging from 26 to 54 percent (Table 17). A good quality placebo-controlled trial reported a statistically significant (p<0.001) reduction in mean MBL among women in the modified intent-to-treat population receiving TXA (40%) compared with those receiving placebo (8%) for six menstrual cycles. The attributable reduction for TXA was 32 percent (p<0.001).78 The other placebo-controlled trial of fair quality reported significant reductions in mean MBL for women receiving 3.9 or 1.95 grams per day of TXA (39% and 26%, respectively) compared with a reduction in MBL of 2 percent for women taking placebo (p<0.001).81

Table 17 Percent change in blood loss from baseline in studies of TXA

Author, Year | Comparator | TXA Group | Comparator Group | TXA vs. Comparator Group
Lukes et al., 2010^78^ | Placebo | -40.4 | -8.2 | p<0.001
Freeman et al., 2011^81^ | Placebo | -38.6 (high dose) -26.1 (low dose) | -1.9 | p<0.0001
Preston et al., 1995^80^ | Norethisterone | -45.0 | +20.0 | p<0.0001
Bonnar and Shepard, 1996^66^ | Mefenamic acid | -54.0 | -20.0 | p<0.05
Bonnar and Shepard, 1996^66^ | Ethamsylate | -54.0 | Increased | p<0.0001
Andersch et al., 1988^71^ | Flurbiprofen | -53.0 | -24.0 | p<0.01

MPA = medroxyprogesterone; NS = nonsignificant; NR = not reported

The trial that compared TXA with norethisterone reported a statistically significant reduction in mean MBL among women receiving TXA for two treatment cycles compared with those receiving norethisterone: 45-percent reduction (95% CI, 23% increase to 93% reduction; p<0.0001 vs. baseline) compared with a 20-percent increase (95% CI, 114% increase to 62% reduction; p=0.26 vs. baseline).80

A trial that compared TXA with ethamsylate and with mefenamic acid reported that over three treatment cycles the mean reduction in MBL from baseline for the group receiving TXA was 54 percent (p<0.001). For the mefenamic acid group the mean reduction in MBL from baseline was 20 percent (p<0.001). There was no change in MBL for the ethamsylate group.66

A small, poor quality, crossover trial (n=15) that compared TXA with flurbiprofen reported that over two treatment cycles the mean reduction in MBL from baseline for TXA was 53 percent (p<0.01) compared with 24 percent for flurbiprofen (p<0.01).71

###### Reduction Expressed as a Volume

In five studies (one good quality, two fair quality, and two poor quality) TXA was associated with significant reductions in MBL ranging from 47 to 140 ml (Table 18). Both placebo-controlled trials reported a statistically significant reduction in mean MBL for women treated with TXA.78,81 Among women in the modified intent-to-treat population receiving TXA for six menstrual cycles, one study reported a reduction in MBL of 69.6 ml compared with a reduction of 12.6 ml in the placebo group; the attributable reduction for TXA was 57 ml (p<0.001). The calculated least-squares mean reduction in MBL in the modified intent-to-treat population receiving TXA (66.3 ml) was greater compared with those receiving placebo (17.8 ml); the attributable reduction for TXA was 48.5 ml (p<0.001).78 The effect size for TXA (standardized observed effect) was 0.67 based upon the modified intention to treat analysis and the standard deviation. The effect size was 0.49 based upon the least squares mean change analysis and the standard deviation.78 The effect size for TXA compared with placebo is large.

Table 18 Change in blood loss volume from baseline in studies of TXA

Author, Year | Comparator | TXA Group | Comparator Group | TXA vs. Comparator Group
Lukes et al., 2010^78^ | Placebo | −69.6 ml | −12.6 ml | p<0.001
Freeman et al., 2011^81^ | Placebo | -65.3 ml (high-dose) -46.5 ml (low-dose) | -3.0 ml | p<0.0001
Preston et al., 1995^80^ | Norethisterone | −79.0 ml | +34.0 ml | p<0.0001
Bonnar and Shepard, 1996^66^ | Mefenamic acid | −89.0 ml | −43.0 ml | p<0.05
Bonnar and Shepard, 1996^66^ | Ethamsylate | −89.0 ml | +8.0 ml | p<0.001
Andersch et al., 1988^71^ | Flurbiprofen | −140.0 ml | −72.0 ml | p<0.01

NR = not reported

In the larger fair quality study that compared high-dose (3.9 g/day) and low-dose (1.95 g/day) TXA to placebo, the mean reduction from baseline for the intent-to-treat population was 65.3 ml and 46.5 ml, respectively, while the placebo group had a small insignificant decline of 3.0 ml. The low-dose group did not meet the authors predetermined threshold of at least 50 ml per cycle reduction in MBL from baseline, but both groups treated with TXA did achieve a reduction in MBL from baseline that exceeded the threshold determined by authors to be meaningful to women (36 ml/cycle).81

A small fair quality trial that compared TXA with norethisterone reported a statistically significant reduction in mean MBL occurred among women receiving TXA for two treatment cycles compared with those receiving norethisterone: 79 ml reduction (95% CI, 62 to 108 ml reduction) compared with 34 ml increase (95% CI, −2 to 64 ml reduction).80

A trial that compared TXA with ethamsylate and with mefenamic acid reported that the pretreatment MBL in the TXA group ranged from 143 to 178 ml, and over three treatment cycles the mean MBL was 72 to 77 ml, a mean reduction in MBL of 89 ml (range, 24 to 214 ml, p<0.001). For the ethamsylate group, the pretreatment MBL ranged from 157 to 185 ml, and over three treatment cycles the mean MBL was 161 to 185 ml, a mean increase of 8 ml (range, 280 to 103 ml). For the mefenamic acid group, the pretreatment MBL ranged from 159 to 199 ml, and over three treatment cycles the mean MBL was 138 to 168 ml, a mean reduction in MBL of 43 ml (range, 82 to 179 ml; p<0.001).66 Head-to-head comparisons of the results of treatment on absolute changes in blood loss showed that TXA reduced the mean loss by 97 ml more than with ethamsylate (95% CI, 54 to 140 ml, p<0.001) and by 56 ml more than with mefenamic acid (95% CI, 2 to 90 ml, p<0.05).66

A small crossover trial that compared TXA with flurbiprofen reported that over two treatment cycles the mean reduction in MBL from baseline for TXA was 140 ml (SD ± 33 ml, p<0.01), compared with 72 ml (SD ± 44 ml, p<0.01) for flurbiprofen.71

##### Pictorial Blood Loss Assessment Chart Score

One poor quality trial that used the pictorial blood loss assessment chart score as the blood loss measure, compared TXA with oral MPA and reported a significant (p<0.005) reduction in the pictorial blood loss assessment chart score over three treatment cycles from baseline for both TXA (60.3%) and MPA (57.7%).79

##### Hemoglobin

Four studies71,78-80 reported changes in hemoglobin level. In the good quality study, mean hemoglobin levels were unchanged from baseline for women taking TXA (0.02 ± 1.10 g/dL) while the placebo group had a statistically significant increase (0.34 ± 0.66 g/dL) that was not considered clinically significant.78 The post treatment hemoglobin levels were similar (estimated difference 0.2 g/dl, 95% CI, −0.5 to 0.9) in the TXA (12.9 g/dl) and norethisterone groups (12.6 g/dl).80 Hemoglobin levels rose significantly from baseline for women taking TXA (p=0.0003) and women taking MPA (p=0.02).79 The small crossover trial did not find differences in mean hemoglobin during the control cycles (127.4 ± 3.7 g/l) compared with either TXA (126.2 ± 3.0 g/l) or flurbiprofen (127.2 ± 3.4 g/l) cycles.71

##### Treatment Success

One placebo-controlled trial reported a statistically significant difference (p<0.001) for achieving a MBL below 80 ml (standard definition of heavy menstrual bleeding) in the modified intent-to-treat population between women receiving TXA (43%) compared with those receiving placebo (17%) for six menstrual cycles.78 This same study reported that 69 percent of cycles in the TXA group achieved a predetermined MBL reduction of at least 36 ml, representing a blood loss reduction considered meaningful to women.78 In the three-arm placebo controlled study, women receiving the higher (3.9 g/day) and lower (1.95 g/d) dose of TXA achieved a reduction in MBL from baseline that was perceived as meaningful to participants; however, only participants receiving the higher dose of TXA (3.9 g/day) achieved a mean reduction in MBL that exceeded 50 ml per cycle.81

##### Quality of Life

One placebo-controlled trial reported a statistically significant (p<0.001) difference in social or leisure activities, and in physical activity, favoring TXA.78 Women taking TXA has significant improvements in quality of life as assessed by the Menorrhagia Impact Questionnaire.81

#### Head-to-Head Comparisons

##### TXA Versus Norethisterone and MPA

The trial that compared TXA with norethisterone reported a statistically significant (p<0.0001) reduction in mean MBL for women receiving TXA for two treatment cycles compared with no reduction for women receiving norethisterone.80 Expressed as percentage, the change in MBL for TXA was a 45-percent reduction (95% CI, 23% increase to 93% reduction; p<0.0001 vs. baseline) compared with an increase of 20 percent (95% CI, 114% increase to 62% reduction; p=0.26 vs. baseline) for norethisterone; expressed as a measure of volume, there was a reduction in MBL of 79 ml (95% CI, 62 to 108 ml reduction) for TXA compared with an increase of 34 ml (95% CI, −2 to 64 ml reduction) for noresthisterone.80

In a trial that compared TXA with oral MPA, both groups experienced significant reductions in MBL compared with baseline; the effect of these interventions was comparable (p=0.78). 79

##### TXA Versus Mefenamic Acid, Ethamsylate, and Flurbiprofen,

TXA reduced the mean blood loss by 97 ml more than with ethamsylate (95% CI, 140 to 54, p<0.001) and by 46 ml more than with mefenamic acid (95% CI, 90 to 2 ml, p<0.05).66 The trial that compared TXA with flurbiprofen reported that the reduction in MBL during treatment with TXA was significantly (p<0.01) greater than the reduction reported during treatment with flurbiprofen.71

### Combined Oral Contraceptives

#### Key Points

- In two medium-sized RCTs, treatment of affected women with estradiol valerate and dienogest led to improvement in a range of AUB symptoms, including both overall complete response and effects on relevant laboratory values (e.g., hemoglobin, ferritin).
- In one small RCT and one small randomized crossover study of combination therapy with ethinyl estradiol and levonorgestrel and one small RCT assessing therapy with ethinyl estradiol and norethindrone acetate, COC treatment was associated with significant reductions in MBL as compared with baseline.

#### Detailed Synthesis

We identified five RCTs that explored the effects of therapy with COCs on the incidence and severity of abnormal cyclic uterine bleeding including two studies examining estradiol valerate and dienogest,82,83 two studies examining ethinyl estradiol plus levonorgestrel,59,68 and one study examining the combination of norethindrone acetate and ethinyl estradiol (Table 19).61 All five studies were industry-sponsored.59,61,68,82,83 Three were multicenter RCTs, involving Australia and Europe,82 the United States and Canada,83 and Canada,61 and two were academic single center studies, one conducted in Egypt59 and one conducted in Australia.68 Two of the studies included seven 28-day cycles of therapy with the primary response rate determined after 90 days of therapy,82,83 while one examined outcomes after 6 months68 and two assessed outcomes after 12 months.59,61 Two studies employed a placebo comparison group,82,83 two compared COCs to LNG-IUS,59,61 and one included a randomized crossover comparison of a COC to mefenamic acid.68

Table 19 Primary outcomes of COCs for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Key Outcomes
Fraser et al., 2011^82^ United States, Canada Good | G1: Estradiol valerate and dienogest (149) G2: Placebo (82) | - Full resolution of qualifying abnormal menstrual symptoms during the first 90 days of treatment observed in 40.7% of G1, as compared with 1.6% of G2 (p<0.0001).; - Mean reduction in MBL was 69% in G1 vs. 5.8% in G2 and there were significant reductions in days of bleeding (p=0.0186), and number of sanitary protection items used (p<0.0001) observed in G1 vs. G2.; - G1 participants had significant improvements vs. baseline in hemoglobin, hematocrit, and ferritin values; no similar change in G2.
Jensen et al., 2011^83^ Australia, Europe Good | G1: Estradiol valerate and dienogest (120) G2: Placebo (70) | - Full resolution of qualifying abnormal menstrual symptoms during the first 90 days of treatment observed in 43.8% of G1 vs. 4.2% of G2 (p<0.001).; - Mean reduction in MBL was 353 ml (64.2%) in G1 vs. 130 ml (18.7%) in G2 (p<0.001).; - G1 participants had significant improvements vs. baseline in hemoglobin, hematocrit, and ferritin values; no similar change in G2.
Shaaban et al., 2011^59^ Egypt Poor | G1: LNG-IUS (56) G2: Ethinyl estradiol and levonorgestrel (56) | - G2 associated with significant reduction in MBL at 12 months vs. baseline from 274.3 ± 142.6 ml to 118.2 ± 75.0 ml (p<0.001).; - Reduction in MBL at 12 months was significantly greater in the G1 vs. G2.; - Significant improvements in patient assessment of overall health noted in G1 and G2.
Endrikat et al., 2009^61^ Canada Poor | G1: LNG-IUS (20) G2: Ethinyl estradiol and norethindrone acetate (19) | - G1 and G2 experienced a significant decreased in MBL at 12 months compared with baseline. Mean decrease of 68% in MBL for G2 (p<0.001).; - Median MBL in G2 decreased from 290 ml at baseline to 72 ml at 12 months.
Fraser et al., 1991^68^ Australia Poor | G1: Mefenamic acid (12)^a^ G2: Ethinyl estradiol and levonorgestrel (12)^a^ | - Significant reduction in mean MBL observed during the COC treatment cycles (43%) as compared with baseline. (p<0.001).; - At least 20% reduction in MBL as compared with the preceding baseline cycles was observed in 10/12 patients during mefenamic acid treatment and 9/12 during COC treatment.

LNG-IUS = levonorgestrel-releasing intrauterine system; MBL = menstrual blood loss; COC = combined oral contraceptive

a Crossover study.

All studies assessed measures related to changes in MBL, including use of the alkaline hematin method59,68,82,83 and the pictorial blood loss assessment chart.59,61 Other outcomes included number of sanitary items used, a composite outcome of menstrual bleeding-related factors,82,83 and related hematologic parameters (i.e., hematocrit, hemoglobin, and/or serum ferritin).59,61,82,83 One study also assessed potential impact on health-related quality of life15 and one described effects on a menorrhagia symptom severity score.61 None of the studies assessed any potential effect modifiers.

Among the five studies of COC therapy, two were good quality82,83 and three were poor quality.59,61,68 Details of quality scoring for individual publications are included in Appendix I.

#### Description of Results

##### Estradiol Valerate and Dienogest

Two multicenter RCTs with the same industry sponsor assessed the utility of estradiol valerate and dienogest in treatment of women with AUB, defined as prolonged, frequent, and/or heavy bleeding. The first RCT82 was conducted in Australia and Europe and comprised 231 women, randomized at a 2:1 ratio after a 90-day run-in period to receive estradiol valerate and dienogest for seven 28-day cycles. The study drug regimen included estradiol valerate 3 mg on days 1 to 2, estradiol valerate 2 mg and dienogest 2 mg on days 3 to 7, estradiol valerate 2 mg and dienogest 3 mg on days 8 to 24, estradiol valerate 2 mg on days 25 to 26, and placebo on days 27 to 28. Complete response, defined as full resolution of qualifying abnormal menstrual symptoms during the first 90 days of treatment as compared with the 90-day run-in phase, was observed in 29.5 percent of the estradiol valerate and dienogest group, as compared with 1.2 percent of the placebo-treated patients (p<0.0001). Treatment with estradiol valerate and dienogest was also associated with significant reductions in volume of MBL (p<0.0001), days of bleeding (p=0.02), and number of sanitary protection items used (p<0.0001) as compared with the placebo group. The estradiol valerate and dienogest-treated patients also experienced significant improvements versus baseline in hemoglobin, hematocrit, and ferritin values; similar improvements were not observed in the placebo-treated group.

The second RCT83 was conducted at centers in the United States and Canada, employing the same dose and randomization schema and including 190 women with AUB. Complete response, defined as full resolution of qualifying abnormal menstrual symptoms during the first 90 days of treatment as compared with the 90-day run-in phase, was observed in a significantly greater proportion of the estradiol valerate and dienogest group (35/80, 44%) as compared with the placebo group (2/48, 4%, p<0.001). The mean reduction in MBL was also greater in the estradiol valerate and dienogest (−353 ml or −64% vs. loss during run-in phase) when compared with the placebo group (−130 ml or −19% vs. observed run-in loss, p<0.001). Individuals in the estradiol valerate and dienogest group also experienced significant improvements in hemoglobin, hematocrit, and ferritin values as compared with the run-in phase, while similar improvements were not observed in the placebo group.

##### Ethinyl Estradiol and Levonorgestrel

Two randomized controlled trials assessed the utility of an ethinyl estradiol (30 mcg) and levonorgestrel (150 mcg) combination in women with menorrhagia.59,68 One of these trials was a single center RCT involving 112 women with idiopathic menorrhagia randomized to LNG-IUS (n=56) or ethinyl estradiol/levonorgestrel (n=56) for 12 months.59 Efficacy data from the LNG-IUS arm of the study is discussed further in the LNG-IUS section of this report. In this trial, the COC regimen was associated with a significant reduction in MBL as assessed by the alkaline hematin method at 12 months as compared with baseline, from 274.3 ± 142.6 ml to 118.2 ± 75.0 ml (p<0.001); however, the overall reduction in MBL was significantly greater in the LNG-IUS group as compared with the COC group. Significant improvements in patient assessment of overall health and reduction in physically ill days were noted in both treatment groups.

The other trial assessing the use of ethinyl estradiol and levonorgestrel was a crossover study in women with menorrhagia, with one arm comparing outcomes of 12 women treated sequentially with mefenamic acid (500 mg every 12 hours from first sign of menses until 24 hours after usual duration of heavy bleeding) and COCs for two cycles each in random order, with a two-cycle washout period between treatment cycles.68 Additional efficacy details for mefenamic acid and for another treatment arm in this study involving naproxen are further discussed in the NSAIDs section of this report. A significant (p<0.001) reduction in mean MBL as measured by the alkaline hematin method was observed during the COC treatment cycles as compared with baseline (43%); the reduction in mean MBL during the mefenamic acid treatment period was not significantly different than the COC treatment period. A response of at least 20 percent reduction in MBL as compared with the preceding baseline cycles was observed in 10 of 12 patients during mefenamic acid treatment and in 9 of 12 during COC treatment. One patient responded to COCs but not to mefenamic acid, and two patients exhibited a response to mefenamic acid but not to the COC regimen.

##### Ethinyl Estradiol and Norethindrone Acetate

One multicenter randomized controlled trial compared the combination of ethinyl estradiol (20 mcg) and norethindrone acetate (1 mg) to use of a levonorgestrel-releasing intrauterine system (LNG-IUS) over 12 months in 39 women with idiopathic menorrhagia.61 Efficacy data from the LNG-IUS arm of the study is also discussed further in the levonorgestrel-releasing intrauterine system section of this report. The LNG-IUS arm included 17 women and the COC arm included 12. Both arms experienced a significant (p<0.001) decrease in MBL at 12 months as compared with baseline, with a decrease from a median MBL of 290 ml at baseline to a median of 72 ml at 12 months observed in the COC group (mean decrease 68%). The decrease in MBL, however, was significantly greater in the LNG-IUS group versus the COC group (p=0.002). Treatment success, defined as MBL less than 100 at 12 months, was observed in a significantly (p<0.009) greater proportion of the LNG-IUS participants (80%) as compared with the COC group (37%). Menorrhagia symptom severity scores were also significantly lower in the LNG-IUS group at 6 months as compared with the COC group (p=0.05). No significant changes in hemoglobin concentration were observed in either group during the study.

### Use of Decision Aids in Treatment of Menorrhagia

#### Key Points

- Three RCTs evaluated decision aids to assist patients with menorrhagia. All were of poor quality due to lack of blinding of participants and care providers.
- Improvements in general health status, the primary outcome for 2 studies, were not associated with decision aids. One study reported lower use of hysterectomy among women who had an interview prior to their consultation while another study did not show differences in hysterectomy rates after 1 year. Two studies did not report differences in treatment outcomes after 6 months or 1 year.

#### Detailed Synthesis

Decision aids are interventions to inform patients of their treatment options when more than one option exists. A recent Cochrane review of RCTs of decision aid94 found that decision aids are beneficial in increasing patient knowledge of treatment options, help to clarify benefits and harms associated with therapeutic choices, and increase patient participation in decision selection. They have been shown to reduce elective surgery and have no apparent adverse effects on patient outcomes or satisfaction.94

We identified three RCTs with four publications85-87,95 about medical decision aids in women with menorrhagia (Table 20). All of the studies used a written decision aid booklet; one study evaluated a computerized decision aid in conjunction with the pamphlet and one study also mailed participants a videotape and conducted an interview prior to clinical appointment. Diagnosis of menorrhagia was determined from medical records and not quantified in any of the studies. Length of followup ranged from 6 months to 2 years. Two studies were conducted in the United Kingdom86,87 and one was conducted in Finland.85 These studies were all of poor quality.

Table 20 Primary outcomes of decision aids for abnormal cyclic uterine bleeding

Author, Year Country Quality | Comparison Groups (n) | Outcomes | Results
Protheroe et al., 2007^87^ United Kingdom Poor | G1: Computerized decision aid and information leaflet (74) G2: Information leaflet only (72) | Primary: total score on Decisional Conflict Scale Secondary: anxiety, quality of life, knowledge, treatment preferences | - Decisional conflict was significantly reduced in G1 vs. G2 (adjusted difference 16.6 95% CI, 21.5 to 11.6, p<0.001).; - Anxiety declined slightly for both groups (p=NS).; - Quality of life and knowledge scores improved in both groups but more in G1 as compared with G2.
Vuorma et al., 2004^85,95^ Finland Poor | G1: Information booklet (184) G2: Usual care (179) | Primary: Planned treatment at 3 months and actual treatment at 1 year General health status measured by RAND -36 Secondary: knowledge of treatment methods, satisfaction with communication anxiety and sexuality | - Fewer women in G1 received newer treatments (minor surgery or LNG-IUS) (p=0.03); hysterectomy rates were similar in both groups.; - Most health status measures improved for both groups.; - At 3 months 18% of women in G1 and 8% in G2 had received prescription for oral medication (p=0.007).; - There were no differences between groups in anxiety, satisfaction, knowledge or sexual satisfaction.
Kennedy et al., 2002^86^ United Kingdom Poor | G1: Interview and information booklet (300) G2: Information booklet only (296) G3: No intervention (298) | Primary: general health status measured using SF-36 Secondary: treatments received during followup, severity of menorrhagia, patient satisfaction | - Health status measures improved for all 3 groups. Treatment rate (81%) during study was similar for all 3 groups (p=0.17) but women in G1 were less likely to have a hysterectomy (OR 0.60 95% CI, 0.38 to 0.96).; - G1 were more satisfied in taking part in treatment decision and with results compared with G3.

CI = confidence interval; OR = odds ratio; NS = nonsignificant

The largest study (n=894), conducted in England, randomized women to receive booklet and videotape with interview, materials without interview, or standard practice groups.86 General health status improved significantly and menorrhagia severity decreased in all three groups. Treatment rates were similar in all groups after 2 years. Women in the interview group had a lower rate of hysterectomy and reported greater satisfaction with treatment results. A medium sized Finnish study evaluated the effectiveness of a mailed information booklet on treatment outcomes and general health status after 1 year.85,95 More women who received the decision aid were less likely to receive newer treatment methods including minor surgery or LNG-IUS (16% vs. 26%, p=0.03). Most of the measured health outcome scores improved after 1 year for both groups with no significant difference in patient satisfaction, knowledge, anxiety or sexual satisfaction.

A small English study87 conducted from 2003 to 2005 evaluated a computerized decision aid in conjunction with a patient leaflet. Women in the intervention group had significantly less decisional conflict at 2 weeks and higher knowledge scores at 6 months. There were no significant group differences in anxiety or treatments received after 6 months.

Although decision aids do help to increase patient knowledge, there are some methodological limitations in these studies, including low participation rates, large number of drop outs, and lack of blinding. The diagnosis of menorrhagia was not quantified and no effect modifiers were examined in any of these studies. Information on harms was not reported in any of the decision aid studies.

## KQ2 Harms of Interventions for Management of Abnormal Bleeding

### Description of Included Studies and Sources of Information

Capturing useful information about potential harms of treatment for reproductive-age women that is specifically applicable to interventions for abnormal bleeding is a challenge. A wide range of interventions are used to treat abnormal bleeding. Twelve interventions relevant to the primary care setting were identified for this report. They range from medications that are exceptionally familiar to providers such as NSAIDs to potentially less familiar or newer medications like exenatide (an injectable diabetes agent). Interventions also include those with widespread use and many indications, like oral contraceptive pills or acupuncture, as well as those specifically for the indication of abnormal bleeding like TXA.

To pare down the scope of the material, we took a four step approach to structuring this KQ about harms.

- Summarizing harms detected within clinical trials included in this review. This has limitations since many of the studies are small, with a range in size of 14 to 894 and a median total study population of 80. Thus they are not well-suited to detecting events that are rare but may be serious or affect a specific subgroup of women.
- Compiling the key content of FDA documents and package inserts for specific products addressed in this review. This however lacks specificity as many of these products have multiple indications and the concerns may not be as applicable to the population of women with AUB or to the dose and duration of use for treating AUB. Furthermore symptoms and harms are reported in these documents that may not be statistically, meaningfully different between the active agent and the placebo.
- Searching for surveillance studies that aimed to examine risk of harm in large populations of individuals (i.e., 1600 or more) using the specific intervention. This last step was done using a separate search described in greater detail in methods. We restricted summarizing results from harms surveillance studies to: metformin, exenatide, progestogens, cabergoline, LNG-IUS, contraceptive vaginal ring, and TXA.
- Providing information about existing contemporary reviews and guidance on harms for common medications with broad indications. Like the second approach it is important to note that these extant literature reviews reflects varied indications and populations that may not be directly applicable to use for AUB.

The organization of this chapter includes evidence about harms from these sources in the following order:

- Harms identified in randomized trials included in this review.
- Harms flagged in FDA package inserts and regulatory proceedings.
- Harms investigated in large surveillance studies of metformin, exenatide, relevant progestogens, cabergoline, LNG-IUS, contraceptive vaginal ring, and TXA.
- Contemporary reviews that include review of harms.

We present this summary of harms in the same order of KQs and intervention methods as the results for our KQs. Interventions for irregular uterine bleeding are present before those for abnormal cyclic uterine bleeding.

### Key Points for Harms of Reviewed Treatments

- Metformin is associated with increased risk of gastrointestinal symptoms like diarrhea and abdominal pain. Symptoms can be reduced by slowly increasing the dose. Severe harms including lactic acidosis, serious hypoglycemia, and liver failure, studied among populations of adult diabetics, occur at incidence rates below 1 in 10,000 and may be as low as 1 in 100,000 person-years of exposure.
- Progestogens are associated with a number of common side effects of hormonal preparations including weight gain, fluid retention, abdominal pain, nausea, change in mood, and change in appetite. Abnormal uterine bleeding is itself a common side effect of progestogen only interventions.
- COCs have commonly recognized side effects that include edema, breast tenderness, nausea, headache, and skin changes. Known contraindications, including advancing age, smoking, and high risk of thrombosis, apply when considering use of COCs for irregular bleeding. Selected COC formulations may have lower risk of deep vein thrombosis than others.
- Cabergoline has few known distinct harms; however, data is inadequate to assess risk in young women without elevated prolactin.
- LNG-IUS has few serious harms after insertion. Irregular bleeding, especially early after insertion is the most commonly reported side effect. Painful insertion occurs in roughly 1 of 100 procedures; 3.2 of 100 insertions are technically difficult, and uterine perforation occurs in 0.9 to 2.6 cases per 1,000. The LNG-IUS is not associated with increased deep vein thrombosis risk.
- NSAIDs have common harms that include abdominal pain, nausea, gastritis, and lightheadedness/dizziness. Gastrointestinal bleeding is a serious side effect related to total dose and duration of use; however, even short-term use can increase risk. The risk of gastrointestinal bleeding from low-dose, intermittent NSAID use is poorly characterized.
- TXA use is associated with headache, nasal and sinus symptoms, back pain, and abdominal pain in more than 10 percent of those taking the drug. Joint pain, muscle cramps, migraine, anemia and fatigue occur in more than 5 percent. Rare events are less well characterized and may include thrombosis, anaphylaxis, and visual disturbances. TXA is contraindicated in those with higher risk of thrombosis.
- Contraceptive vaginal ring has similar side effects to COCs including breast tenderness, nausea and headache. Ring users also experience local problems including leucorrhea, vaginitis, and ring-related events including expulsion, foreign body sensation, and coital problems. The contraceptive vaginal ring is not recommended for use in cigarette smokers over age 35.
- Other than COCs, progestogens, and the LNG-IUS, the available data may not apply well to populations of young women using these treatments.

### Detailed Synthesis

#### Harms Related to Metformin

##### Information about Metformin from Included Trials

Metformin was investigated in two placebo controlled trials51,52 and in two arms of a three-arm trial in which two arms included metformin:53 one metformin alone and another with combined oral metformin and exenatide weekly injections. Doses used in these studies, after an initial 1 week dose ramp up were 850 mg twice a day,51 500 mg 3 times daily,52 and 1,000 mg twice daily.53 Combined, the three RCTs, with four total metformin arms, administered the drug to only 77 women, 20 of whom were also receiving another agent.51-53 This provides insufficient power to detect events that occur at the level of 1 to 5 percent or lower that are typically of concern for harms. It also provides insufficient power to conclude that specific symptoms were statistically more common among those treated than among the 33 women who received placebo in two studies.51,52 Women receiving metformin did report gastrointestinal symptoms, including diarrhea, abdominal pain, and nausea at higher absolute numbers than those in the placebo or exenatide only groups,52,53 and the study reporting withdrawals51 documented 3 times as many women on the active drug withdrew from the trial for side effects (15/45 vs. 5/47; p<0.05).

##### Information About Metformin From FDA Documents and Package Inserts

Increased gastrointestinal complaints are consistent with the documented side effects listed in the package insert for metformin which include: diarrhea, nausea/vomiting, flatulence, indigestion, and abdominal discomfort as events that are the most common and expected to occur in more than 5 percent of those who initiate the drug.96 Of note, it is recommended that the dose be increased gradually over 1 week or more precisely because these effects are common and can be reduced by gradual introduction of the drug. The most serious known side effect of metformin is lactic acidosis which occurs when lactate accumulates in the blood and decreases blood pH. The package insert includes a boxed warning for this concerning effect.96 Little is known about how common lactic acidosis might be among reproductive-age women, with PCOS and not type 2 diabetes, similar to those in the study or for whom the intervention might be considered as part of primary care management of irregular uterine bleeding.

##### Information About Metformin From Large Datasets

Our literature search aimed at identifying publications designed to investigate harms, required more than 1,600 exposed individuals, or for case-control analyses, case identification consistent with a base population of more than 1,600. We identified four publications focused on metformin harms.97-100

The Toxic Exposure Surveillance System database of the American Association for Poison Control Centers provided data from 1996 through 2000 for accidental and intentional over ingestion and unintentional misuse of metformin for 4,072 cases.97 Fifty-nine percent were women and the majority was adults. Children under 12 had few serious side effects and no deaths. Among adults, harms were evenly distributed across ages with a trend for more serious outcomes in the elderly. In all groups lactic acidosis was rare (1.6%) and hypoglycemia at 2.8 percent was more common that previously reported. Given all individuals had unintended or higher than therapeutic doses, they also observed elevated creatinine levels, an increased anion gap, hypotension, and coma among those hospitalized.

The first publication focused on harms of intended use was published in 2003 to assess incidence of serious acute liver injuries in patients on hypoglycemic agents.98 The population comprised the 171,264 members of five health maintenance organizations receiving oral diabetes medications. They identified 35 cases of acute liver failure, not known to be attributable to another cause. Incidence per 1,000 person-years of use was not statistically meaningfully different by medication used, after adjusting for other comorbidities and confounders. Overall occurrence was roughly 1 case per 10,000 person-years in this population of all adult diabetics.98

In 2008, an analysis using the U.K. General Practice Research Database undertook an analysis of the risk of lactic acidosis and hypoglycemia among 50,048 type 2 diabetics using oral medications.99 The average age of patients included in the analysis was 60.7 ± 11.7 and 54.8 percent were women. They determined the incidence rate of lactic acidosis was 3.3 per 100,000 person-years among metformin users and 4.8 per 100,000 person-years among those on sulfonyl ureas. The adjusted odds ratios for both lactic acidosis and severe hypoglycemic episodes were significantly higher for those on sulfonyl ureas than metformin with a more than 2-fold elevation in risk. However this analysis also did not include individuals taking metformin for indications other than diabetes.

A retrospective cohort of more than 44,169 diabetic patients in a prepaid health plan followed for an average of 4.2 years evaluated use of endoscopy.100 The exposure of interest was defined by prescription of specific diabetes medications and the outcome of interest was lower gastrointestinal tract endoscopy including flexible sigmoidoscopy and colonoscopy. The analysis was undertaken in part out of concern that therapy with metformin, with attendant risk of gastrointestinal side effects, could increase use of lower tract endoscopy. Forty-seven percent of participants were women with an average age of 66. The authors found that rates of endoscopy were higher among all groups of diabetics on medications, including those using insulin. Taking into account the precision of the estimates, there was no evidence that metformin led to excess use compared with other medications either in the window immediately after initiation or with chronic use. Overall, the higher use of endoscopy may simply reflect greater screening and prevention vigilance among these patients with a chronic disease. No comparison is offered to rates among diabetics controlled with diet and exercise alone.

##### Information About Metformin From Systematic Reviews

Estimates for withdrawals related to inability to tolerate the drug in included trials are consistent with the meta-estimate in a recent systematic evidence review on management of obesity. The AHRQ Screening and Management of Obesity in Adults101 evidence review reported a risk ratio of 3.92 (95% CI, 1.23 to 12.57) for withdrawals in metformin-treated groups compared with placebo in trials aimed at weight loss and not diabetes management.101 The report likewise found excess complaints of gastrointestinal symptoms but was not able to quantify risk and noted that evidence about harms is insufficient to inform care.101

Similar to the surveillance data, a Cochrane pooled analysis of comparative data from 347 trials found an upper limit of 4.3 cases of lactic acidosis per 100,000 patient-years among metformin-treated diabetic patients.102 The analysis indicated no significant difference in mean treatment levels or net change from baseline for lactate for metformin users as compared with users of other therapies represented in the included trials.103 This review also notes that the only evidence for lactic acidosis associated with metformin use is based on approximately 330 cases reported in the literature.102 The 2011 AHRQ comparative effectiveness review (CER) Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update104 included 140 trials with a meta-analysis. Across all data sources in their review, the reviewers concluded there was high grade evidence that metformin alone and in combination with other diabetes medications was associated with greater occurrence of gastrointestinal side effects than with other agents alone or in combinations that did not include metformin. Nonetheless the overall safety profile and effectiveness of metformin led to the conclusion that metformin was the first-line agent for initial management of type 2 diabetes. The authors take care to point out that even among trials for a chronic condition like type 2 diabetes, longer term surveillance for harms does not exceed 2 years. As in diabetes, women with abnormal bleeding might wish to consider chronic treatment and the literature to assess safety of continued use for any indication is scant.

Within a number of reviews of oral diabetes agents105,106 metformin is typically found to have a favorable safety profile when compared with other medications and is often noted to be first-line therapy in part for this reason. Relative safety in the context of other options for treating diabetes is not directly applicable to use for improving menstrual cycle regularity, however there are no physiologic reasons to expect that younger individuals without diabetes would experience greater risk.

#### Harms Related to Exenatide

##### Information About Exenatide From the Included Trial

A single RCT in this review investigated exenatide, finding that alone it was less effective than metformin, but that when combined the results were superior to either agent alone for improving cycle regularity in women with PCOS.53 Exenatide is injected weekly and is generally administered as a second agent among those with diabetes that is insufficiently controlled on a single agent. The trial included in this review allocated women with PCOS to three groups: 1,000 mg of metformin twice daily, exenatide 10 mcg per day, or both.53 Nausea, diarrhea, and bloating were more common in the arms taking metformin. No harm was more common in the exenatide group except injection site pain or bruising which was de facto restricted to groups using exenatide. Comparisons across groups of 20 are underpowered to detect differential harms across groups or to detect more rare and potentially serious harms.

##### Information About Exenatide From FDA Documents and Package Insert

The package insert for exenatide notes that hypoglycemia is a common adverse effect but does not specify what proportion of those prescribed the drug might experience low blood sugar.107 Events that occurred in 2 percent or more of new users of exenatide when added to a regimen with metformin or a sulfonyl urea include: nausea, vomiting, diarrhea, feeling jittery, dizziness, headache, dyspepsia, asthenia which is a lack of strength or energy, gastroesophageal reflux, and increased sweating. Postmarketing experience includes reports of: injection-site reactions; generalized pruritus and/or urticaria; macular or papular rash; angioedema; anaphylactic reaction; increased international normalized ratio with concomitant warfarin use sometimes associated with bleeding; nausea, vomiting, and/or diarrhea resulting in dehydration; abdominal distension; abdominal pain; eructation; constipation; flatulence; acute pancreatitis; hemorrhagic and necrotizing pancreatitis sometimes resulting in death; dysgeusia; somnolence; altered renal function, including increased serum creatinine; renal impairment; worsened chronic renal failure or acute renal failure (sometimes requiring hemodialysis); kidney transplant and kidney transplant dysfunction; and alopecia (Byetta Package Insert, 2011).107

##### Information About Exenatide From Large Datasets

Surveillance studies have all focused on acute pancreatitis which is suspected of being a rare but important side effect. Two analyses in large patient pools did not identify an association,108,109 while a third publication with data from the FDA post marketing surveillance database did see increased risk for both exenatide and another drug with similar but not identical mechanism, sitagliptin.110

The two claims-based analyses relied on large databases of health plan enrollees: The Ingenix Research Datamart108 and the Normative Health Information database.109 The first examined 27,966 individuals who began exenatide and 16,276 who started sitagliptin.108 During 1 year of followup, acute pancreatitis occurred in 0.13 percent of those on exenatide and 0.12 percent of those on sitagliptin. In adjusted models, relative to comparison cohorts within the health plan the relative risk of acute pancreatitis was 1.0 for both groups with confidence bounds from 0.6 to 1.7 and 0.5 to 2.0 respectively. The second analysis included 25,719 new users of exenatide compare to 234,536 new users of other diabetes medications.109 The groups differed in important ways including more obesity and concomitant diabetes medications among those using exenatide. In adjusted models to control for these and other factors, there was no increase in use for current or recent use but an elevation in risk for past use. This was compared with a matched case-control analysis that found no association for any category of current, recent, or past use. This is compatible with those with past use having unknown additional comorbidity or discontinuing use because of other serious health events. The authors conclude overall there was not increased risk of pancreatitis among those taking exenatide.

The FDA surveillance data compared adverse events for exenatide to those for other drugs in the database.110 They found the odds of being on exenatide were more than 10-fold higher than the control drug for pancreatitis. Pancreatic cancer was almost 3-fold higher. The sole control for confounding was the use of those on other drugs in the registry as a comparator. The authors note that the FDA data is limited by incomplete data and reporting bias; notably they lack information about obesity and individual behaviors such as alcohol use and the risk models are not adjusted for these confounders.

##### Information About Exenatide From Systematic Reviews

Systematic reviews of diabetes medications (including the AHRQ report above on obesity treatment101), a detailed CER conducted by the United Kingdom's National Health Service, and a Cochrane analysis including exenatide, reveal gastrointestinal issues, particularly nausea and vomiting, and hypoglycemia as the most commonly observed side effects observed in those initiating therapy with this agent.101,111,112

#### Harms Related to Progestogens

##### Information About Progestogens From Included Trials

A single RCT included in this review investigated progestogen use for improving cycle regularity.49 The two agents used in this comparative effectiveness trial were 20 mg of oral dydrogesterone, each day for 10 days, or 90 mg of micronized progesterone gel vaginally every other day for 10 days. The authors' intent was to demonstrate that both oral and vaginal administration improved cycle control which was the case compared with baseline. However power calculations did not indicate the equivalence band desired and the overall study was small (n=69). They report the only adverse events experienced were in the micronized vaginal progesterone gel group and included one episode each of groin pain, ovarian cyst, and 5-kg weight gain. These events were too rare given the small study size to meaningfully assert comparability or excess of harms between groups. Six patients in each treatment group withdrew from the study (reasons not given), suggesting there was not a large discrepancy in willingness to stay on study drug.

Eight studies of treatments for abnormal cyclic bleeding (KQ1B) included a progestogen as a comparator. MPA was a comparator in three studies,60,62,79 one of which included DMPA as a third comparison arm.62 Five studies compared LNG-IUS, TXA, an NSAID, or the contraceptive vaginal ring to norethisterone64,70,74,80,84 and one of these studies also included a third arm using the progesterone-impregnated intrauterine coil as a comparator.74 Harms reported with this class of drug include: breakthrough bleeding; spotting; change in menstrual flow; amenorrhea; headache; nervousness; dizziness; edema; increases or decreases in weight; change in cervical secretions; cholestatic jaundice, breast tenderness and galactorrhea; skin sensitivity reactions consisting of urticaria, pruritus, edema and generalized rash; acne, alopecia and hirsutism; rash (allergic) with and without pruritus; anaphylactoid reactions and anaphylaxis; depression; pyrexia; fatigue; insomnia; nausea; and somnolence.113-116 Most studies reviewed were small and did not systematically compare adverse events across interventions groups. In all but one case, progestogens were a comparator that was hypothesized and found to perform less well than the intervention under study. The one exception was a direct comparison of two routes of delivery discussed above.49 We consider COCs and the LNG-IUS in their own section.

##### Information About Progestogens From FDA Documents and Package Inserts

We have summarized information for progestogen only methods included in this review. The label for Crinone, the progesterone vaginal gel, reports adverse events seen in the three clinical studies for secondary amenorrhea in women taking either 4-percent or 8-percent strength Crinone along with estrogen and occurring in 5 percent or more of women.114 These are given as: abdominal pain (5% in patients taking 4% strength, 9% in patients taking 8% strength, respectively); appetite increased (5%, 8%); bloating (13%, 12%); cramps not otherwise specified (19%, 26%); fatigue (21%, 22%); headache (19%, 15%); nausea (8%, 6%); back pain (8%, 3%); myalgia (8%, 0%); depression (19%, 15%); emotional lability (23%, 22%); sleep disorder (18%, 18%); vaginal discharge (11%, 3%); upper respiratory tract infection (5%, 8%); and pruritus in genital area (2%, 6%).114 The package insert for vaginal progesterone gel includes a warning that “physicians should be alert to the earliest manifestations of thrombotic disorders (thrombophlebitis, cerebrovascular disorders, pulmonary embolism, and retinal thrombosis).”114

This profile of complaints is similar among smaller groups of women who receive the drug as part of treatment for infertility care. One of the specific agents studied among women with irregular menses, dydrogesterone, is not available in the United States. This compound has been associated with risk of onset of acute porphyria. Porphyria is a genetic condition in which individuals have a range of severities of defects in the enzyme pathways that produce heme. The insert advises prescribing only for compelling reasons. Our review team does not find evidence that other progestogens are associated with acute onset of porphyria symptoms.

The DMPA label115 includes a warning to women who may become pregnant while using the drug or find themselves exposed to the drug during the first 4 months of pregnancy regarding the risk of hypospadias; the risk of hypospadias, usually 5 to 8 per 1,000 male births in the general population, may be approximately doubled with exposure to these drugs.115 Additionally, there have been undesirable effects at the site of injection, such as residual lump, change in skin color, or sterile abscess.115

##### Information about Progestogens from Large Datasets

The specific compounds used for irregular uterine bleeding or abnormal cycle bleeding were not addressed in large surveillance studies or in systematic review that compiled information about harms separate from their inclusion in COCs with the exception of DMPA and norethindrone in progestin-only pills.

As noted, we did not attempt to review the surveillance literature related to harms of oral contraceptives or specific progestogens in COCs. We did however seek large scale primary studies related to harms of progestogen-only formulations such as DMPA. Four studies, one conducted in Europe, one in Turkey, and two in Africa, described harms associated with DMPA.117-120 A single cross-cutting study of contraceptive risks included norethindrone-alone pills.121

A Danish case-control study that included 64,548 women with fractures indicated an association with DMPA use (OR=1.44; 95% CI, 1.01 to 2.06); this however was not adequately controlled for factors that may confound the relationship, such as the potentially increased use of DMPA among smokers or those with lower body mass index which are both also associated with fracture risk.118 A study in South Africa evaluated bone density in 3,487 black, reproductive-age women using injectable progestogens as contraception and reported decreased bone density by measurement of heel bone density; this effect was reversible within 2 to 3 years of discontinuing the injected progestogen across age categories of users.119 These findings are compatible with data from smaller studies which they review well in their publication.

DMPA has been associated in observational studies with deep venous thrombosis.117 However, other work comparing those who use medications for menorrhagia has documented increased risk among women who use TXA, mefenamic acid, and norethisterone, suggesting that the increased risk of thrombosis may be an example of confounding by indication. Such confounding suggests that the reason for which the medication is administered itself increases risk of the adverse outcomes.122 In a comprehensive study of 9,262 DMPA users in Turkey conducted between 1996 and 2004, deep vein thrombosis was not observed.120 The most common adverse effects reported were menstrual disturbances (80%), weight gain (10%), bloating, breast pain, headache, mood change, and sexual difficulties (each reported by more than 1%). More than one-third of women discontinued the method with the most common reasons for discontinuing other than desiring to conceive being irregular menses and side effects.

A 2012 publication about hormonal contraceptive methods and risk of thrombotic stroke and myocardial infarction, estimated risk based on person-years of exposure to specific contraceptive methods in a cohort of 15 years duration.121 In a total of 85,874 women-years of observation, norethindrone progestin-only pills were not statistically significantly associated with increased risk of either stroke or myocardial infarction.

##### Information About Progestogens From Systematic Reviews

A Cochrane review examining the use of progestogens for the treatment of heavy menstrual bleeding found that progestogens had a generally better side effect profile than danazol, with lower incidence of side effects such as headache, weight gain, and skin changes; however, breast changes were relatively more common in the progestogens group.123 In the context of evaluating progestogen-only pills for contraception, another Cochrane review found inter-cycle bleeding and cycle irregularity to be some of the most common reasons for treatment discontinuation represented in included trials.124

#### Harms Related to COCs

##### Information About COCs From Included Trials

Our review included six RCTs examining COC use in women with abnormal uterine bleeding.50, 59, 61, 68, 82, 83 Due to the low power of these three medium sized RCTs and three small RCTs for detecting adverse events, reports of potential harms in these publications are largely limited to descriptive text rather than quantitative comparisons.

Among women with irregular menses only (KQ1A), one study treated patients with COCs. Davis and colleagues50 assessed a triphasic pill in which the estrogen was ethinyl estradiol and the progestogen was norgestimate. Their trial randomly assigned 201 women to the oral contraceptive arm or a placebo. Authors do not provide detailed description of adverse events, noting that the incidence was low and comparable between the two groups. Four women in the COC group and three in the placebo group discontinued use after adverse events. Sixteen percent of those on active drug and 19 percent of those receiving placebo withdrew prior to completion of the trial.

Two trials assessing the use of estradiol valerate and dienogest in women with abnormal cyclic uterine bleeding (KQ1B) each found that 9 to 10 percent of women discontinued therapy with the COC regimen due to side effects.82,83 The type and incidence of adverse effects noted in these two studies of estradiol valerate and dienogest are similar to those noted in the package insert for this combination.125

The trial examining therapy with ethinyl estradiol and norethindrone acetate reported that five women discontinued the study due to adverse events (approximately 25%), noting that the most comment events included intermenstrual bleeding, menstrual disorder, and headache.61 The two studies involving use of ethinyl estradiol and levonorgestrel did not describe potential harms associated with treatment failure, other than noting the incidence of treatment failure.59,68

##### Information About COCs From FDA Documents and Package Inserts

The package inserts are similar for all combined estrogen and progestogen oral contraceptive pills. The warning for combined pills notes:

Cigarette smoking increases risk of serious cardiovascular events from combined oral contraceptive (COC) use. This risk increases with age particularly in women over 35 years of age and with the number of cigarettes smoked. For this reason, COC's should not be used by women who are over 35 years of age and smoke.126-128

Other serious harms associated with COCs include thrombophlebitis and venous thrombosis with and without embolism, arterial thromboembolism, pulmonary embolism, myocardial infarction, cerebral hemorrhage, cerebral thrombosis, hypertension, gallbladder disease and benign liver tumors. A complete listing of package insert adverse events for this and other oral contraceptives reviewed in this report is included in Appendix N. Package inserts do not generally include information about the expected population incidence of these harms.

The majority of primary care providers and many women are aware of the most serious risks of COCs and of more common side effects such as edema, nausea, vomiting, skin changes, and gastrointestinal symptoms. Among more common side effects are also changes in cycle characteristics themselves including spotting/breakthrough bleeding, lack of menses, and change in characteristics of menstrual flow.

Adverse events for specific COCs studied for heavy menstrual bleeding in this review include Nordette-28^®^ (0.03 mg ethinyl estradiol and 0.15 mg levonorgestrel). The package insert reports based on data from case control studies, the relative risk for superficial venous thrombosis is three times higher in users of the COC compared with nonusers; the risk of deep vein thrombosis or pulmonary embolism is 4 to 11 times higher, and 1.5 to 6 times higher in women predisposed to venous thromboembolic disease.127 The incidence of deep vein thrombosis and pulmonary embolism for users of low-dose (i.e., less than 0.05 mg ethinyl estradiol) COCs is up to 4 per 10,000 woman-years compared with 0.5 to 3 per 10,000 woman-years for nonusers, although this risk is less than the risk associated with pregnancy (6 per 10,000 woman-years).127 A large postmarketing study noted that the Nordette label information reports a relative risk of thrombotic strokes ranging from 3 for normotensive users to 14 in women with severe hypertension. The relative risk of hemorrhagic stroke is reported to be 1.2 for nonsmokers using oral contraceptives, 2.6 for smokers who did not use oral contraceptives, 7.6 for smokers who used oral contraceptives, 1.8 for normotensive users, and 25.7 for users with severe hypertension.127

Label information on estradiol valerate and dienogest (Natazia^®^) reports two cases of myocardial infarction and two cases of rupture ovarian cyst from clinical trials, along with known serious risk of other cardiovascular events, vascular events, and liver disease (the estimated attributable risk of liver adenomas is 3.3 cases per 100,000 COC users).125 In clinical studies of the drug, 11.4 percent of women discontinued treatment due to an adverse reaction, most commonly: menstrual disorder (metrorrhagia, menorrhagia, menstruation irregular, genital hemorrhage, vaginal hemorrhage, dysfunctional uterine bleeding; 2.3%); mood changes (depression, mood swings, mood altered, depressed mood, dysthymic disorder, crying; 1.2%); acne (1.1%), headache (including migraines; 1.1%), and weight increased (0.7%).125

Postmarketing reports with Natazia include: venous and arterial thromboembolic events (including pulmonary emboli, deep vein thrombosis, cerebral thrombosis, myocardial infarction and stroke); hypertension; gallbladder disease; hepatitis; hypersensitivity; fluid retention; hypertriglyceridemia; dizziness; chloasma; angioedema; erythema nodosum; erythema multiforme; vulvovaginal candidiasis; and gastrointestinal symptoms.125

##### Information About COCs From Large Datasets

More than a hundred publications about harms (and preventive effects) of COCs are available and full review was beyond the scope of this review. The systematic reviews featured below include contemporary pills formulations and their harms.

##### Information About COCs From Systematic Reviews

Two recent systematic reviews have identified significant increased risk of deep venous thrombosis among users of oral contraceptives, though the size of risk varied significantly among different COC regimens and appeared lowest for agents containing levonorgestrel or norgestimate.129,130 One Cochrane review has evaluated the potential association between COC use and weight gain, finding insufficient evidence to make conclusions and noting the likelihood that there is no large association between COCs and increased weight during therapy.131 Other Cochrane reviews have assessed the relative efficacy and safety of various oral contraceptive regimens; these reviews note variability in the type and incidence of adverse events among included studies and comment that adverse event reporting among these studies was generally of lower quality than expected, recommending better tracking of side effects in future studies as well as systematic capture of patient reasons for treatment discontinuation.132-135 One of these reviews found that the incidence of discontinuation due to side effects was lower in triphasic-treated patients as compared with their monophasic-treated counterparts.134 The one Cochrane review assessing the use of COCs in the setting of heavy menstrual bleeding identified only one small crossover trial, which did not include description of adverse events.36

#### Harms Related to Cabergoline

##### Information About Cabergoline From Included Trials

A single exploratory study, with 29 participants among whom 14 had PCOS and 15 were normal controls, randomly assigned 16 women to cabergoline and 13 to placebo for 4 months.55 The authors did not report adverse events and all women completed the trial.

##### Information About Cabergoline From Package Insert

The package insert for this drug intended to treat elevated prolactin levels provides data about the risk of side effects in comparison to placebo in a 4-week study and compared with bromocriptine which is another medication for prolactinoma treatment.136 In Table 21 we summarize the incidence of cabergoline side effects that occurred in more than 5 percent of those on the drug, as well as 4 week experience of side effects among individuals on placebo. We did not identify large dataset analyses aimed at surveillance for harms.

Table 21 Side effects reported in cabergoline trials

Side Effect (% participants experiencing) | Placebo at 4 Weeks | Cabergoline at 4 Weeks | Cabergoline at 8 weeks
Nausea | 20 | 27 | 29
Headache | 25 | 26 | 26
Dizziness | 5 | 15 | 17
Asthenia | 10 | 9 | 6
Constipation | 0 | 10 | 7
Abdominal pain | 5 | 5 | 5
Somnolence | 5 | 5 | 2
Fatigue | 0 | 7 | 5
Depression | 5 | 3 | 3
Hot flashes | 5 | 1 | 3
Dyspepsia | 0 | 2 | 5

##### Information About Cabergoline From Large Datasets

One harms surveillance study using the U.S. Adverse Event Reporting System Database 137and two analyses done with data from the UK General Practice Research Database 138,139 have linked drugs typically used to treat Parkinson's disease, including cabergoline, to risk of harms. Comparing cabergoline, an ergot derived drug, to nonergot derived drugs, or no medication, these descriptive studies report new cardiac valve regurgitation occurred almost 5 times more often among those receiving cabergoline in the UK case control study137 and more than 100-fold more often in the United States adverse events registry.137 The latter publication followed the former which may have raised awareness and amplified reporting. The research team using United States data also reported increased odds of other forms of noncardiac fibrotic reaction in the pleura, retroperitoneal spaces, and lungs. Most recently, cabergoline in the UK database was link with doubling of heart failure risk.139 Notably these populations are substantially older and highly likely to have a specific comorbidity (Parkinson's) which may also modify risk and which makes estimation of risk in other groups infeasible. No direct surveillance data is available to inform estimation of risk in reproductive-age women.

##### Information About Cabergoline From Systematic Reviews

Several systematic reviews have explored the safety and efficacy of cabergoline for treatment of a range of conditions. Two Cochrane reviews on ovarian hyperstimulation syndrome and restless leg syndrome, respectively, each assessed a small pool of available trials, finding no significant difference in overall incidence of adverse events between cabergoline and comparators.140,141 A meta-analysis of dopamine receptor agonist use among individuals with Parkinson's disease found a relative risk of 6.38 (95% CI, 3.17 to 12.81) for moderate to severe valvular regurgitation142; a similar analysis of cabergoline use in hyperprolactinemia also found a significant increase in risk of valve regurgitation, though this echocardiographic finding in this patient population was clinically asymptomatic in all patients and participants were certain to be older and more frail than women who would use the treatment for irregular uterine bleeding.143

#### Harms Related to Lifestyle and Behavioral Interventions

##### Information Across Sources for Diet and Exercise

The single RCT of diet and exercise intervention was conducted in teens with irregular menses and did not identify adverse effects.56 One acupuncture trial included 34 women randomized to a walking regimen who reported no adverse events or injuries.57 However it is important not to assume that lifestyle and behavioral interventions such as diet and exercise are without risks. The U.S. Preventive Services Task Force report on Screening and Management of Obesity in Adults101 provides a clear and succinct description of the potential harms stating:

Possible harms that could accrue from [these] interventions include bone loss and increased fracture risk, injuries from increased physical activity, decreased self-esteem from being labeled as obese or failure to lose weight, use of extreme or unhealthy dietary approaches, and weight cycling.101

#### Harms Related to Acupuncture

##### Information Across Sources for Acupuncture

One study of acupuncture, that compared two strategies for selecting placemen of needles, did not discuss harms or withdrawals.58 The other RCT reports only local redness or hematomas occurring in 10 percent of those receiving acupuncture in 14 sessions over 16 weeks.57 Two of 33 women in the acupuncture group reported other side effects which were dizziness and nausea, while the exercise and no intervention control group did not report any events.

A number of Cochrane reviews have explored the use of acupuncture for treatment of a variety of women's health issues, ranging from dysmenorrhea to endometriosis-related pain to induction of labor; across the board, these reviews found that potential harms of acupuncture have not been well studied and are often omitted from trial reports completely, noting that investigation of possible adverse effects is an important consideration for future research involving this therapeutic approach.144-147

#### Harms Related to LNG-IUS

##### Information About LNG-IUS From Included Trials

One trial did not provide any information about harms or adverse effects.59 Two trials stated that there were no serious adverse effects related to either treatment.64,65 In one trial with 39 participants, one participant discontinued LNG-IUS therapy (5%) and five participants discontinued cyclic COC (26%).61 One trial reported side effects in a table without comparative statistics.63

One trial (n=165) reported that no deaths or drug-related serious adverse events occurred during the study.60 Six participants in the LNG-IUS group (7%) and two in the oral MPA group (2%) discontinued treatment because of adverse events.60 The LNG-IUS was expelled in four participants (5%); two other participants had the LNG-IUS removed due to adverse effects.60 No uterine perforations or pregnancies were observed during the study.60 Other treatment-emergent adverse events reported during the study and occurring in at least 5 percent of women in any treatment group were reported in a table without comparative statistics.

One trial reported 242 adverse events among 51 participants, with 158 in the LNG-IUS group and 84 in the mefenamic acid group.63 The LNG-IUS was expelled in two participants (8%); one of these had chlamydial endometritis.63

##### Information About LNG-IUS From FDA Documents and Package Insert

In October 2009, the prescription label for the LNG-IUS available in the United States was updated though a process with the FDA.148 This revision was made for the new indication: treatment of heavy menstrual bleeding for women who choose to use intrauterine contraception as their method of contraception.149

According to the package insert, the most common (i.e., more than 10 percent) adverse reactions reported in clinical trials of LNG-IUS are: uterine/vaginal bleeding alterations (51.9%), amenorrhea (23.9%), intermenstrual bleeding and spotting (23.4%), abdominal /pelvic pain (12.8%), and ovarian cysts (12%).148 The data provided reflect the experience with the use of Mirena brand LNG-IUS in the adequate and well-controlled studies for contraception (n=2,339) and heavy menstrual bleeding (n=80). For the treatment of heavy menstrual bleeding indication (n=80), the subjects included women aged 26 to 50 with confirmed heavy bleeding and exposed for a median of 183 treatment days of Mirena (range, 7 to 295 days).

The adverse reactions seen across the two indications overlapped, and are reported using the frequencies from the contraception studies. The less common (i.e., between 5% and 9% of users) adverse reactions are: headache/migraine (7.7%), acne (7.2%), depressed/altered mood (6.4%), menorrhagia (6.3%), breast tenderness/pain (4.9%), vaginal discharge (4.9%), and IUD expulsion (4.9%). Other relevant adverse reactions occurring in fewer than 5 percent of subjects include nausea, nervousness, vulvovaginitis, dysmenorrhea, back pain, weight increase, decreased libido, cervicitis/Papanicolaou smear normal/class II, hypertension, dyspareunia, anemia, alopecia, skin disorders including eczema, pruritus, rash and urticaria, abdominal distention, hirsutism, and edema.148,150

##### Information About the LNG-IUS From Large Datasets

Large scale surveillance for harms provides important information to patients to assure informed decisions about risks. This data includes information about complications with insertion. In the New Zealand monitoring system which includes 3,519 insertions, difficult insertions occurred in 3.6 percent of procedures and were not well predicted by nulliparous status of noncontraceptive use of the IUD. Pain on insertion occurred for 1 percent of patients and 0.5 percent of attempts to insert could not be completed.151,152 Uterine perforation rates in three large datasets ranged from 0.9 to 2.6 cases per 1,000.^151,153,154^ Authors of each of these studies, as well as those of another report from four national pharmacovigilance centers in Europe confirm, that perforations may not consistently be associated with painful insertions and that only a small portion (less than 10%) are recognized at the time of the insertion.155

In surveillance data, the LNG-IUS in not associated with increased risk of deep vein thrombosis,117 including in more than 8 million women-years of observation among Danish women.156 The anecdotally reported complaint of hair loss is supported by a single study in New Zealand by surveying women in the national registry. They found five cases of alopecia (two recovered, one not, and two still unknown) and estimated incidence to be 1.8 per 1,000 users.153

A 2012 publication about hormonal contraceptive methods and risk of thrombotic stroke and myocardial infarction, estimated risk based on person-years of exposure to specific contraceptive methods in a cohort of 15 years duration.121 In a total of 184,875 women-years of observation, the LNG-IUS was not statistically significantly associated with increased risk of myocardial infarction, and appeared, relative to women not using hormonal methods, to offer protection from stroke (RR=0.73; 95% CI, 0.54 to 0.98).

##### Information About the LNG-IUS From Systematic Reviews

Systematic reviews report adverse events similar to those noted in the package insert,148 with weight gain, bloating, acne, nausea and breast pain as the most commonly observed side effects. These systematic reviews also comment on the risk of spontaneous device expulsion, reporting an incidence of 5 to 16 percent.157-159

#### Harms Related to Contraceptive Vaginal Ring

##### Information About Contraceptive Vaginal Ring From Included Trials

The vaginal ring was used in a single study in this review as a treatment for heavy menstrual bleeding and was found to be similar in effectiveness to oral norethisterone.84 The contraceptive vaginal ring provides a steady release of 15 mcg of ethinyl estradiol and 120 mcg of etonogestrel daily and is used vaginally for 3 weeks per cycle and then removed for 1 week. Following three cycles of treatment, this study reported that the incidence of nausea, headache, and breast tenderness was comparable in both treatment groups. The contraceptive vaginal ring users were less likely to report breakthrough bleeding than the women taking norethisterone. No ring expulsions were reported. Local events, including vaginal discomfort, vaginitis, foreign body sensation and coital problems were reported more frequently in ring-users, but no one discontinued treatment due to adverse events.

##### Information About Contraceptive Vaginal Ring From FDA Documents and Package Insert

The package insert lists the most common harms reported by 5 to 14 percent of women in clinical trials including vaginitis, headache, upper respiratory infection, vaginal secretion, sinusitis, nausea, and weight gain.160 The adverse events leading to discontinuation of treatment in 1 to 2.5 percent of women include device-related events (e.g., foreign body sensation, coital problems, and expulsion), vaginal symptoms, headache, emotional lability, and weight gain. The package insert also warns against use of the vaginal contraceptive ring in cigarette-smokers over age 35.

##### Information About Contraceptive Vaginal Ring From Large Data Sets

We identified three studies reporting data on harms from large studies of contraceptive vaginal ring users.121,161,162 A 15-year Danish cohort study that included over 38,000 person-years of vaginal ring use reported an elevated adjusted relative risk of 2.5 (95% CI, 1.4 to 4.4) for thrombotic stroke and 2.1 (95% CI, 0.7 to 6.5) for myocardial infarction compared with women (over 9 million person-years) who had not used hormonal contraception.121 In an observational study of over 2,500 Swiss women, 20 percent (n=539) of contraceptive vaginal ring users reported 753 adverse events. The most common harms were changes in menstrual bleeding pattern (2.3%), vaginal discomfort (2.2%), leucorrhea (2.1%), mood disorders (2.0%) and headache (1.9%).161 This profile is similar to data from a German open label study of the acceptability of the contraceptive vaginal ring in which 431 of 5,823 (7.4%) of women discontinued use for side effects over six cycles of use. In the full cohort, 9.9% of women experienced symptoms classified as adverse events with the most common being bleeding pattern, headache (including migraine),and acne.162 The research team reports 19 women (<0.3%) has serious adverse events each of which was an isolated event, other than dizziness which was reported by two women.

##### Information About Contraceptive Vaginal Ring From Systematic Reviews

A recently published review of the contraceptive vaginal ring summarized adverse events from three large trials.163 The number of women using the contraceptive vaginal ring in these three studies ranged from 499 to 2,322. Over one half of the women (58 to 66%) reported at least one adverse event and 29 to 38 percent of these were possibly related to the contraceptive. The most frequent complaints were headache (5.8 to 7.2%), ring-related (4.4 to 6.8%), vaginitis (3.9 to 5.6%), leucorrhea (3.2 to 4.8%), and nausea (0.8 to 3.2%). Between 11 and 14 percent of women discontinued use of the contraceptive vaginal ring due to adverse events. Two women in one study had deep vein thrombosis. Hypertension was reported in four women (0.8%) in a single study. A study that investigated the effects of the device on lipid profiles reported increases in triglycerides and sex hormone binding globulin levels but total cholesterol was unchanged.

Another systematic review of COCs and bone health included one small cohort study of contraceptive vaginal ring users, noting no change in bone mineral density from baseline for the vaginal ring users compared with an increase in bone density among the control group of nonhormone users.164 A recently published systematic review examining thrombotic risks of oral contraceptives included data from studies of the contraceptive vaginal ring.165 The risk of venous thromboembolism for the contraceptive vaginal ring was elevated and similar to COCs containing ethinyl estradiol and gestodene (5.6-fold increase) or desogestrel (7.3-fold increase) or ethinyl estradiol and drospirenone (6.3-fold increase).165

#### Harms Related to NSAIDs

##### Information About NSAIDs From Included Trials

Three trials did not provide any information about harms or adverse effects.68,73,74 Two trials reported there were no serious side effects.75,77 Another trial reported treatment discontinuation among one person receiving mefenamic acid and one person receiving norethisterone after the third cycle.70 A table of adverse events was presented in this study with no comparative statistics, though abdominal pain was reported in 18 percent and 20 percent of both mefenamic acid and norethisterone groups.

In one trial,63 there were 242 adverse events noted with 158 in the LNG-IUS group and 84 in the mefenamic acid group. There were two significant adverse events in this study, one with hypertension in a patient with a history of hypertension, and one with chlamydia endometriosis resulting in LNG-IUS expulsion. Of note, a smaller proportion of patients reported abdominal pain with mefenamic acid (7.7%) compared with LNG-IUS (32.0%), though significance was not reported in the table of adverse events.

In another trial,66 a total of 18 patients stopped treatment including three of 23 taking mefenamic acid due to poor efficacy or an unwanted event such as nausea, headache, and dizziness.

One trial77 reported nausea and gastrointestinal disturbances in nine (16.4%) and eight (14.5%) and leg cramps in seven (12.7%) and 12 (21.8%) cases among those receiving TXA and TXA with mefenamic acid, respectively.

One small crossover trial reported no treatment discontinuations,71 however, patients receiving TXA reported nausea, dizziness, numbness, restless legs, and headache. Vomiting and difficulty swallowing was reported by three women in the TXA group. Patients receiving flurbiprofen reported tiredness, stomach pains, and nausea.

In one trial,67 one person discontinued mefenamic acid due to severe skin rash and itching and in another trial,69 one person on mefenamic acid complained of gastritis. In another trial,72 one patient had epigastric distress and four patients had nausea and vomiting on meclofenamate. However, the severity of dysmenorrhea (p<0.006), backache (p<0.02), and headache (p<0.002) were significantly less for patients taking meclofenamate than placebo. There was no difference in nausea or vomiting.

One trial75 reported any side effects in 18 patients taking naproxen and in 15 patients taking mefenamic acid. Thirteen patients taking naproxen experienced gastrointestinal symptoms (i.e., nausea, diarrhea, abdominal discomfort, and anorexia) compared with six taking mefenamic acid. Central nervous system symptoms (i.e., light headedness, dizziness, tiredness, and headache) were reported by patients receiving mefenamic acid (n=6) and naproxen (n=5).

One trial76 reported no significant differences in nausea, depression, breast symptoms, and other symptoms between mefenamic acid and placebo. However there was significant reductions in abdominal pain (p<0.001), headache (p<0.001), and diarrhea (p<0.008) among those taking mefenamic acid compared with placebo.

##### Information About NSAIDs From FDA Documents and Package Inserts

As a class, NSAIDs carry a risk of serious harms from cardiovascular thrombotic events, myocardial infarction, stroke, renal effects, and hepatic effects, along with gastrointestinal ulceration, bleeding and perforation. All drugs in this class have a boxed warning for cardiovascular and gastrointestinal risk. Upper gastrointestinal ulcers, gross bleeding, or perforation caused by NSAIDs occur in approximately 1 percent of patients treated for 3 to 6 months, and in about 2 to 4 percent of patients treated for 1 year, with trends continuing with longer duration of continuous use.166-168 Labels note that even short-term therapy is not without risk with this drug class.

In general, NSAIDs have been commonly associated with harms including edema, abdominal pain, constipation, diarrhea, dyspepsia/heartburn, elevated liver enzymes, flatulence, gastrointestinal bleeding, nausea, vomiting, body weight changes, headache, nervousness and other manifestations of central nervous system stimulation (e.g., anxiety, insomnia, increased reflexes, tremor), symptoms associated with central nervous system inhibition (e.g., amnesia, asthenia, depression, malaise, somnolence), rash, changes in vision, dizziness/vertigo, tinnitus, and signs and symptoms suggesting urinary tract infection.

More harms information on specific drugs is limited in the package inserts, for many of the reasons given in the above discussion. In controlled studies of meclofenamate, approximately 4 percent of the patients had diarrhea severe enough to require discontinuation of the drug.167 See Appendix M for more complete information from individual package inserts.

##### Information About NSAIDs From Systematic Reviews

A pooled analysis of trials in a systematic review of NSAIDs for the treatment of dysmenorrhea found that mild neurological and gastrointestinal adverse events reported at significantly greater frequency by those receiving NSAIDs as compared with those receiving placebo.169 Another recent review underscores the risk of various gastrointestinal complaints and notes that the cardiovascular effects of the traditional NSAIDs are poorly understood and warrant further research;103 an increased risk of nonfatal myocardial infarction was also observed in a recent systematic review and meta-analysis.170

#### Harms Related to TXA

##### Information About TXA From Included Trials

Within studies included in our review, similar numbers of participants withdrew from TXA and placebo or other treatment groups.78,79 No thrombotic events were reported in the participants treated with TXA and no deaths occurred during the study. Serious adverse events reported in the TXA groups of trials included allergic reactions, headaches, and other symptoms such as tachycardia, acute bronchitis, hypoglycemia, and posttraumatic stress disorder, the latter judged to be unrelated to study treatment. There was no significant difference in the percentage of side effects reported, comparing TXA to placebo. In particular, the frequency of gastrointestinal-related adverse events was similar between groups. In another trial,66 a total of 18 patients stopped treatment including four of 26 taking TXA due to poor efficacy or an unwanted event such as nausea, headache, and dizziness. One included trial had no withdrawals or side effects reported,71 another reported no serious adverse effects.80

##### Information about TXA from FDA Documents and Package Insert

The companies, Xanodyne Pharmaceuticals and Ferring Pharmaceuticals, that manufacture TXA (Lysteda^®^) received FDA approval after submitting research findings and other data in 2009. The manufacturer conducted two placebo-controlled randomized trials; the second of which has been published.78 The first trial randomized 304 women and compared two doses of TXA (1,950 mg and 3,900 mg daily for up to 5 days during each menstrual period) versus placebo over three cycles.171 The data provided to the FDA for safety included these two pragmatic cluster RCTs and two uncontrolled phase three trials, and a single QT-interval phase two study. In total, these five studies described 12,169 treatment cycles, but among them only 234 women received the current recommended therapeutic dose of the medication.172 Overall, the nature and number of adverse events did not raise any significant safety concerns. There were no venous thromboembolic events in subjects taking TXA. There were no adverse effects on vision or ocular safety concerns. There was no effect on the QT-interval. No drug-drug interactions studies were conducted. The total number of subjects in clinical trials who received TXA was considered low for evaluation of harms and drug safety.

The FDA also reviewed evidence from a database for a different formulation of TXA that included 40 cases of possible venous thromboembolism over 5 years (none in the United States), with 40 percent of these events occurring with intravenous use of the drug, and for indications other than heavy menstrual bleeding.171 The review utilized by the FDA also documented associated instances of retinal venous and arterial occlusion and ligneous conjunctivitis.171

In April 2011, the prescription label and package insert for the formulation of TXA available in the United States was updated.171 According to the current label, the most common adverse reactions reported in clinical trials of TXA were headache (50.4%), nasal and sinus symptoms (25.4%), back pain (20.7%), abdominal pain (19.8%), musculoskeletal pain (11.2%), arthralgia (6.9%), muscle cramps and spasms (6.5%), migraine (6%), anemia (5.6%), and fatigue (5.2%); comparative statistics between active drug and placebo were not provided.171

##### Information About TXA From Large Data Sets

We identified a single large surveillance study using the General Practice Database from the United Kingdom.122 The case-control analysis of deep vein thrombosis reported increased odds of TXA use among cases (OR=3.20; 95% CI, 0.65 to 15.78) and note lack of precision of the estimates based on sparse use of the medication. This report, examining drugs used for heavy menstrual bleeding, found that all common treatments for menorrhagia were associated with deep vein thrombosis risk and raised the question of confounding by indication, meaning that characteristics of the women being treated (abnormal bleeding patterns) rather than the drugs themselves might be the causal component.122

Based on United States and worldwide postmarketing reports, the following have been reported in patients receiving TXA for various indications: nausea, vomiting, and diarrhea; allergic skin reactions; anaphylactic shock and anaphylactoid reactions; impaired color vision and other visual disturbances; dizziness; and thromboembolic events (e.g., deep vein thrombosis, pulmonary embolism, cerebral thrombosis, acute renal cortical necrosis, and central retinal artery and vein obstruction).171 There postmarketing reports of venous and arterial thrombotic events included women who had used TXA concomitantly with combined hormonal contraceptives.

In consideration of the information reviewed, the FDA issued contra-indications and precautions for TXA use, advising clinicians not to prescribe TXA to women known to have the following conditions: active thromboembolic disease (e.g., deep vein thrombosis, pulmonary embolism, or cerebral thrombosis); a history of thrombosis or thromboembolism, including retinal vein or artery occlusion; an intrinsic risk of thrombosis or thromboembolism (e.g., thrombogenic valvular disease, thrombogenic cardiac rhythm disease, or hypercoagulopathy). Four precautions are noted: (1) concomitant therapy with tissue plasminogen activators may decrease the efficacy of both medications; (2) the risk of venous thromboembolism and arterial thromboses may increase further when hormonal contraceptives are administered with TXA, of particular concern in women who are obese or smoke cigarettes, especially smokers over 35 years of age; (3) TXA is not recommended for women taking either Factor IX complex concentrates or anti-inhibitor coagulant concentrates because the risk of thrombosis may be increased; (4) patients should be instructed to report visual and ocular symptoms promptly and the medication should be stopped pending a complete ophthalmic evaluation, including dilated retinal examination, to exclude the possibility of retinal venous or arterial occlusion.171

##### Information About TXA From Systematic Reviews

A 2012 review of the efficacy of TXA in treating heavy menstrual bleeding is compatible with this review, finding mild to moderate adverse effects reported in included studies.173 Gastrointestinal effects were most common, and there were no reports of thromboembolic events in the 10 studies evaluated.173 A Cochrane review conducted a combined analysis of the efficacy and safety of TXA and ethamsylate as antifibrinolytics used to treat heavy menstrual bleeding; emphasizing the short duration of the included studies, they comment that no increase in adverse events was observed with use of these agents.174 Two systematic reviews of TXA use in orthopedic surgery recently found no increased risk of thrombotic events in their pooled data analyses.175,176 It is important to note that the trials included in these reviews are similar to those in this review in that they are underpowered to detect rare but important harms.

#### Harms Related to Decision Aids

There are no harms associated with using decision aids other than time invested by patient and clinician if the decision aid does not effectively inform patients about important care options.

### Summary

Pharmaceutical agents, procedures and devices, and even diet and exercise have potential complications. While contraceptive methods have typically been well-characterized in the broadly applicable population of reproductive-age women, there may be characteristics associated with abnormal bleeding that modify the risk profile of these interventions when restricted to women with indications related to AUB. Women and their care providers will need to weigh individual risk profiles, desire for contraception, and treatment strategies in order to balance symptom management with minimization of risk, especially when choosing medications that are less well-studied in this population, such as those used for diabetes management.