# References

1 Liu Z, Doan QV, Blumenthal P, et al. A systematic review evaluating health-related quality of life, work impairment, and health-care costs and utilization in abnormal uterine bleeding. Value Health. May-Jun. 2007;10(3):183-94. [pmid: 17532811].
2 Marret H, Fauconnier A, Chabbert-Buffet N, et al. Clinical practice guidelines on menorrhagia: management of abnormal uterine bleeding before menopause. Eur J Obstet Gynecol Reprod Bio. Oct. 2010;152(2):133-7. [pmid: 20688424].
3 Albers JR, Hull SK, Wesley RM. Abnormal uterine bleeding. Am Fam Physician. Apr. 15. 2004;69(8):1915-26. [pmid: 15117012].
4 Fritz MA, Speroff L. Clinical gynecologic endocrinology and infertility. 8th ed. Philadelphia. Wolters Kluwer Health/Lippincott Williams & Wilkins. 2011.
5 Hallberg L, Hogdahl AM, Nilsson L, et al. Menstrual blood loss—a population study. Variation at different ages and attempts to define normality. Acta Obstet Gynecol Scand. 1966;45(3):320-51. [pmid: 5922481].
6 Treloar AE, Boynton RE, Behn BG, et al. Variation of the human menstrual cycle through reproductive life. Int J Fertil. Jan-Mar. 1967;12(1 Pt 2):77-126. [pmid: 5419031].
7 Belsey EM, Pinol AP. Menstrual bleeding patterns in untreated women. Task Force on Long-Acting Systemic Agents for Fertility Regulation. Contraception. Feb. 1997;55(2):57-65. [pmid: 9071513].
8 Matteson KA, Clark MA. Questioning our questions: do frequently asked questions adequately cover the aspects of women's lives most affected by abnormal uterine bleeding? Opinions of women with abnormal uterine bleeding participating in focus group discussions. Women Health. Mar. 2010;50(2):195-211. [pmid: 20437305].
9 Munro MG, Critchley HO, Broder MS, et al., FIGO Working Group on Menstrual Disorders. FIGO classification system (PALM-COEIN) for causes of abnormal uterine bleeding in nongravid women of reproductive age. Int J Gynaecol Obstet. Apr. 2011;113(1):3-13. [pmid: 21345435].
10 Bradley LD. Diagnosis of abnormal uterine bleeding with biopsy or hysteroscopy. Menopause. Apr. 2011;18(4):425-33. [pmid: 21701428].
11 Doubilet PM. Diagnosis of abnormal uterine bleeding with imaging. Menopause. Apr. 2011;18(4):421-4. [pmid: 21701427].
12 Woolcock JG, Critchley HO, Munro MG, et al. Review of the confusion in current and historical terminology and definitions for disturbances of menstrual bleeding. Fertil Steril. 2008;90(6):2269-80. [pmid: 18258230].
13 Rahn DD, Abed H, Sung VW, et al., Society of Gynecologic Surgeons Systematic Review Group. Systematic review highlights difficulty interpreting diverse clinical outcomes in abnormal uterine bleeding trials. J Clin Epidemiol. Mar. 2011;64(3):293-300. [pmid: 20705427].
14 Fraser IS, Critchley HO, Munro MG, et al. A process designed to lead to international agreement on terminologies and definitions used to describe abnormalities of menstrual bleeding. Fertil Steril. Mar. 2007;87(3):466-76. [pmid: 17362717].
15 Fraser IS, Critchley HO, Munro MG, et al. Can we achieve international agreement on terminologies and definitions used to describe abnormalities of menstrual bleeding?. Hum Reprod. Mar. 2007;22(3):635-43. [pmid: 17204526].
16 Munro MG, Critchley HO, Fraser IS, FIGO Working Group on Menstrual Disorders. The FIGO classification of causes of abnormal uterine bleeding. Int J Gynaecol Obstet. Apr. 2011;113(1):1-2. [pmid: 21316671].
17 Hale GE, Zhao X, Hughes CL, et al. Endocrine Features of Menstrual Cycles in Middle and Late Reproductive Age and the Menopausal Transition Classified According to the Staging of Reproductive Aging Workshop (STRAW) Staging System. J Clin Endocrinol Metab. August. 1. 2007. 2007;92(8):3060-7. [pmid: 17550960].
18 Heller DS. Pathologic basis for abnormal uterine bleeding with organic uterine pathologies. Menopause. Apr. 2011;18(4):412-5. [pmid: 21701425].
19 ACOG Committee on Practice Bulletins—Gynecology. ACOG Practice Bulletin No. 14: management of anovulatory bleeding. Int J Gynaecol Obstet. Mar. 2001;72(3):263-71. [pmid: 11296797].
20 ACOG Committee on Practice Bulletins—Gynecology. ACOG Practice Bulletin No. 59: clinical management guidelines for obstetricians-gynecologists: intrauterine device. Obstet Gynecol. Jan. 2005;105(1):223-32. [pmid: 15625179].
21 ACOG Committee on Practice Bulletins—Gynecology. ACOG Practice Bulletin No. 110: noncontraceptive uses of hormonal contraceptives. Obstet Gynecol. Jan. 2010;115(1):206-18. [pmid: 20027071].
22 ACOG Committee on Practice Bulletins—Gynecology. ACOG Practice Bulletin No. 121: long-acting reversible contraception: implants and intrauterine devices. Obstet Gynecol. Jul. 2011;118(1):184-96. [pmid: 21691183].
23 Ely JW, Kennedy CM, Clark EC, et al. Abnormal uterine bleeding: a management algorithm. J Am Board Fam Med. Nov-Dec. 2006;19(6):590-602. [pmid: 17090792].
24 National Collaborating Centre for Women's and Children's Health. Heavy Menstrual Bleeding. NICE Clinical Guideline CG44. London. Institute for Health and Clinical Excellence. 2007.
25 Matteson KA, Anderson BL, Pinto SB, et al. Practice patterns and attitudes about treating abnormal uterine bleeding: a national survey of obstetricians and gynecologists. Am J Obstet Gynecol. 2011. May. 14. [pmid: 21737060].
26 Jensen JT, Lefebvre P, Laliberte F, et al. Cost Burden and Treatment Patterns Associated with Management of Heavy Menstrual Bleeding. J Womens Health (Larchmt). 2012. Feb. 23. [pmid: 22360696].
27 Samuel NC, Justin Clark T. Future research into abnormal uterine bleeding. Best Pract Res Clin Obstet Gynaecol. 2007;21(6):1023-40. [pmid: 17584533].
28 Espey E, Ogburn T. Long-acting reversible contraceptives: intrauterine devices and the contraceptive implant. Obstet Gynecol. Mar. 2011;117(3):705-19. [pmid: 21343774].
29 Endrikat J, Vilos G, Muysers C, et al. The levonorgestrel-releasing intrauterine system provides a reliable, long-term treatment option for women with idiopathic menorrhagia. Arch Gynecol Obstet. 2011. Apr. 8. [pmid: 21475963].
30 Mosher WD, Jones J. Use of contraception in the United States: 1982-2008. Vital Health Stat 23. Aug. 2010;(29):1-44. [pmid: 20939159].
31 Xu X, Macaluso M, Ouyang L, et al. Revival of the intrauterine device: increased insertions among US women with employer-sponsored insurance, 2002-2008. Contraception. Feb. 2012;85(2):155-9. [pmid: 22067778].
32 Smith SK, Abel MH, Kelly RW, et al. Prostaglandin synthesis in the endometrium of women with ovular dysfunctional uterine bleeding. Br J Obstet Gynaecol. Apr. 1981;88(4):434-42. [pmid: 7225303].
33 Pinkerton JV. Pharmacological therapy for abnormal uterine bleeding. Menopause. Apr. 2011;18(4):453-61. [pmid: 21701432].
34 Lethaby A, Augood C, Duckitt K, et al. Nonsteroidal anti-inflammatory drugs for heavy menstrual bleeding. Cochrane Database Syst Rev. 2007;(4):CD000400. [pmid: 17943741].
35 Lumsden MA, Wedisinghe L. Tranexamic acid therapy for heavy menstrual bleeding. Expert Opin Pharmacother. Sep. 2011;12(13):2089-95. [pmid: 21767224].
36 Farquhar C, Brown J. Oral contraceptive pill for heavy menstrual bleeding. Cochrane Database Syst Rev. 2009;(4):CD000154. [pmid: 19821266].
37 Telner DE, Jakubovicz D. Approach to diagnosis and management of abnormal uterine bleeding. Can Fam Physician. Jan. 2007;53(1):58-64. [pmid: 17872610].
38 Kiley J, Hammond C. Combined oral contraceptives: a comprehensive review. Clin Obstet Gynecol. Dec. 2007;50(4):868-77. [pmid: 17982329].
39 Norman RJ, Noakes M, Wu R, et al. Improving reproductive performance in overweight/obese women with effective weight management. Hum Reprod Update. May-Jun. 2004;10(3):267-80. [pmid: 15140873].
40 Livdans-Forret AB, Harvey PJ, Larkin-Thier SM. Menorrhagia: a synopsis of management focusing on herbal and nutritional supplements, and chiropractic. J Can Chiropr Assoc. Dec. 2007;51(4):235-46. [pmid: 18060009].
41 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. www.effectivehealthcare.ahrq.gov.
42 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. J Clin Epidemiol. Oct. 2009;62(10):e1-34. [pmid: 19631507].
43 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
44 Avoiding bias in selecting studies. AHRQ Draft Manuscript: Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 23. 2011. www.effectivehealthcare.ahrq.gov.
45 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
46 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
47 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
48 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
49 Karakus S, Kiran G, Ciralik H. Efficacy of micronised vaginal progesterone versus oral dydrogestrone in the treatment of irregular dysfunctional uterine bleeding: a pilot randomised controlled trial. Aust N Z J Obstet Gynaecol. Dec. 2009;49(6):685-8. [pmid: 20070724].
50 Davis A, Godwin A, Lippman J, et al. Triphasic norgestimate-ethinyl estradiol for treating dysfunctional uterine bleeding. Obstet Gynecol. Dec. 2000;96(6):913-20. [pmid: 11084177].
51 Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. Feb. 2002;87(2):569-74. [pmid: 11836287].
52 Moghetti P, Castello R, Negri C, et al. Metformin effects on clinical features, endocrine and metabolic profiles, and insulin sensitivity in polycystic ovary syndrome: a randomized, double-blind, placebo-controlled 6-month trial, followed by open, long-term clinical evaluation. J Clin Endocrinol Metab. Jan. 2000;85(1):139-46. [pmid: 10634377].
53 Elkind-Hirsch K, Marrioneaux O, Bhushan M, et al. Comparison of single and combined treatment with exenatide and metformin on menstrual cyclicity in overweight women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2008;93(7):2670-8. [pmid: 18460557].
54 Oner G, Muderris II. Clinical, endocrine and metabolic effects of metformin vs N-acetyl-cysteine in women with polycystic ovary syndrome. Eur J Obstet Gynecol Reprod Biol. Nov. 2011;159(1):127-31. [pmid: 21831508].
55 Paoletti AM, Cagnacci A, Depan GF, et al. The chronic administration of cabergoline normalizes androgen secretion and improves menstrual cyclicity in women with polycystic ovary syndrome. Fertil Steril. 1996;66(4):527-32. [pmid: 8816612].
56 Ornstein RM, Copperman NM, Jacobson MS. Effect of weight loss on menstrual function in adolescents with polycystic ovary syndrome. J Pediatr Adolesc Gynecol. 2011;24(3):161-5. [pmid: 21419674].
57 Jedel E, Labrie F, Oden A, et al. Impact of electro-acupuncture and physical exercise on hyperandrogenism and oligo/amenorrhea in women with polycystic ovary syndrome: a randomized controlled trial. Am J Physiol Endocrinol Metab. Jan. 2011;300(1):E37-45. [pmid: 20943753].
58 Cai XM, Wu J. The mind-tranquilizing and menstruation-regulating method for acupuncture treatment of delayed menstrual cycle—a clinical controlled study. J Tradit Chin Med. Mar. 2009;29(1):35-8. [pmid: 19514186].
59 Shaaban MM, Zakherah MS, El-Nashar SA, et al. Levonorgestrel-releasing intrauterine system compared to low dose combined oral contraceptive pills for idiopathic menorrhagia: a randomized clinical trial. Contraception. Jan. 2011;83(1):48-54. [pmid: 21134503].
60 Kaunitz AM, Bissonnette F, Monteiro I, et al. Levonorgestrel-releasing intrauterine system or medroxyprogesterone for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Sep. 2010;116(3):625-32. [pmid: 20733445].
61 Endrikat J, Shapiro H, Lukkari-Lax E, et al. A Canadian, multicentre study comparing the efficacy of a levonorgestrel-releasing intrauterine system to an oral contraceptive in women with idiopathic menorrhagia. J Obstet Gynaecol Can. Apr. 2009;31(4):340-7. [pmid: 19497153].
62 Kucuk T, Ertan K. Continuous oral or intramuscular medroxyprogesterone acetate versus the levonorgestrel releasing intrauterine system in the treatment of perimenopausal menorrhagia: a randomized, prospective, controlled clinical trial in female smokers. Clin Exp Obstet Gynecol. 2008;35(1):57-60. [pmid: 18390083].
63 Reid PC, Virtanen-Kari S. Randomised comparative trial of the levonorgestrel intrauterine system and mefenamic acid for the treatment of idiopathic menorrhagia: a multiple analysis using total menstrual fluid loss, menstrual blood loss and pictorial blood loss assessment charts. BJOG. Aug. 2005;112(8):1121-5. [pmid: 16045528].
64 Irvine GA, Campbell-Brown MB, Lumsden MA, et al. Randomised comparative trial of the levonorgestrel intrauterine system and norethisterone for treatment of idiopathic menorrhagia. Br J Obstet Gynaecol. Jun. 1998;105(6):592-8. [pmid: 9647148].
65 Lahteenmaki P, Haukkamaa M, Puolakka J, et al. Open randomised study of use of levonorgestrel releasing intrauterine system as alternative to hysterectomy. BMJ. Apr. 11. 1998;316(7138):1122-6. [pmid: 9552948].
66 Bonnar J, Sheppard BL. Treatment of menorrhagia during menstruation: randomised controlled trial of ethamsylate, mefenamic acid, and tranexamic acid. BMJ. Sep. 7. 1996;313(7057):579-82. [pmid: 8806245].
67 van Eijkeren MA, Christiaens GC, Geuze HJ, et al. Effects of mefenamic acid on menstrual hemostasis in essential menorrhagia. Am J Obstet Gynecol. May. 1992;166(5):1419-28. [pmid: 1595797].
68 Fraser IS, McCarron G. Randomized trial of 2 hormonal and 2 prostaglandin-inhibiting agents in women with a complaint of menorrhagia. Aust N Z J Obstet Gynaecol. Feb. 1991;31(1):66-70. [pmid: 1872778].
69 Grover V, Usha R, Gupta U, et al. Management of cyclical menorrhagia with prostaglandin synthetase inhibitor. Asia Oceania J Obstet Gynaecol. Sep. 1990;16(3):255-9. [pmid: 2088249].
70 Cameron IT, Haining R, Lumsden MA, et al. The effects of mefenamic acid and norethisterone on measured menstrual blood loss. Obstet Gynecol. Jul. 1990;76(1):85-8. [pmid: 2359570].
71 Andersch B, Milsom I, Rybo G. An objective evaluation of flurbiprofen and tranexamic acid in the treatment of idiopathic menorrhagia. Acta Obstet Gynecol Scand. 1988;67(7):645-8. [pmid: 3073625].
72 Vargyas JM, Campeau JD, Mishell DR Jr. Treatment of menorrhagia with meclofenamate sodium. Am J Obstet Gynecol. Oct. 1987;157(4 Pt 1):944-50. [pmid: 3314521].
73 Tsang BK, Domingo MT, Spence JE, et al. Endometrial prostaglandins and menorrhagia: influence of a prostaglandin synthetase inhibitor in vivo. Can J Physiol Pharmacol. Oct. 1987;65(10):2081-4. [pmid: 3123043].
74 Cameron IT, Leask R, Kelly RW, et al. The effects of danazol, mefenamic acid, norethisterone and a progesterone-impregnated coil on endometrial prostaglandin concentrations in women with menorrhagia. Prostaglandins. Jul. 1987;34(1):99-110. [pmid: 3685399].
75 Hall P, Maclachlan N, Thorn N, et al. Control of menorrhagia by the cyclo-oxygenase inhibitors naproxen sodium and mefenamic acid. Br J Obstet Gynaecol. Jun. 1987;94(6):554-8. [pmid: 3304401].
76 Fraser IS, Pearse C, Shearman RP, et al. Efficacy of mefenamic acid in patients with a complaint of menorrhagia. Obstet Gynecol. Nov. 1981;58(5):543-51. [pmid: 7029369].
77 Najam R, Agarwal D, Tyagi R, et al. Comparison of traneximic acid with a combination of traneximic acid and mefenamic acid in reducing menstrual blood loss in ovulatory dysfunctional uterine bleeding (DUB). Journal of Clinical and Diagnostic Research. 2010;4(5):3020-5.
78 Lukes AS, Moore KA, Muse KN, et al. Tranexamic acid treatment for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Oct. 2010;116(4):865-75. [pmid: 20859150].
79 Kriplani A, Kulshrestha V, Agarwal N, et al. Role of tranexamic acid in management of dysfunctional uterine bleeding in comparison with medroxyprogesterone acetate. J Obstet Gynaecol. Oct. 2006;26(7):673-8. [pmid: 17071438].
80 Preston JT, Cameron IT, Adams EJ, et al. Comparative study of tranexamic acid and norethisterone in the treatment of ovulatory menorrhagia. Br J Obstet Gynaecol. May. 1995;102(5):401-6. [pmid: 7612535].
81 Freeman EW, Lukes A, VanDrie D, et al. A dose-response study of a novel, oral tranexamic formulation for heavy menstrual bleeding. Am J Obstet Gynecol. Oct. 2011;205(4):319 e1-7. [pmid: 21777897].
82 Fraser IS, Romer T, Parke S, et al. Effective treatment of heavy and/or prolonged menstrual bleeding with an oral contraceptive containing estradiol valerate and dienogest: A randomized, double-blind Phase III trial. Human Reproduction. 2011;26(10):2698-708. [pmid: 21784734].
83 Jensen JT, Parke S, Mellinger U, et al. Effective treatment of heavy menstrual bleeding with estradiol valerate and dienogest: A randomized controlled trial. Obstetrics and Gynecology. 2011;117(4):777-87. [pmid: 21422847].
84 Abu Hashim H, Alsherbini W, Bazeed M. Contraceptive vaginal ring treatment of heavy menstrual bleeding: a randomized controlled trial with norethisterone. Contraception. Mar. 2012;85(3):246-52. [pmid: 22067765].
85 Vuorma S, Rissanen P, Aalto AM, et al. Impact of patient information booklet on treatment decision—a randomized trial among women with heavy menstruation. Health Expect. Dec. 2003;6(4):290-7. [pmid: 15040791].
86 Kennedy AD, Sculpher MJ, Coulter A, et al. Effects of decision aids for menorrhagia on treatment choices, health outcomes, and costs: a randomized controlled trial. JAMA. Dec. 4. 2002;288(21):2701-8. [pmid: 12460093].
87 Protheroe J, Bower P, Chew-Graham C, et al. Effectiveness of a computerized decision aid in primary care on decision making and quality of life in menorrhagia: results of the MENTIP randomized controlled trial. Medical Decision Making. 2007;27(5):575-84. [pmid: 17898242].
88 Shaw ST Jr., Aaronson DE, Moyer DL. Quantitation of menstrual blood loss—further evaluation of the alkaline hematin method. Contraception. Jun. 1972;5(6):497-513. [pmid: 4650663].
89 Hallberg L, Nilsson L. Determination of menstrual blood loss. Scand J Clin Lab Invest. 1964;16:244-8. [pmid: 14161862].
90 Zakherah MS, Sayed GH, El-Nashar SA, et al. Pictorial blood loss assessment chart in the evaluation of heavy menstrual bleeding: diagnostic accuracy compared to alkaline hematin. Gynecol Obstet Invest. 2011;71(4):281-4. [pmid: 21228538].
91 Janssen CA, Scholten PC, Heintz AP. A simple visual assessment technique to discriminate between menorrhagia and normal menstrual blood loss. Obstet Gynecol. Jun. 1995;85(6):977-82. [pmid: 7770270].
92 Higham JM, O'Brien PM, Shaw RW. Assessment of menstrual blood loss using a pictorial chart. Br J Obstet Gynaecol. Aug. 1990;97(8):734-9. [pmid: 2400752].
93 Fraser IS, McCarron G, Markham R. A preliminary study of factors influencing perception of menstrual blood loss volume. Am J Obstet Gynecol. Aug. 1. 1984;149(7):788-93. [pmid: 6380294].
94 Stacey D, Bennett CL, Barry MJ, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. 2011;(10):CD001431. [pmid: 21975733].
95 Gemzell-Danielsson K, Inki P, Boubli L, et al. Bleeding pattern and safety of consecutive use of the levonorgestrel-releasing intrauterine system (LNG-IUS)—a multicentre prospective study. Hum Reprod. Feb. 2010;25(2):354-9. [pmid: 19955104].
96 Glucophage [package insert]. Princeton, NJ. Bristol-Myers Squibb Company. 2009.
97 Spiller HA, Quadrani DA. Toxic effects from metformin exposure. Ann Pharmacother. May. 2004;38(5):776-80. [pmid: 15031415].
98 Chan KA, Truman A, Gurwitz JH, et al. A cohort study of the incidence of serious acute liver injury in diabetic patients treated with hypoglycemic agents. Arch Intern Med. Mar. 24. 2003;163(6):728-34. [pmid: 12639207].
99 Bodmer M, Meier C, Krahenbuhl S, et al. Metformin, sulfonylureas, or other antidiabetes drugs and the risk of lactic acidosis or hypoglycemia: a nested case-control analysis. Diabetes Care. Nov. 2008;31(11):2086-91. [pmid: 18782901].
100 Lewis JD, Capra AM, Achacoso NS, et al. Medical therapy for diabetes is associated with increased use of lower endoscopy. Pharmacoepidemiol Drug Saf. Nov. 2007;16(11):1195-202. [pmid: 17603822].
101 LeBlanc E, O'Connor E, Whitlock EP, et al. Screening for and Management of Obesity and Overweight in Adults. Evidence Report No. 89. AHRQ Publication No. 11-05159-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. Oct. 2011.
102 Salpeter SR, Greyber E, Pasternak GA, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2010;(1):CD002967. [pmid: 20091535].
103 Salvo F, Fourrier-Reglat A, Bazin F, et al. Cardiovascular and gastrointestinal safety of NSAIDs: a systematic review of meta-analyses of randomized clinical trials. Clin Pharmacol Ther. Jun. 2011;89(6):855-66. [pmid: 21471964].
104 Bennett WL, Wilson LM, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. AHRQ Publication No. 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. Mar. 2011.
105 Saenz A, Fernandez-Esteban I, Mataix A, et al. Metformin monotherapy for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005;(3):CD002966. [pmid: 16034881].
106 Qaseem A, Humphrey LL, Sweet DE, et al. Oral pharmacologic treatment of type 2 diabetes mellitus: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Feb. 7. 2012;156(3):218-31. [pmid: 22312141].
107 Byetta [package insert]. San Diego, CA. Amylin Pharmaceuticals, Inc. 2011.
108 Dore DD, Seeger JD, Arnold Chan K. Use of a claims-based active drug safety surveillance system to assess the risk of acute pancreatitis with exenatide or sitagliptin compared to metformin or glyburide. Curr Med Res Opin. Apr. 2009;25(4):1019-27. [pmid: 19278373].
109 Dore DD, Bloomgren GL, Wenten M, et al. A cohort study of acute pancreatitis in relation to exenatide use. Diabetes Obes Metab. Jun. 2011;13(6):559-66. [pmid: 21320263].
110 Elashoff M, Matveyenko AV, Gier B, et al. Pancreatitis, pancreatic, and thyroid cancer with glucagon-like peptide-1-based therapies. Gastroenterology. Jul. 2011;141(1):150-6. [pmid: 21334333].
111 Waugh N, Cummins E, Royle P, et al. Newer Agents for Blood Glucose Control in Type 2 Diabetes (Supplement). London. National Institute for Health and Clinical Excellence. 2009.
112 Shyangdan DS, Royle P, Clar C, et al. Glucagon-like peptide analogues for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2011;(10):CD006423. [pmid: 21975753].
113 Aygestin [package insert]. Sellersville, PA. Teva Women's Health, Inc. 2010.
114 Crinone [package insert]. Livingston, NJ. Columbia Laboratories, Inc. 2009.
115 Depo-Provera CI [package insert]. New York, NY. Pharmacia & Upjohn Company. 2011.
116 Provera [package insert]. New York, NY. Pharmacia and Upjohn Company. 2009.
117 van Hylckama Vlieg A, Helmerhorst FM, Rosendaal FR. The risk of deep venous thrombosis associated with injectable depot-medroxyprogesterone acetate contraceptives or a levonorgestrel intrauterine device. Arterioscler Thromb Vasc Biol. Nov. 2010;30(11):2297-300. [pmid: 20798377].
118 Vestergaard P, Rejnmark L, Mosekilde L. The effects of depot medroxyprogesterone acetate and intrauterine device use on fracture risk in Danish women. Contraception. Dec. 2008;78(6):459-64. [pmid: 19014791].
119 Rosenberg L, Zhang Y, Constant D, et al. Bone status after cessation of use of injectable progestin contraceptives. Contraception. Dec. 2007;76(6):425-31. [pmid: 18061699].
120 Aktun H, Moroy P, Cakmak P, et al. Depo-Provera: use of a long-acting progestin injectable contraceptive in Turkish women. Contraception. Jul. 2005;72(1):24-7. [pmid: 15964288].
121 Lidegaard O, Lokkegaard E, Jensen A, et al. Thrombotic stroke and myocardial infarction with hormonal contraception. N Engl J Med. Jun. 14. 2012;366(24):2257-66. [pmid: 22693997].
122 Sundstrom A, Seaman H, Kieler H, et al. The risk of venous thromboembolism associated with the use of tranexamic acid and other drugs used to treat menorrhagia: a case-control study using the General Practice Research Database. BJOG. Jan. 2009;116(1):91-7. [pmid: 19016686].
123 Lethaby A, Irvine G, Cameron I. Cyclical progestogens for heavy menstrual bleeding. Cochrane Database Syst Rev. 2008;(1):CD001016. [pmid: 18253983].
124 Grimes DA, Lopez LM, O'Brien PA, et al. Progestin-only pills for contraception. Cochrane Database Syst Rev. 2010;(1):CD007541. [pmid: 20091638].
125 Natazia [package insert]. Wayne, NJ. Bayer HealthCare Pharmaceuticals, Inc. 2012.
126 Loestrin 1/20 [package insert]. Pomona, NY. Duramed Pharmaceuticals, Inc. 2009.
127 Nordette [package insert]. Sellersville, PA. Teva Pharmaceuticals USA, Inc. 2010.
128 Ortho Tri-Cyclen [package insert]. Raritan, NJ. Ortho-McNeil-Janssen Pharmaceuticals, Inc. 2010.
129 Manzoli L, De Vito C, Marzuillo C, et al. Oral contraceptives and venous thromboembolism: a systematic review and meta-analysis. Drug Saf. Mar. 1. 2012;35(3):191-205. [pmid: 22283630].
130 Martinez F, Ramirez I, Perez-Campos E, et al. Venous and pulmonary thromboembolism and combined hormonal contraceptives. Systematic review and meta-analysis. Eur J Contracept Reprod Health Care. Feb. 2012;17(1):7-29. [pmid: 22239262].
131 Gallo MF, Lopez LM, Grimes DA, et al. Combination contraceptives: effects on weight. Cochrane Database Syst Rev. 2011;(9):CD003987. [pmid: 21901687].
132 Lawrie TA, Helmerhorst FM, Maitra NK, et al. Types of progestogens in combined oral contraception: effectiveness and side-effects. Cochrane Database Syst Rev. 2011;(5):CD004861. [pmid: 21563141].
133 Edelman AB, Gallo MF, Jensen JT, et al. Continuous or extended cycle vs. cyclic use of combined oral contraceptives for contraception. Cochrane Database Syst Rev. 2005;(3):CD004695. [pmid: 16034942].
134 Van Vliet HA, Grimes DA, Helmerhorst FM, et al. Biphasic versus triphasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2006;(3):CD003283. [pmid: 16856002].
135 Van Vliet HA, Grimes DA, Lopez LM, et al. Triphasic versus monophasic oral contraceptives for contraception. Cochrane Database Syst Rev. 2011;(11):CD003553. [pmid: 22071807].
136 Cabergoline [package insert]. Sellersville, PA. Teva Pharmaceuticals. 2011.
137 Andersohn F, Garbe E. Cardiac and noncardiac fibrotic reactions caused by ergot-and nonergot-derived dopamine agonists. Mov Disord. Jan. 15. 2009;24(1):129-33. [pmid: 19170199].
138 Schade R, Andersohn F, Suissa S, et al. Dopamine agonists and the risk of cardiac-valve regurgitation. N Engl J Med. Jan. 4. 2007;356(1):29-38. [pmid: 17202453].
139 Renoux C, Dell'Aniello S, Brophy JM, et al. Dopamine agonist use and the risk of heart failure. Pharmacoepidemiol Drug Saf. Jan. 2012;21(1):34-41. [pmid: 22109939].
140 Tang H, Hunter T, Hu Y, et al. Cabergoline for preventing ovarian hyperstimulation syndrome. Cochrane Database Syst Rev. 2012;(2):CD008605. [pmid: 22336848].
141 Scholz H, Trenkwalder C, Kohnen R, et al. Dopamine agonists for restless legs syndrome. Cochrane Database Syst Rev. 2011;(3):CD006009. [pmid: 21412893].
142 Rasmussen VG, Ostergaard K, Dupont E, et al. The risk of valvular regurgitation in patients with Parkinson's disease treated with dopamine receptor agonists. Mov Disord. Apr. 2011;26(5):801-6. [pmid: 21671508].
143 Bogazzi F, Manetti L, Raffaelli V, et al. Cabergoline therapy and the risk of cardiac valve regurgitation in patients with hyperprolactinemia: a meta-analysis from clinical studies. J Endocrinol Invest. Dec. 2008;31(12):1119-23. [pmid: 19246980].
144 Smith CA, Zhu X, He L, et al. Acupuncture for primary dysmenorrhoea. Cochrane Database Syst Rev. 2011;(1):CD007854. [pmid: 21249697].
145 Zhu X, Hamilton KD, McNicol ED. Acupuncture for pain in endometriosis. Cochrane Database Syst Rev. 2011;(9):CD007864. [pmid: 21901713].
146 Cheong YC, Hung Yu, Ng E, Ledger WL. Acupuncture and assisted conception. Cochrane Database Syst Rev. 2008;(4):CD006920. [pmid: 18843737].
147 Smith CA, Crowther CA. Acupuncture for induction of labour. Cochrane Database Syst Rev. 2004;(1):CD002962. [pmid: 14973999].
148 Mirena [package insert]. Wayne, NJ. Bayer HealthCare Pharmaceuticals, Inc. 2009.
149 FDA. FDA approves additional use for IUD Mirena to treat heavy menstrual bleeding in IUD users [Internet]. 2009. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/2009/ucm184747.htm. May 11, 2012.
150 FDA. Statistics filing memorandum for a supplemental NDA (Mirena). FDA. 2009. http://www.fda.gov/downloads/Drugs/DevelopmentApprovalProcess/DevelopmentResources/UCM245687.pdf.
151 Zhou L, Harrison-Woolrych M, Coulter DM. Use of the New Zealand Intensive Medicines Monitoring Programme to study the levonorgestrel-releasing intrauterine device (Mirena). Pharmacoepidemiol Drug Saf. Jul-Aug. 2003;12(5):371-7. [pmid: 12899110].
152 Harrison-Woolrych M, Zhou L, Coulter D. Insertion of intrauterine devices: a comparison of experience with Mirena and Multiload Cu 375 during post-marketing monitoring in New Zealand. N Z Med J. Aug. 8. 2003;116(1179):U538. [pmid: 14513085].
153 Paterson H, Clifton J, Miller D, et al. Hair loss with use of the levonorgestrel intrauterine device. Contraception. Oct. 2007;76(4):306-9. [pmid: 17900442].
154 Van Houdenhoven K, van Kaam KJ, van Grootheest AC, et al. Uterine perforation in women using a levonorgestrel-releasing intrauterine system. Contraception. Mar. 2006;73(3):257-60. [pmid: 16472566].
155 van Grootheest K, Sachs B, Harrison-Woolrych M, et al. Uterine perforation with the levonorgestrel-releasing intrauterine device: analysis of reports from four national pharmacovigilance centres. Drug Saf. Jan. 1. 2011;34(1):83-8. [pmid: 21142273].
156 Lidegaard O, Nielsen LH, Skovlund CW, et al. Risk of venous thromboembolism from use of oral contraceptives containing different progestogens and oestrogen doses: Danish cohort study, 2001-9. BMJ. 2011;343:d6423. [pmid: 22027398].
157 Lethaby AE, Cooke I, Rees M. Progesterone or progestogen-releasing intrauterine systems for heavy menstrual bleeding. Cochrane Database Syst Rev. 2005;(4):CD002126. [pmid: 16235297].
158 Marjoribanks J, Lethaby A, Farquhar C. Surgery versus medical therapy for heavy menstrual bleeding. Cochrane Database Syst Rev. 2006;(2):CD003855. [pmid: 16625593].
159 French R, Van Vliet H, Cowan F, et al. Hormonally impregnated intrauterine systems (IUSs) versus other forms of reversible contraceptives as effective methods of preventing pregnancy. Cochrane Database Syst Rev. 2004;(3):CD001776. [pmid: 15266453].
160 NuvaRing [package insert]. Whitehouse Station, NJ. Merck & Co. 2012.
161 Merki-Feld GS, Hund M. Clinical experience with NuvaRing in daily practice in Switzerland: cycle control and acceptability among women of all reproductive ages. Eur J Contracept Reprod Health Care. Sep. 2007;12(3):240-7. [pmid: 17763262].
162 Brucker C, Karck U, Merkle E. Cycle control, tolerability, efficacy and acceptability of the vaginal contraceptive ring, NuvaRing: results of clinical experience in Germany. Eur J Contracept Reprod Health Care. Mar. 2008;13(1):31-8. [pmid: 17853162].
163 Brache V, Faundes A. Contraceptive vaginal rings: a review. Contraception. Nov. 2010;82(5):418-27. [pmid: 20933115].
164 Martins SL, Curtis KM, Glasier AF. Combined hormonal contraception and bone health: a systematic review. Contraception. May. 2006;73(5):445-69. [pmid: 16627030].
165 Rott H. Thrombotic risks of oral contraceptives. Curr Opin Obstet Gynecol. Aug. 2012;24(4):235-40. [pmid: 22729096].
166 Flurbiprofen tablet [package insert]. Detroit, MI. Caraco Pharmaceutical Laboratories, Inc. 2007.
167 Meclofenamate sodium [package insert]. Morgantown, WV. Mylan Pharmaceuticals, Inc. 2006.
168 Naprosyn [package insert]. South San Francisco, CA. Genentech USA, Inc. 2010.
169 Marjoribanks J, Proctor M, Farquhar C, et al. Nonsteroidal anti-inflammatory drugs for dysmenorrhoea. Cochrane Database Syst Rev. 2010;(1):CD001751. [pmid: 20091521].
170 Garcia Rodriguez LA, Gonzalez-Perez A, Bueno H, et al. NSAID use selectively increases the risk of non-fatal myocardial infarction: a systematic review of randomised trials and observational studies. PLoS One. 2011;6(2):e16780. [pmid: 21347435].
171 Lysteda [package insert]. Parsippany, NJ. Ferring Pharmaceutical. 2011.
172 FDA. New Drug Application: 22-430 (Tranexamic Acid) Summary Review. Center for Drug Evaluation and Research. 2009. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2009/022430s000sumr.pdf.
173 Naoulou B, Tsai MC. Efficacy of tranexamic acid in the treatment of idiopathic and non-functional heavy menstrual bleeding: A systematic review. Acta Obstet Gynecol Scand. May. 2012;91(5):529-37. [pmid: 22229782].
174 Lethaby A, Farquhar C, Cooke I. Antifibrinolytics for heavy menstrual bleeding. Cochrane Database Syst Rev. 2000;(4):CD000249. [pmid: 11034679].
175 Sukeik M, Alshryda S, Haddad FS, et al. Systematic review and meta-analysis of the use of tranexamic acid in total hip replacement. J Bone Joint Surg Br. Jan. 2011;93(1):39-46. [pmid: 21196541].
176 Alshryda S, Sarda P, Sukeik M, et al. Tranexamic acid in total knee replacement: a systematic review and meta-analysis. J Bone Joint Surg Br. Dec. 2011;93(12):1577-85. [pmid: 22161917].
177 Vuorma S, Teperi J, Aalto AM, et al. A randomized trial among women with heavy menstruation — impact of a decision aid on treatment outcomes and costs. Health Expect. Dec. 2004;7(4):327-37. [pmid: 15544685].
178 Stewart A, Cummins C, Gold L, et al. The effectiveness of the levonorgestrel-releasing intrauterine system in menorrhagia: a systematic review. BJOG. Jan. 2001;108(1):74-86. [pmid: 11213008].
179 Coulter A, Kelland J, Peto V, et al. Treating menorrhagia in primary care. An overview of drug trials and a survey of prescribing practice. Int J Technol Assess Health Care. Summer. 1995;11(3):456-71. [pmid: 7591547].
180 Stern D, Reissman D. Specialty pharmacy cost management strategies of private health care payers. J Manag Care Pharm. Nov-Dec. 2006;12(9):736-44. [pmid: 17249906].
181 Kim YA, Rascati KL, Prasla K, et al. Retrospective evaluation of the impact of copayment increases for specialty medications on adherence and persistence in an integrated health maintenance organization system. Clin Ther. May. 2011;33(5):598-607. [pmid: 21665044].
182 Hartung DM, Carlson MJ, Kraemer DF, et al. Impact of a Medicaid copayment policy on prescription drug and health services utilization in a fee-for-service Medicaid population. Med Care. Jun. 2008;46(6):565-72. [pmid: 18520310].
183 Neugut AI, Subar M, Wilde ET, et al. Association between prescription co-payment amount and compliance with adjuvant hormonal therapy in women with early-stage breast cancer. J Clin Oncol. Jun. 20. 2011;29(18):2534-42. [pmid: 21606426].